# Methods

The methods for this systematic review follow the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Medical Test Reviews.3,20–23

## Literature Search Strategy

### Search Strategy

To identify articles relevant to each Key Question (KQ), we searched PubMed^®^, the Cochrane Library, and EMBASE^®^. The full search strategy is presented in Appendix A. We used either Medical Subject Headings (MeSH) or major headings as search terms when available or key words when appropriate, focusing on terms to describe the relevant cancers and tests of interest. Searches were run by an experienced information scientist serving as the Evidence-based Practice Center (EPC) librarian and were peer reviewed by another information scientist.

We limited the electronic searches to English-language, adult, and human-only studies. Sources were searched from inception through November 2013. We manually searched reference lists of pertinent review articles and studies meeting our inclusion criteria to look for any relevant citations that our searches might have missed. We imported all citations into an EndNote^®^ X5 (Thomson Reuters, New York, NY) electronic database.

We also searched for unpublished studies relevant to this review using test developers’ Web sites, ClinicalTrials.gov, the Food and Drug Administration (FDA) Web site, Health Services Research Projects in Progress, and the European Union Clinical Trials Register. In addition, we requested unpublished information from the College of American Pathologists (CAP) and from the relevant companies, asking for data that they believe should be considered for the review. In cases in which relevant information was unclear or not reported, we contacted authors to get additional or unpublished information.

Any literature suggested by reviewers was investigated and, if appropriate, incorporated into the final review. We determined appropriateness for inclusion in the review by the same methods described in this chapter.

### Eligibility Criteria

We developed eligibility (inclusion and exclusion) criteria for Populations, Interventions (i.e., tests for this report), Comparators, Outcomes, Timing, Settings (PICOTS), and study designs (Table 3). We included studies meeting the criteria described in Table 3 that were relevant to at least one of the KQs.

Table 3 Inclusion/exclusion criteria

Category | Inclusion | Exclusion
Population | Adult patients (19 years of age or older) with cancer of the colon/rectum, breast, lung, or urinary bladder (cancer types known to be of higher incidence in the core Medicare beneficiary population [people 65 years of age or older]) | People 18 years of age or younger; all other tumor types and sites. Studies focused on a population with advanced/metastatic cancer.
Interventions (i.e., tests) | The following molecular pathology tests when used alone or in combination with “traditional” prognostic factors to measure the likelihood of malignant tumor recurrence (e.g., tumor size, tumor grade, estrogen receptor status; see Table 1): Lung cancer: ALK, EGFR, KRAS CRC: Microsatellite instability (MSI), MLH1 promoter methylation, KRAS, BRAF, Oncotype DX Colon Breast cancer: Oncotype DX Breast, MammaPrint Urinary bladder cancer: UroVysion | Molecular pathology tests used to measure the likelihood of malignant tumor recurrence that are not commercially available in the United States. Studies focused on predicting response to treatments (e.g., studies focused on response to gefitinib for people with advanced lung cancer).
Comparators | We will compare the molecular pathology tests listed above with standard tests or markers (see Introduction) used to measure the likelihood of malignant tumor recurrence. We will collect information about comparators as they are defined and reported in each study. For KQs 1, 4, and 5, we are looking for studies that compare an eligible molecular pathology test plus all known prognostic factors with all known prognostic factors alone to isolate whether the test adds any value (benefit) or introduces additional harms (KQ 5). Alternatively, studies that compare an eligible molecular pathology test alone with known prognostic factors are also eligible for inclusion. If a study uses most of the known prognostic factors but not all of them, it could also meet our inclusion criteria, and the comparison would be considered in the risk of bias (RoB) assessment (related mainly to confounding and approach to statistical adjustment). For KQ 2 (analytic validity), comparators also include intra- and interlaboratory repeat testing of samples. For KQ 3 (clinical validity), cohort studies that do the test on everyone, follow them over some period of time to capture relevant outcomes, and then do a multivariate analysis to adjust for known factors and to determine whether the tests have prognostic value for predicting recurrence are eligible. Such studies must compare those with different test results (e.g., those with a mutation versus those who are wild-type) to establish prognostic value, adjusted for known factors. To inform whether molecular pathology tests add value above standard prognostic factors, results must be adjusted for known prognostic factors (or they must be addressed in other ways, such as through inclusion/exclusion criteria of the study or stratification). Relevant case-control studies for KQ 3 could compare cases (people with recurrence) and controls (without recurrence) by rates of exposure (e.g., test positive vs. test negative), adjusting for known prognostic factors. | Unadjusted studies demonstrating associations between test results (e.g., those with a mutation versus those who are wild-type) and outcomes.
Outcomes | [underlined: KQ 1. Overarching question.] Studies must provide direct evidence of the impact of a test of interest on physician decision-making (regarding the use of adjuvant anti-neoplastic chemo- and/or radiotherapy, enhanced diagnostic testing for recurrence, or preventive surgery) and also on health outcomes (overall survival, disease-free survival, time to recurrence, or quality of life). [underlined: KQ 2. Analytic validity] Tissue sample acceptance/rejection criteria. Sensitivity/specificity of testing for each marker at assay conditions. Degree of variation in the results if the same tumor is tested in multiple laboratories. Uniqueness of the markers used in the panel and their robustness to contamination. Quality control standards for considering the validity of the overall assay (for multiplex tests). Proportion of probes or antibodies that must return a valid result (for multiplex tests). [underlined: KQ 3. Clinical validity] Prognostic value for recurrence (e.g., time to recurrence and disease-free survival) and overall survival. Differences in prognostic value associated with patient characteristics. Differences in prognostic value between non-Medicare and Medicare population. [underlined: KQ 4. Clinical utility] 4a. Decision-making Modification of physician decisions regarding the use of the following: adjuvant anti-neoplastic chemo- and/or radiotherapy enhanced diagnostic testing for recurrence preventive surgery 4b. Health outcomes Overall survival, disease-free survival, time to recurrence, quality of life (must be assessed using a valid and reliable quality-of-life measurement tool) [underlined: KQ 5. Harms] Adverse effects of tests, adverse effects of adjuvant therapy, decreased quality of life | Prediction of response to treatment. Progression-free survival is not an eligible outcome.
Time Frame/ Duration | We will include studies of any duration that otherwise meet inclusion criteria.
Study Designs | Include/eligible study designs, by KQ: KQ 1a. Randomized controlled trials (RCTs), non-RCTs, prospective cohort studies with eligible comparison groups, and case-control studies that directly assess the impact of a test of interest on physician decision-making (regarding the use of adjuvant antineoplastic chemo- and/or radiotherapy, enhanced diagnostic testing for recurrence, or preventive surgery) and also on health outcomes (overall survival, disease-free survival, time to recurrence, or quality of life). KQ 2. Collaborative studies using panels (ideally large panels) of well-characterized samples, data from external proficiency testing schemes, data from inter-laboratory comparison programs, test and retest of samples, or validation studies (including those from manufacturers). KQ 3. Prospective and retrospective cohort studies and case-control studies with eligible comparison groups. This could also include publications of validated clinical decision algorithms that were developed using cohort data to quantify the contributions of different variables (e.g., molecular pathology test result, tumor size, tumor grade) in order to determine classification/interpretation of a molecular pathology test result for prognosis. KQ 4a. RCTs, non-RCTs, prospective and retrospective cohort studies with eligible comparison groups, and case-control studies. Case series will be considered for KQ 4a for decision-making outcomes only if other eligible study designs are not available. KQ 4b.^a^RCTs, non-RCTs, prospective and retrospective cohort studies with eligible comparison groups, and case-control studies. KQ 5. RCTs, non-RCTs, prospective and retrospective cohort studies with eligible comparison groups, and case-control studies. | Non-English publications, systematic and nonsystematic reviews, case series (except as noted for KQ 4a; we determined that the RoB in case series is too high to provide valid and reliable information for the other KQs), letters, editorials, abstracts, and observational studies without comparison groups.
Settings | Any country (no limits)

a An RCT that randomized subjects to use a molecular pathology testmolecular pathology test alone or in combination with standard prognostic factors compared with standard prognostic factors alone to inform decisions and that reported health outcomes would address the overarching question (KQ 1), whereas KQ 4b would include studies that evaluated the link between decisions and health outcomes.

Abbreviations: ALK = gene name; BRAF = gene name; DX = diagnosis; EGFR = gene name; KQ = Key Question; KRAS = gene name; MLH-1 = gene name promoter hypermethylation; MSI = microsatellite instability; RCT = randomized controlled trial; RoB = risk of bias.

### Study Selection

We developed and pilot tested review forms for review of titles/abstracts and full texts. All references were tracked in a Microsoft Excel^®^ Version 14.0 (Microsoft Corporation, Redmond, WA) database. Two trained members of the research team independently reviewed each title and abstract identified through searches for eligibility. Studies marked for possible inclusion by either reviewer underwent a full-text review. For studies that lacked adequate information to determine inclusion or exclusion, we retrieved the full text and then made the determination. If the necessary information in full-text articles was unclear or missing, we contacted authors of the publications.

Two trained members of the research team independently reviewed each full-text article for inclusion or exclusion based on the eligibility criteria described above. If both reviewers agreed that a study did not meet the eligibility criteria, we excluded it. If the reviewers disagreed, they resolved conflicts by discussion and consensus or by consulting a third member of the review team. We recorded the principal reason that each excluded full-text publication did not satisfy the eligibility criteria (Appendix B).

### Data Extraction

For studies that met our inclusion criteria, we extracted study characteristics and results into evidence tables. We designed, pilot tested, and used structured data extraction forms to gather pertinent information from each article; this included characteristics of study populations, settings, interventions, comparators, study designs, methods, and results. Trained reviewers extracted the relevant data from each included article into the data extraction forms. All data extractions were reviewed for completeness and accuracy by a second member of the team. All data extraction was performed using Microsoft Excel^®^ software.

## Risk-of-Bias Assessment of Individual Studies

We assessed the RoB (internal validity) in the reviewed studies using an approach supported by the Methods Guide for Medical Test Reviews.3 For studies of analytic validity, we considered the potential for bias due to flaws in the sample selection, testing protocol, reference standards, verification procedures, interpretation, and/or analysis. We used the questions relevant for prognostic tests from the QUADAS-2^24,25^ (which was developed for diagnostic tests) for assessing risk of relevant biases. For studies of clinical validity and clinical utility, we assessed the potential for selection bias, confounding, performance bias, attrition bias, and detection bias. We assessed these biases using relevant questions and predefined criteria based on guidance from the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews and the RTI Question Bank.26

We summarized RoB for each study as low, medium, high, or unclear. In general, studies with a low RoB are those that have a low risk of selection bias, use valid and reliable outcome measures, use appropriate statistical and analytical methods, have low attrition, and report methods and outcomes clearly and precisely. Studies with a medium RoB are those that do not meet all criteria required for low RoB but do not have flaws that are likely to cause major bias. Missing information often led to ratings of medium as opposed to low RoB. Studies with inadequate reporting to allow assessment of RoB were described as having unclear RoB—this was often the case for abstracts from conference proceedings. Studies with a high RoB are those with at least one substantial flaw in the study’s design, conduct, or analysis that could invalidate the results. Two independent reviewers assessed the RoB for each study. Disagreements were resolved by discussion and consensus or by consulting a third member of the team. Appendix C details the criteria used for evaluating the RoB of all included studies and explains the rationale for high RoB ratings.

## Data Synthesis

For clinical validity, data were synthesized for each test by cancer type using meta-analytic techniques described in Hedges & Vevea.27 The measure of the effect size in most studies was a hazard ratio (HR). A few studies had odds ratios. A summary HR was estimated for any outcome that had three or more independent HR estimates. In cases where subpopulations from one study were included in the sample for another study, we used the study with the largest included population in our meta-analyses (to avoid double-counting any data). If studies provided separate estimates for different subsamples (e.g., node negative and node positive), both estimates were included if no overall HR was provided. If an overall HR for the entire sample and the separate HRs for subsamples were provided, then only the overall measure was used.

If the test is non-informative, we expect that the probability of experiencing the end point would be the same for either group, with an HR of 1. If the HR is greater than 1, the probability of the endpoint is higher in the group with the higher hazard. If the HR is lower than 1, the probability of experiencing the endpoint is lower in the group with the lower hazard. For example, an HR of 2 for CSS indicates that one group (e.g., those with high risk results for Oncotype DX Breast) has twice the rate per unit of time as the comparison group (e.g., those with low-risk test results).

The standard error (SE) of the HR was used to estimate the variance of the effect size. In most cases, the SE was estimated from the 95% confidence interval (CI). We tested the null hypothesis of homogeneity of effect sizes across the studies27,28 for each of the outcomes. If the null hypothesis was rejected at a significance level of 0.05, the summary HR was estimated using a random effects model; if not, it was estimated using a fixed effects model. In both cases, the inverse of the variance was used to estimate a weighted summary HR. Forest plots with indicators of the weight assigned to each study were used to help visualize the contributions of each study and to show the summary HR.

We did not include studies with a high or unclear RoB in our main analyses/main data syntheses.

## Strength of the Body of Evidence

We graded the strength of evidence (SOE) based on the guidance established for the Evidence-based Practice Center program Program.29,30 Developed to grade the overall strength of a body of evidence, this approach incorporates four key domains: RoB (includes study design and aggregate quality), consistency, directness, and precision of the evidence. It also considers other optional domains that may be relevant for some scenarios, such as a dose-response association, plausible confounding that would decrease the observed effect, strength of association (magnitude of effect), and publication bias. Table 4 defines the grades of evidence that we assigned.

Table 4 Definitions of the grades of overall strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Source: Owens et al., 2010^29^

For each test being evaluated in this review, two reviewers assessed each domain for each key outcome and determined an overall SOE grade based on domain ratings. In the event of disagreements on the domain or overall grade, they resolved differences by consensus discussion or by consulting with a third investigator.

We attempted to find studies that directly address the overarching question (KQ 1). If we did not find adequate direct evidence addressing the overarching question, we attempted to construct an indirect chain of evidence (using studies identified for the other KQs).

Appendix D includes tables showing our assessments for each domain and resulting SOE grades for each outcome, organized by type of cancer and test. We graded the SOE separately for analytic validity and for evidence on our overarching KQ. For analytic validity, we graded the SOE for the following: sensitivity and specificity, positive and negative predictive value, and cross-lab validity. For evidence on the overarching KQ, we graded the SOE for the following outcomes: risk of recurrence, cancer-specific survival, overall survival, and decisions about treatment.

## Applicability

We assessed applicability of the evidence following guidance from the Methods Guide for Comparative Effectiveness Reviews.28,31 We used the PICOTS framework to explore factors that affect applicability. Some factors identified that may limit the applicability of evidence include age, sex, and race or ethnicity of enrolled populations.

## Peer Review and Public Commentary

### Peer Review

The comments were generally favorable from the peer reviewers. Two main areas were identified as needing revisions.

1. Emphasizing that this report focused on the prognostic value of the tests and did not examine the predictive value of the tests (i.e., in predicting response to treatment).
2. Incorporating CAP’s information into the description of the analytic validity for the tests and general comments on improving the description of analytic validity of the tests.

We have incorporated these suggestions in the document.

### Public Comments

A lot of the public comments were from the manufacturers of the tests examined. Besides disputing some of the SOE grades and conclusions or suggesting revisions to KQs, one salient issue raised by a manufacturer was about including UroVysion in the report. Abbott Molecular pointed out that UroVysion was not designed or marketed as a test to assess prognosis and requested that the test be excluded from the report.

We have decided to keep UroVysion in the report but have added clear statements in various sections to clarify the intended use of the test.