# Discussion

Below, we summarize the main findings and strength of evidence (SOE). We then discuss implications for decision-making, limitations, future research, and conclusions.

## Key Findings and Strength of Evidence

We found no studies that directly addressed our overarching question (Key Question [KQ] 1) (i.e., no studies directly assessed the impact of a test of interest on physician decision-making and subsequent health outcomes). Further, no studies directly addressed whether modified decisions lead to improved health outcomes (KQ 4b, clinical utility), and none reported harms associated with treatment decisions that are informed by molecular pathology tests (KQ 5).

The majority of studies meeting inclusion criteria for our review focused on clinical validity (KQ 3), and they evaluated associations between prognostic tests and outcomes. For two tests, MammaPrint and Oncotype DX Breast, we found studies rated as low or medium risk of bias (RoB) addressing whether prognostic information provided by the molecular pathology tests modified treatment decisions (KQ 4a).

### Analytic Validity

Of the six molecular pathology tests with studies of low or medium RoB, the EGFR and KRAS mutation tests for lung cancer, the MammaPrint test for breast cancer, and the KRAS mutation test for colorectal cancer (CRC) were determined to have an overall moderate or high SOE for analytic validity (Table 41). Studies of these tests used fairly large panels of samples, were all low RoB, were directly measuring the test, and were consistent in their measurements.

Table 41 Summary of findings and strength of evidence for analytic validity

Test | Parameter | N studies; N subjects | Value | Strength of Evidence
MammaPrint: Breast | SS | 2;399 | NR | Moderate
MammaPrint: Breast | CV | 1;100 | NA | Low
EGFR: Lung: | SS | 5; 898 | Sensitivity range: 68–100%; Specificity range: 79–100% | Moderate
EGFR: Lung: | CV | 5;636 | Kappa score range: 0.20–0.73 | High
KRAS: Lung: | SS | 2;188 | NR | Moderate
KRAS: Lung: | CV | 4;686 | Kappa score range: 0.15–0.66 | High
BRAF: Colorectal | SS | 1;117 | NR | Insufficient
BRAF: Colorectal | CV | 3;533 | NA | High
KRAS: Colorectal | SS | 5;576 | Sensitivity range: 69–98%; Specificity range: 90–100% | High
KRAS: Colorectal | CV | 5;747 | Reproducibility: 98% | High
Oncotype DX: Colorectal: | SS | 1; NR | NR | Insufficient [
Oncotype DX: Colorectal: | CV | NA | NA | NA

Abbreviations: BRAF = gene name; CV = cross-lab validity; EGFR = gene name; KRAS = gene name; N = number; NA = not applicable; NR = not reported; SS = sensitivity and specificity.

The SOE for the overall analytic validities of the BRAF mutation test for CRC and the Oncotype DX Colon multigene assay for CRC were determined to be low. There were only one or two studies to consider, RoB was generally higher, and consistency was often unknown (when there was a single study). However, the BRAF mutation test for CRC, due to the CAP report data, showed a high SOE for cross-lab validity.

In general, we found limited evidence in the published literature assessing analytic validity of the included tests. For most of these tests, we found evidence from fewer than 200 subjects; just 2 of the tests (EGFR/Lung and KRAS/CRC) had more than 200 samples contributing to our SOE grade (Table 41).

However, the best data on reproducibility we found is from the College of American Pathologists’ report data for EGFR mutation testing, KRAS mutation testing, BRAF mutation testing, microsatellite instability for colorectal cancer, and UroVysion cytogenetics for urinary bladder cancer, which support the analytic validity of these tests.

In general, in most of the studies, tests were developed in the laboratories and compared with the gold standard of direct Sanger sequencing of the gene in formalin-fixed, paraffin-embedded tissue samples. We had very few studies directly assessing the analytic validity (test performance) using direct sequencing of frozen tissue (the current gold standard), which would be of great importance in determining the true analytic validity of the tests.

In general, the studies showed that their tests in comparison with the gold standard were of comparable marker sensitivity/specificity and had similar proportions of valid results (level of detection). Because the analytic validity, sensitivity, and specificity of direct sequencing of frozen tissue have not been established against their “true” tumor diagnosis, the false-positive rate cannot truly be determined for the other tests used in these studies. In Beau-Faller et al.,35 the false positive rate for direct sequencing of EGFR and KRAS was stated to be about 10 to 15 percent. Therefore, any numbers we have given for marker sensitivity/specificity and predictive value are estimates, assuming accurate direct sequencing.

### Clinical Validity

Included studies provided some evidence on clinical validity for 9 of the included tests, adjusted for known prognostic factors (Table 42). Evidence from multiple studies supports prognostic value , beyond known prognostic factors, for MammaPrint, Oncotype DX Breast, KRAS mutation testing for lung cancer, BRAF mutation testing for CRC, KRAS mutation testing for CRC, and microsatellite instability (MSI) for CRC for at least one of our included outcomes (i.e., risk of recurrence [RR], cancer-specific survival [CSS], or overall survival [OS]). For UroVysion, limited evidence from 2 small studies (total N=168) rated as low or medium RoB supported prognostic value for RR. None of the studies we evaluated suggested that EGFR added prognostic value to the traditional factors used to determine prognosis for lung cancer. For CRC, evidence did not adequately support added prognostic value for Oncotype DX Colon.

Table 42 Summary of findings on clinical validity (i.e., Association between Test Result and Prognosis)

Test: Cancer | Outcome | N studies; N subjects | Results Effect Size (95% CI) | Evidence from Multiple Studies Supports Association between Test Result and Prognosis?
MammaPrint: Breast | RR | 6; 1,913 | HR: 2.84 (2.11 to 3.89) for poor prognosis vs. good prognosis | Yes
MammaPrint: Breast | CSS | 5; 1,615 | HR: 3.3 (2.22 to 4.9) for poor prognosis vs. good prognosis | Yes
MammaPrint: Breast | OS | 1; 144 | HR: 1.67 (0.73 to 3.82) for poor prognosis vs. good prognosis | No
Oncotype DX Breast | RR | 6; 3,222 | HR: 2.97 (2.19 to 4.02) for high risk vs. low risk | Yes
Oncotype DX Breast | CSS | 2; 1,234 | HR: 2.02 (1.35 to 3.00) for high risk vs. low risk | Yes
Oncotype DX Breast | OS | 1; 668 | HR: 1.65 (1.24 to 2.19) for high risk vs. low risk | No, single study
EGFR Lung | RR | 6; 1,870 | HR: 0.87 (0.65 to 1.15); No association | No
EGFR Lung | CSS | 0; 0 | NA | No
EGFR Lung | OS | 6; 1,820 | HR: 0.76 (0.50 to 1.19); No association | No
KRAS Lung | RR | 4; 611 | 2.84 (1.14, 7.1) KRAS mutation associated with greater RR | Yes
KRAS Lung | CSS | 0; 0 | NA | No
KRAS Lung | OS | 2; 253 | 2.69 ( 1.91,3.8); 3.33 ( 1.03, 10.82) | Yesa
BRAF CRC | RR | 5; 4,106 | HR 1.07 (0.76 to 1.52) for wild-type vs. mutation | No
BRAF CRC | CSS | 7; 5,409 | HR 1.50 (1.26 to 1.77) for wild-type vs. mutation | Yes
BRAF CRC | OS | 11;7,610 | HR 1.45 (1.29 to 1.62) for wild-type vs. mutation | Yes
KRAS CRC | RR | 5; 4,085 | HR 1.02 (0.91 to 1.14) for wild-type vs. mutation | No
KRAS CRC | CSS | 2; 1,174 | HR 1.30 (1.02 to 1.66) for wild-type vs. mutation | Yes
KRAS CRC | OS | 10; 5,328 | HR 1.22 (0.93 to 1.60) for wild-type vs. mutation | No
MSI: CRC | RR | 10; 7,130 | HR 0.60 (0.50 to 0.72) for MSI-H vs. MSS | Yes
MSI: CRC | CSS | 6; 3,439 | HR 0.65 (0.51 to 0.82) for MSI-H vs. MSS | Yes
MSI: CRC | OS | 12; 8,839 | HR 0.57 (0.43 to 0.77) for MSI-H vs. MSS | Yes
Oncotype DX: CRC | RR | 1; 690 | HR 1.68 (1.18 to 2.38) | No, single study
Oncotype DX: CRC | CSS | 0; 0 | NA | No
Oncotype DX: CRC | OS | 0; 0 | NA | No
UroVysion: Bladder | RR | 2; 168 | Association between mutation and RR in 2 small studies | Yes, but limited to 168 subjects
UroVysion: Bladder | CSS | 0; 0 | NA | No
UroVysion: Bladder | OS | 0; 0 | NA | No

a Data synthesiswas done only when we had 3 or more HRs to combine to create a summary.

Notes: Table includes results of our main analyses that were based on studies rated as low or medium RoB. HRs reported are results of our meta-analyses of studies rated as low or medium RoB reporting adjusted associations for clinical validity (KQ 3).

Abbreviations: BRAF = gene name; CRC = colorectal cancer; CSS = cancer-specific survival; EGFR = gene name; HR = hazard ratio; KRAS = gene name; MSI = microsatellite instability; MSI-H = microsatellite instability high; MSS = microsatellite stability: N = number; NA = not applicable; OS = overall survival; RR = risk of recurrence; vs. = versus.

#### Breast Cancer: MammaPrint

Our meta-analysis suggests that patients classified as having a poor prognosis by MammaPrint consistently do worse than those with a good prognosis signature with respect to distant metastatis-free survival and CSS. Studies included in the search varied somewhat in the subpopulations they tested; the fact that the signature added prognostic value across these various subpopulations suggests that it has broad applicability. Because no studies looked at the value of MammaPrint with respect to loco-regional recurrence (LRR) and only one considered overall survival, there is scant or no evidence regarding the clinical validity of the MammaPrint signature in terms of these outcomes.

#### Breast Cancer: Oncotype DX

Some evidence indicates that the risk score (RS) estimated by Oncotype DX adds prognostic value in predicting distant recurrence and CSS. The two included studies that used LRR as an outcome reported that the RS does not add value in determining prognosis (with respect to LRR). Thus, evidence suggests that the Oncotype DX score adds value in determining prognosis for distant metastasis and CSS but not for LRR.

##### Lung Cancer: KRAS mutation

Some evidence suggest that testing for KRAS mutations has added prognostic value in lung cancer for both RR and OS. Our meta-analysis resulted in significant HRs for both RR and OS. There were no studies that looked at CSS. The results seem to hold for all stages. However, because the studies did not examine differences by race, age, or gender, it is not known if the prognostic value of the mutation varies by any of these factors.

#### Colorectal Cancer: BRAF Mutation

Evidence suggests that BRAF mutation does not have added prognostic value for RR. But our meta-analysis found that BRAF mutation testing has prognostic value for CSS and OS. The populations studied included proximal and distal colon cancers as well as rectal cancers. The studies did not examine if the risk varied by race, age, or gender. The results seem to hold for proximal, distal, and rectal cancers. However, because the studies did not examine differences by race, age, or gender, it is not known if the prognostic value of the mutation varies by any of these factors.

#### Colorectal Cancer: KRAS Mutation

Evidence suggests that KRAS mutation does not have added prognostic value for RR or OS. But our meta-analysis found that KRAS mutation testing has prognostic value for CSS. The populations studied included proximal and distal colon cancers as well as rectal cancers. The studies did not examine if the risk varied by race, age, or gender. The results seem to hold for proximal, distal, and rectal cancers. However, because the studies did not examine differences by race, age, or gender, it is not known if the prognostic value of the mutation varies by any of these factors.

#### Colorectal Cancer: MSI

Our meta-analyses found that testing for MSI adds prognostic value with respect to RR, CSS, and OS in CRC patients. Patients with MSI-H tumors have a lower risk of recurrence, death due to CRC, and death due to any cause compared with patients with MSS tumors.

The studies included looked at proximal, distal, and rectal cancers but did not look for differences by race, age, or gender. Thus, although it is possible to say that in general MSI-H has a protective effect for CRC patients, evidence was lacking to allow determination of whether protection varies by race, age, or gender.

### Clinical Utility and the Overarching Question

We found no studies that directly addressed our overarching question (KQ 1) (i.e., no studies directly assessed the impact of test use on downstream health outcomes). We attempted to construct an indirect chain of evidence to answer the overarching question, but no studies addressed whether modified decisions lead to improved health outcomes (KQ 4b, clinical utility), so we were unable to do so. The furthest downstream evidence that we found addressed whether prognostic information provided by the molecular pathology tests modifies treatment decisions (KQ 4a); we found such evidence for three tests, MammaPrint, Oncotype DX Breast, and Oncotype DX Colon (but the three studies identified for Oncotype DX Colon were rated as high or unclear risk of bias).

For impact on treatment decisions, we found moderate SOE that one test, Oncotype DX Breast, leads to changes in decisions. Although the decision changes were observed in both directions for individual patients, studies consistently showed an overall shift to less-intensive treatment recommendations as a result of using Oncotype DX Breast, with fewer recommendations for chemotherapy (and therefore less exposure to potential harms of chemotherapy; but studies did not follow patients to actually report on harms or to assess the overall balance of clinical benefits and harms).We found just one study of low or medium RoB for the impact of MammaPrint on treatment decisions, and we concluded that evidence was insufficient to determine the impact of MammaPrint on treatment decisions, primarily because of unknown consistency and imprecision.

Table 43 summarizes the evidence on the overarching question, clinical utility, and the impact of test use on treatment decisions. Ultimately, for the reasons described above, we found insufficient SOE to answer the overarching question for most tests. Even in the cases where the tests seemed to add value in determining prognosis (i.e., evidence of clinical validity), we found no direct evidence that using the test was related to improved outcomes for patients. For a few tests, we found low SOE, suggesting that using the test would not improve outcomes for patients—for these tests we found evidence that did not support clinical validity (because with evidence suggesting lack of clinical validity, it is unlikely that the tests will be found to have clinical utility).

Table 43 Summary of findings and strength of evidence for impact on treatment decisions, clinical utility, and our overarching question

Test: Cancer | Outcome | N studies; N subjects | Conclusions | Strength of Evidence
MammaPrint: Breast | RR | 6; 1,913 | All studies assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
MammaPrint: Breast | CSS | 5; 1,615 | All studies assessed clinical validity; no evidence that test use leads to improved CSS | Insufficient
MammaPrint: Breast | OS | 1; 144 | Study assessed clinical validity; no evidence that test use leads to improved morality | Insufficient
MammaPrint: Breast | Decisions about Rx | 1; 427 | Adjuvant therapy was used less if the prognosis signature is used | Insufficient
Oncotype DX Breast | RR | 6; 3,222 | All studies assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
Oncotype DX Breast | CSS | 2; 1,234 | All studies assessed clinical validity; no evidence that test use leads to improved CSS | Insufficient
Oncotype DX Breast | OS | 1; 668 | All studies assessed clinical validity; no evidence that test use leads to improved mortality | Insufficient
Oncotype DX Breast | Decisions about Rx | 16; 2,251 | ~30% of treatment decisions changed by the test | Moderate
EGFR Lung | RR | 6; 1,870 | All studies assessed clinical validity and found no prognostic value; test is unlikely to improve outcomes | Low
EGFR Lung | CSS | 0; 0 | NA | Insufficient
EGFR Lung | OS | 6;1,820 | No prognostic value; none of the reported HRs were statistically significant; test unlikely to improve mortality | Low
EGFR Lung | Decisions about Rx | 0; 0 | NA | Insufficient
KRAS Lung | RR | 4; 611 | All studies assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
KRAS Lung | CSS | 0; 0 | NA | Insufficient
KRAS Lung | OS | 2; 253 | Studies assessed clinical validity; no prognostic value; no evidence that test use leads to improved mortality | Insufficient
KRAS Lung | Decisions about Rx | 0; 0 | NA | Insufficient
BRAF CRC | RR | 5; 4,106 | All studies assessed clinical validity; no prognostic value; test is unlikely to improve outcomes | Low
BRAF CRC | CSS | 7; 5,409 | All studies assessed clinical validity; no evidence that test use leads to improved CSS | Insufficient
BRAF CRC | OS | 10; 7,610 | All studies assessed clinical validity; no evidence that test use leads to improved mortality | Insufficient
BRAF CRC | Decisions about Rx | 0; 0 | NA | Insufficient
KRAS CRC | RR | 5; 4,085 | All studies assessed clinical validity; no prognostic value; test is unlikely to improve outcomes | Low
KRAS CRC | CSS | 2; 1,174 | All studies assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
KRAS CRC | OS | 10; 5,328 | All studies assessed clinical validity; no prognostic value; test is unlikely to improve mortality | Low
KRAS CRC | Decisions about Rx | 0; 0 | NA | Insufficient
MSI: CRC | RR | 10; 7,130 | All studies assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
MSI: CRC | CSS | 6; 3,439 | All studies assessed clinical validity; no evidence that test use leads to improved CSS | Insufficient
MSI: CRC | OS | 12; 8,839 | All studies assessed clinical validity; no evidence that test use leads to improved mortality | Insufficient
MSI: CRC | Decisions about Rx | 0; 0 | NA | Insufficient
Oncotype DX: CRC | RR | 1; 690 | Study assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
Oncotype DX: CRC | CSS | 0; 0 | NA | Insufficient
Oncotype DX: CRC | OS | 0; 0 | NA | Insufficient
Oncotype DX: CRC | Decisions about Rx | 0; 0 | NA | Insufficient
UroVysion: Bladder | RR | 2; 168 | Both studies assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
UroVysion: Bladder | CSS | 0; 0 | NA | Insufficient
UroVysion: Bladder | OS | 0; 0 | NA | Insufficient
UroVysion: Bladder | Decisions about Rx | 0; 0 | NA | Insufficient

Notes: Table included results of our main analyses that were based on studies rated as low or medium RoB. HRs reported are results of our meta-analyses of studies rated as low or medium RoB reporting adjusted associations for clinical validity (KQ 3).

Strength of evidence grades are for the overarching question not for clinical validity (i.e., not for prognostic value or accuracy).

Abbreviations: BRAF = gene name; CRC = colorectal cancer; CSS = cancer-specific survival; EGFR = gene name; HR = hazard ratio; KRAS = gene name; MSI = microsatellite instability; N = number; NA = not applicable; OS = overall survival; RR = risk of recurrence; Rx = treatment.

## Implications for Clinical and Policy Decisionmaking

Our review demonstrated that the weight of published research to date in the area of molecular pathology tests for improving estimates of cancer prognosis has focused on the clinical validity of the tests of interest in giving information about prognosis and little emphasis on how these tests can be integrated into the overall care of cancer patients in terms of measuring changes in management decisions or the effect of those altered decisions on downstream outcomes of value to patients. Such changes in management may be occurring and may be of benefit, or possibly of harm, to patients but have not been measured and studied, with the notable exception of the Oncotype DX assay in breast cancer, which does have a sizeable body of evidence to suggest an effect on treatment decisions (resulting in fewer recommendations for chemotherapy), though not yet a clear effect on downstream outcomes.

At this point, physicians can, in many cases, rely on the prognostic value of molecular pathology tests, can share test results with patients, and discuss whether the test result indicates a better or worse than average prognosis. However, in most cases, physicians cannot be sure whether they should direct management plans based on the results. Although having accurate information about prognosis may be valued by patients independent of its effects on treatment planning or on survival and recurrence outcomes, this has yet to be demonstrated for the tests of interest.

Policymakers may request information and research that not only demonstrate the prognostic value of a test for cancer recurrence, but also evaluate the broader context of how the test fits into the overall plan of care and how information provided by the test changes a patient’s long-term outcomes. Because molecular pathology tests for risk of cancer recurrence are relatively recent innovations in cancer care, it is reasonable for policymakers to expect that their value may be better demonstrated over the next decade as the research base matures.

## Limitations of the Comparative Effectiveness Review Process

We did not include studies focused on populations with advanced/metastatic cancer. The focus of this report is on whether the included tests are useful for prognosis as related to the risk of cancer recurrence. People with advanced/metastatic cancer would first have to achieve remission before recurrence is a possibility. Studies of people with advanced/metastatic cancer tend to focus on overall survival and typically do not provide information about the risk of cancer recurrence.

Also publication bias and selective reporting are potential limitations. Although we searched for unpublished studies and unpublished outcomes and did not find direct evidence of either of these biases, many of the included studies were published prior to the availability of registries that would allow for greater certainty in determining the potential for either type of bias.

Finally, although the r eview was focused om the Medicare population we did not find evidence specific to thulation. Many studies included participants from this age group and we did not find any evidence suggesting that the prognostic value of the tests varies with age.

## Limitations of the Evidence Base

The evidence base was inadequate to draw conclusions for some of our questions or subquestions of interest. In particular, as described above, we found no direct evidence addressing our overarching question and insufficient evidence to determine whether modified decisions that result from prognostic testing lead to improved health outcomes. Further, we found scant evidence meeting our inclusion criteria regarding ALK translocation testing.

Although we found insufficient evidence to determine whether modified decisions that result from prognostic testing lead to improved health outcomes, studies of the use of Oncotype DX Breast reveal a pattern of less aggressive treatment recommendations as a result of using test information to inform decision-making (i.e., more recommendations for patients to have hormonal therapy alone than hormonal plus chemotherapy). We would expect this to improve quality of life and to decrease the costs of treatment, but we did not find empiric evidence to confirm this, and it might only hold true if recurrence and survival were either unchanged or were improved.

Many of the included studies had methodological limitations introducing some RoB. For example, most of them were observational studies assessing associations between test results and outcomes and are susceptible to potential confounding. To limit such bias, we only included studies for KQ 3 that adjusted for most or all standard prognostic factors. Also, we assessed potential selection bias and confounding in our RoB assessments—limiting our main data syntheses to studies with low or medium RoB.

We were also not able to address the prognostic value of the tests for the Medicare population due to a lack of data that was specific to that age group.

## Future Research

We found no direct evidence of the impact of the information provided by these tests on downstream health outcomes such as patients’ quality of life or survival. Thus, future research should focus on quality of life, survival, and other health outcomes. There is no information on the differential effects of the test by race or cancer subtype (e.g., ductal versus lobular in breast cancer) or location (e.g., proximal versus distal in CRC). As described in the results, the subpopulations that were represented in the studies varied in terms of stage, tumor type, and location in the case of CRC. Race and location have both been shown to be important predictors of the prognostic value of genetic markers in CRC.152,153 Similar differences in prognostic value by subpopulations could be a factor in terms of EGFR and KRAS in the lung. There is thus a need to create an evidence base that replicates results in the same subpopulations, particularly in CRC and lung cancer.

As in many studies in the oncology field, the published literature uses a variety of specific definitions for outcomes such as recurrence and CSS, making comparison of effects across studies more difficult. Future research should take into account careful selection of the most appropriate endpoints, both in the context of the existing body of literature and the endpoints of most clinical relevance to doctors and patients.

Research on the prognostic value of molecular pathology tests, whether existing or novel, is limited by the lack of availability of biologic samples or detailed molecular pathology test result information from large population-based cohorts making assessment and generalizability of genetic prognostic tests difficult. Because many published studies used subsets of the same clinical trial populations, there is overlap in the sample of patients studied (e.g., three of the studies included for Oncotype DX in breast cancer report on the same 668 patients). There is a need to expand the research into independent populations and to incorporate collection of molecular pathology test results and/or biologic samples into the design of registry and prospective cohort studies. Although concerns may arise regarding privacy issues, these may be allayed by understanding that genetic alterations in the carcinomas, rather than those in germline DNA, are the focus of the research, and well-established ethical guidelines exist for handling and storing patient biospecimens.

## Conclusions

We found modest evidence supporting added prognostic value (i.e., clinical validity), beyond traditional prognostic factors, for MammaPrint, Oncotype DX Breast, KRAS mutation testing for lung, BRAF mutation testing for CRC, KRAS mutation testing for CRC, and MSI for CRC for RR, CSS, and/or OS. For UroVysion, which is marketed as a diagnostic (not prognostic) test, limited evidence supported an association between test result and prognosis for RR. For the other included tests, evidence either did not support added prognostic value or we found no studies with sufficiently low RoB to support a conclusion about prognostic value.

We found no studies that directly addressed our overarching question (i.e., no studies directly assessed the impact of test use on downstream health outcomes to establish clinical utility). We attempted to construct an indirect chain of evidence to answer the overarching question, but evidence was generally insufficient to do so. Even for the tests with good evidence supporting clinical validity, we found no evidence that using the test was related to improved outcomes for patients.

For impact of test use on treatment decisions, we found moderate SOE that Oncotype DX Breast leads to changes in decisions. One study of low or medium RoB found a significant impact of MammaPrint on treatment decisions, but evidence was insufficient to draw any firm conclusions, primarily because of unknown consistency and imprecision.

Many of the included tests are currently used to predict response to specific treatments, an aspect that was not evaluated in this report. A determination of whether the tests have clinical utility for predicting therapeutic response is beyond the scope of this review.