# Background and Objectives

## Burden of Cancer in the Medicare Population

Cancer is a leading cause of death in the United States. More than 1.6 million new cases of cancer are expected to be diagnosed in the United States in 2012.^1^ Because rates of cancer incidence increase with age, almost half of these new cases will occur in the Medicare beneficiary population. As illustrated in Figure 1, adults ages 65 or older carry a disproportionate burden of new cancer diagnoses for the five most common solid tumor cancer types. For newly diagnosed Medicare beneficiaries with cancer and their care providers, estimating the prognosis of their cancer is a key step in understanding their diagnosis and forming a treatment plan. As our understanding of cancer has evolved to include the DNA mutational diversity and mRNA expression differences in the neoplastic clones, molecular pathology tests are playing an increasingly important role in determining cancer prognosis. This review aims to clarify the value of certain molecular pathology tests in determining prognosis for common cancers (breast, lung, colon, bladder) affecting Medicare beneficiaries.

Figure 1 Incidence of five most common solid tumor cancer types

Source: Data drawn from National Cancer Institute, Surveillance, Epidemiology, and End Results (SEER) Program, http://seer.cancer.gov/.1 This figure represents an estimate of new cancer cases in the 65 or older population for the year 2012 based on overall incidence estimates for 2012 and historical distribution of new cases by age between 2005 and 2009 provided in the SEER Cancer Statistics Review.

Figure 1 is titled, "Incidence of five most common solid tumor cancer types." It is a bar graph depicting the estimate of new cancer cases in the 65 or older population for the year 2012 based on overall incidence estimates for 2012 and historical distribution of new cases by age between 2005 and 2009 provided in the SEER Cancer Statistics Review. The approximate number of cases per year for all ages for each cancer type is as follows: breast cancer: 225,000; lung cancer: 225,000; prostate cancer: 240,000; colon cancer: 140,000; bladder cancer: 60,000. In each category the approximate proportion of cases among those age 65 or older is shown in the figure as follows: breast cancer: 40 percent; lung cancer: 70 percent; prostate cancer: 58 percent; colon cancer: 64 percent; bladder cancer: 75 percent.

### What Is a Prognostic Test?

Prognosis is “a forecasting of the probable course and termination of an illness.”2 A prognostic test is used to predict a patient’s probability of developing a disease or experiencing a medical event.3 Determining prognosis is one of the most important steps for a newly diagnosed cancer patient and his or her health care providers. For people with cancer, a prognostic test is used to provide estimates for the likelihood of recurrence after curative-intent treatment, death from cancer, or death due to any cause after a diagnosis of cancer. In cancer research studies, these estimates are frequently referred to as recurrence-free survival, cancer-specific survival, and overall survival. Recurrence of the cancer, cancer-specific deaths, and all-cause death are outcomes of great interest for the physician and patient as well as for researchers.

Prognostic estimates are important to cancer patients for several reasons. First, the patients and caregivers are naturally interested in finding out what to expect after the cancer is diagnosed and treated, for emotional and psychological reasons as well as for planning purposes. Second, prognostic information is often used to assist in treatment decisions, and to weigh the potential harms of treatment against the risk of disease recurrence. For example, if a patient were told that his cancer has a 10 percent chance of recurrence after initial surgical treatment, he might decide not to undergo additional chemotherapy with the potential for significant harms, whereas a patient given a 60 percent chance of recurrence might be more likely to decide to have chemotherapy. Pieces of information that distinguish patients who have different likelihoods of specific cancer outcomes are often referred to as prognostic factors.

### Standard Prognostic Factors in Solid Tumor Cancer

The stage of a patient’s cancer is one of the most powerful factors used to assess a patient’s prognosis. The TNM staging system is based on the local extent of invasion by the tumor (T), whether cancer cells have spread to nearby (regional) lymph nodes (N), and whether distant (to other parts of the body) metastasis (M) has occurred.4,5

In addition, the grade of the tumor; other pathologic features; and other patient characteristics such as age, sex, and race are all factors that can affect prognosis depending on the primary site of the cancer. Table 1 lists the most widely accepted and validated prognostic factors for the cancer types of interest for this review.

### Molecular Pathology Tests and Cancer Prognosis

As the science of cancer pathology has evolved over the past several decades, scientists have increasingly appreciated that there is biological diversity within cancers occurring in the same anatomic location and that patients with anatomically similar cancers may, in fact, have a variety of outcomes driven by molecular subtypes. The search for biomarkers to identify patients with better or worse prognoses within similar stage cancers began with the identification of distinct histologic cell types (e.g., squamous cell versus adenocarcinoma as two kinds of nonsmall cell lung cancer). These distinctions have been enriched by immunohistochemical assays, which can identify altered expression of cellular proteins. Such markers may or may not be associated with differences in prognosis. A key example includes the expression of the human epidermal growth factor 2 (HER2) receptor in breast cancer in which HER overexpression is associated with poor prognosis6, but also serves as a predictor of response to anti-HER2 therapy. Such biomarkers have become a part of routine clinical care, and help clinicians offer more personalized prognoses and therapies to patients.

Table 1 Key standard prognostic factors in nonmetastatic solid tumors

Cancer Type | Prognostic Factor | Relationship
Colorectal | - Depth of invasion of bowel wall^a^; - Invasion of adjacent structures^a^; - Lymph node involvement^a^; - Grade; - Special cellular subtypes (e.g., mucinous, signet ring); - Lymphovascular invasion; - Elevated carcinoembryonic antigen (CEA) level; - Location (rectum vs. colon); - Sex; - Age | Compton et al., 2000^7^ Sun et al., 2009^8^
Breast | - Tumor size^a^; - Tumor grade; - Lymph node involvement^a^; - Hormone (estrogen and progesterone) receptor status; - HER2 receptor status; - Inflammatory disease^a^; - Age; - Special cellular subtypes (e.g., mucinous, tubular) | Fitzgibbons et al., 2000^9^ Rakha et al., 2008^10^
Lung | - Tumor size^a^; - Invasion of adjacent tissues^a^; - Spread to more than one lobe^a^; - Lymph node involvement^a^; - Cell type; - Performance status; - Weight loss; - Sex | Groome et al., 2007^11^ Sculier et al., 2008^12^
Bladder | - Depth of invasion of bladder wall^a^; - Invasion of adjacent structures^a^; - Lymph node involvement^a^; - Lymphatic or vascular invasion | International Bladder Cancer Nomogram Consortium et al., 2006^13^ Shariat et al., 2006^14^

a Factor included in American Joint Committee on Cancer staging criteria.

Abbreviations: CEA = carcinoembryonic antigen; HER2 = Human Epidermal Growth Factor Receptor 2, also known as Neu..

The search for better markers to estimate prognosis has been further enhanced with the advances in our understanding of the human genome. Genetic diversity between tumors of the same cancer type may or may not be associated with differences in prognosis. In some cases, tests for DNA mutations, DNA translocations, or mRNA expression differences (hereafter referred to as “molecular pathology tests”) may offer a more accurate estimate of prognosis as an alternative or complement to traditional prognostic factors. To the extent that the results of a molecular pathology test add distinct information about a patient’s likelihood of a certain outcome, such as recurrence, they can be valuable in patient education and decisionmaking.

Although molecular pathology tests are potentially valuable new tools, all such tests for common cancers are not created equal. Molecular pathology tests may vary in the extent to which they have been validated in groups of patients for whom long-term outcome data are available, and in the extent to which the patient population used in validation represents the average patient with the cancer of interest. Molecular pathology tests may also vary in their performance characteristics, including reproducibility, sensitivity and specificity, and lower limit of detection. In addition, some molecular pathology tests may change prognostic estimates by large increments when used in addition to traditional predictors, whereas others refine prognostic estimates only slightly or not at all. All of these characteristics influence the degree to which a molecular pathology test is useful in clinical oncology practice.

### How Is Prognosis Estimated?

Researchers developing prognostic models generally start with information about patient and cancer characteristics for a group of patients whose cancer outcomes (such as survival or cancer recurrence) are already known. These data are used to figure out mathematical relationships between the potential prognostic factors and the outcome of interest. Researchers must consider which outcome they wish to predict, identify the population for which they wish to make an estimate, and consider all the potential prognostic factors to include in their model based on prior literature and clinical observation.15 Multivariable prognostic models are statistical tools that enable physicians and patients to estimate prognosis based on a combination of clinical and laboratory factors. For most cancers, the following outcomes are of greatest interest: all-cause survival (measured as time from diagnosis to death due to any cause), disease-specific survival (time from diagnosis to death due to cancer), and recurrence (time from initial surgical resection and treatment to recurrence). Thus, the mathematical models that estimate prognosis will assess the ability of the prognostic markers to predict one of these three outcomes. After comparing potential models to determine which one works best, the model’s performance should be tested by using statistical methods and applying the model to different groups of patients to see if it performs as well as it did in the initial patient group. In many cases, these models can be simplified into nomograms or risk calculators that can be used in the office setting to estimate prognosis for individual patients. The usefulness of these tools depends on the validity of the predictive model that underlies them.

All prognostic estimates contain an element of uncertainty. A physician seeing a new patient may have an educated guess as to how the patient’s cancer course will proceed based on the physician’s experience. Although this guess may often be correct, there is still a significant degree of uncertainty. Similarly, a statistical model that estimates the likelihood of recurrence in a group of patients has some degree of uncertainty. By incorporating as many strong prognostic factors into the estimate as possible, we can reduce this uncertainty. As new candidate prognostic factors are discovered, they can be tested in combination with the known prognostic factors to investigate whether the new combination provides more accurate estimates of prognosis than the old combination (i.e., the known prognostic factors).

In evaluating prognostic tests, researchers consider prognostic accuracy, defined as the extent to which the test is able to predict which individuals have a higher or lower likelihood of getting the outcome (discrimination) and the extent to which the probability of a certain outcome in the population predicted by the test matches the actual probability (calibration).16 In a disease with multiple prognostic factors, it is important to know whether a prognostic estimate incorporating a molecular pathology test of interest has improved calibration and discrimination compared with a model using only previously known prognostic factors such as those in Table 1. Further, it may be even more informative to assess net reclassification17–19 (i.e., how much more frequently appropriate reclassification occurs than inappropriate reclassification when using a new model [incorporating a molecular pathology test] than with a model only using previously known prognostic factors). Unfortunately, not all newly discovered molecular pathology prognostic tests are evaluated in this manner. Thus, when a novel prognostic marker is reported in the scientific literature, physicians and patients may not know whether to place more value in estimates of prognosis based on older information, or on estimates based on the novel marker.

This review evaluates the value of 11 tests that are potentially useful for assessing prognosis for patients with colorectal (CRC), breast, lung, or bladder cancers. The outcome of interest in this review is recurrence of the cancer after the initial resection and treatment.

In a preliminary literature search and discussion with clinical experts for this systematic review, no commercially available molecular prognostic tests were identified for prostate cancer; therefore, prostate cancer is excluded from further consideration for this review. The molecular pathology tests of interest for the remaining four most common solid tumors among Medicare beneficiaries (Table 2) were selected based on preliminary literature searches, consultation with clinical experts, and consultation with the funding agency.

Table 2 Descriptions of genomic tests evaluated in this report

Cancer Type | Vendor | Vendor Test, Kit, or LDT | FDA- Approved | Sample Requirements | Type of Analyte | Panel Size | Neoplasms to be Tested | Results Reported from Which Lab?
Colorectal ACa
MSI | Promega | Kit | No | Ca and NL FFPE tissue | DNA | 5 micro-satellites | Colorectal ACa | MGP
MLH-1 PHM | Qiagen | Kit (Pyro seq) | No | FFPE tissue | DNA | 1 locus | Colorectal ACa | MGP
BRAF mutation | (1) Qiagen (2) Roche | (1) Kit (Pyro seq) (2) Quant PCR | (1) No (2) Yes | FFPE tissue | DNA | 1 locus | Colorectal ACa | MGP
KRAS mutation | Qiagen | Kit (Pyro seq) | No | FFPE tissue | DNA | 1 locus | Colorectal ACa | MGP
Oncotype DX | Genomic Health | Vendor IVDMIA | No | FFPE tissue | mRNA | 12 loci | Stg II CRC ACa | Vendor
Breast Ca
Oncotype DX | Genomic Health | Vendor IVDMIA | No | FFPE tissue | mRNA | 21 loci | ER+ LN− BrCa | Vendor
MammaPrint | Agendia | Vendor IVDMIA | Yes | Frozen or FFPE tissue | mRNA | 70 loci | <5 cm LN− BrCa | Vendor
Lung Ca, NSCLC
ALK transloc’n | Vysis | Kit | Yes | FFPE tissue | DNA (inter-phase chromosomes) | 1 locus | NSCLC | Cytogenetics
EGFR mutation | (1) Illumina (2) Ion Torrent (3) Qiagen (4) Integrated Onc/Lab Corp (5) Roche | (1) TruSeq Amplicon Cancer Panel (2) Ion AmpliSeq Cancer Panel (3) Kit (Pyro seq) Quant PCR (4) Ref lab Sanger sequencing (5) Cobas Real-time PCR | No No No Yes No | FFPE tissue FFPE tissue FFPE tissue FFPE tissue FFPE tissue | DNA DNA DNA DNA DNA | 1 locus 1 locus 1 locus 1 locus 1 locus | NSCLC NSCLC NSCLC NSCLC NSCLC | (1) MGP (2) MGP (3) MGP (4) Vendor (5) MGP
KRAS mutation | Qiagen | Kit (Pyro seq) | No | FFPE tissue | DNA | 1 locus | NSCLC | MGP
Bladder (Urothelial) Ca
UroVysion | Vysis | Kit | Yes | Alcohol-fixed | Cells | DNA (4 inter-phase chromosomes) | Urothelial | Vendor

Abbreviations: ACa = adenocarcinoma; ALK = gene name; BRAF = gene name; Ca = cancer; BrCa = breast cancer; CRC = colorectal cancer; DNA = deoxyribonucleic acid; DX = diagnosis; EGFR = gene name; ER+ = estrogen receptor positive; FDA = Food and Drug Administration; FFPE = formalin-fixed paraffin-embedded tissue; IVDMIA = in vitro diagnostic multivariate index assays; KRAS = gene name; LDT = lab-developed test; LN- = lymph node; MGP = molecular genetic pathology; MLH-1 PHM = MLH-1 gene name promoter hypermethylation; mRNA = messenger ribonucleic acid; MSI = microsatellite instability; NL = normal; NSCLC = nonsmall cell lung carcinoma; PCR = polymerase chain reaction; seq = sequence; Stg = stage.

### Scope and Objectives of the Review

These genetic tests are used in two different contexts. In one, the tests are used in a specific context of a diagnostic/therapy combination, where the diagnostic test is being used to predict response to a very specific treatment. In the second context, the genetic tests are used to estimate the patient’s prognosis, and physicians use this prognostic information to choose from a variety of different treatment options. CMS requested this report to evaluate the second context. Therefore, studies that evaluate specific diagnostic/therapy combinations are excluded from this reporte thus did not include studies that were assessing tests for that purpose.The main purpose of this review is to determine whether the tests improve estimation of prognosis (for recurrence); affect physician decision-making; and thereby improve outcomes for patients with colorectal, breast, lung, or bladder cancer compared with traditional assessment of prognosis of recurrence. This technology assessment will use the analytic framework illustrated in Figure 2 and the associated Key Questions (KQs) to systematically review the evidence on 11 molecular pathology tests. In this review, we address the KQs listed below.

Figure 2 Analytic framework

Abbreviation: KQ = Key Question.

Figure 2 is titled, "Analytic framework." The framework starts on the left with a square indicating the population of interest: Adults with colorectal, breast, lung, or urinary bladder tumors. A straight line with an arrow labeled KQ 2 extends to the right pointing to a box with rounded corners labeled "Genetic marker." Moving straight across to the right, another line with an arrow labeled KQ 3 points to a box with rounded corners labeled "Predicted risk of recurrence/prognosis." Next is a line with an arrow labeled KQ 4a pointing to a box with rounded corners labeled "Treatment decisions." From here, another line with an arrow is labeled KQ 4b and it points to a square that lists health outcomes: recurrence, survival, and quality of life. Extending down for the line labeled KQ 4b is a curved line labeled KQ 5 pointing to a circle representing harms of treatment decisions. On the top of the figure, a line extends from the KQ 2 arrow on the left to the Health Outcomes box on the far right. This line represents the overarching question, KQ 1.

The following tests are under consideration for this assessment and apply to all KQs: microsatellite instability for CRC, MLH1 promoter methylation for CRC, KRAS mutation testing for CRC, BRAF mutation testing for CRC, Oncotype DX Colon for CRC, Oncotype DX Breast for breast cancer, MammaPrint for breast cancer, ALK translocations for non-small cell lung carcinoma (NSCLC), EGFR for NSCLC, KRAS for NSCLC, and UroVysion for urinary bladder cancer.

KQ 1. Overarching Question: Is there direct evidence that the addition of the specified molecular pathology tests used alone or in combination with traditional prognostic factors changes physician decisionmaking and improves outcomes for adult patients with CRC, breast, lung, or bladder cancer compared with the use of traditional factors to predict risk of recurrence (RR) for adults with these cancers?

KQ 2. Analytic Validity Does existing evidence establish the technical accuracy and reliability of these tests for detecting the relevant molecular analytes?

KQ 3. Clinical Validity Does existing evidence establish the prognostic accuracy of the tests for predicting recurrence?

KQ 4. Clinical Utility Does existing evidence support clinical utility of the molecular pathology tests?

KQ 4a. What is the evidence that the prognostic information provided by the molecular pathology tests modifies physician decisions regarding use of adjuvant antineoplastic chemo- and/or radiotherapy, enhanced diagnostic testing for recurrence, and/or surgery among adult patients with malignant tumors?

KQ 4b. What is the evidence that modified decisions lead to improved outcomes, including patient-centered outcomes such as improved quality of life, reduced disease recurrence, increased overall survival (OS) or disease-free survival (DFS), or reduced therapeutic side effects?

KQ 5. What are the harms associated with treatment decisions that are informed by the molecular pathology tests?