# Strength of Evidence (SOE)

Table D-1 EGFR for lung carcinoma

Outcome | Study Design: No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Other | Result/ Effect Size (CI) | Strength of Evidence
Risk of Recurrence | Cohort: 6 (1,870) | Medium | Indirect | Consistent | Imprecise | None | 0.87(0.65,1.15) No Association^a^ | Low
Cancer-specific mortality | None | NA | NA | NA | NA | NA | NA | NA
Overall survival | Cohort: 6 (1,820) | Medium | Indirect | Consistent | Imprecise | NA | 0.77(0.5, 1.19) No Association^b^ | Insufficient
Decisions about treatment
Analytic Validity | 5;898 | Low | Direct | Consistent | Precise | | | High
Sensitivity and specificity | 5;898 | Low | Direct | Consistent | Precise | | | High
Positive and negative predictive value | 5;898 | Low | Direct | Consistent | Precise | | | High
Cross-lab validity | 5;636 | Low | Direct | Consistent | Precise | CAP Report Data | | High

a Two studies did not report a hazard ratio for risk of recurrence, therefore 4 studies (N=936) contributed data to the meta-analysis.

b Two studies did not report a hazard ratio for overall survival, therefore 4 studies (N=834) contributed data to the meta-analysis.

Abbreviations: CI = confidence interval; N = number.

Table D-2 KRAS for lung carcinoma

Outcome | Study Design: No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Other | Result/ Effect Size (CI) | Strength of Evidence
Risk of Recurrence | Cohort: 4 (N=611) | Medium | Indirect | Inconsistent | Imprecise | None | 2.84(1.14, 7.1)^a^ KRAS mutation associated with greater RR | Insufficient
Cancer-specific mortality | None | NA | NA | NA | NA | NA | NA | NA
Overall survival | Cohort: 2 (N=253) | Medium | Indirect | Unknown (single study) | Unknown (single study) | None | OR, 2.69(1.91,3.80)); 3.33 ( 1.03, 10.82) mutation associated with lower OS | Insufficient
Decisions about treatment | 0/0 | NA | NA | NA | NA | NA | NA | NA
Analytic Validity | 2;188 | Low | Direct | Consistent | Precise | | | Moderate
Sensitivity and specificity | 1;114 | Low | Direct | Consistency Unknown (Single Study) | Precise | | | Low
Positive and negative predictive value | 1;114 | Low | Direct | Consistency Unknown (Single Study) | Precise | | | Low
Cross-lab validity | 4;686 | Low | Direct | Consistent | Precise | CAP Report Data | | High

a Three studies representing 4 cohorts (N=611) contributed to the meta-analysis.

Abbreviations: CI = confidence interval; N = number.

Table D-3 Microsatellite instability for colorectal carcinoma

Outcome | Study Design: No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Other | Result/ Effect Size (CI) | Strength of Evidence
Risk of Recurrence | Cohort studies: 10 (7,130) | Medium | Indirect | Inconsistent | Imprecise | NA | MSI-H vs. MSS: HR, 0.60 (0.50 to 0.72) for the association between MSI status and recurrence | Insufficient
Cancer-specific mortality | Cohort studies: 6 (3,439) | Medium | Indirect | Inconsistent | Imprecise | NA | MSI-H vs. MSS: HR, 0.65 (0.51 to 0.82)^a^ for the association between MSI status and cancer-specific mortality | Insufficient
Overall survival | Cohort studies: 12 (8,839) | Medium | Indirect | Inconsistent | Imprecise | NA | MSI-H vs. MSS: HR, 0.57 (0.43 to 0.77)^b^ for the association between MSI status and OS; | Insufficient
Decisions about treatment | 0 (0) | NA | NA | NA | NA | NA | NA | Insufficient
Analytic Validity | NA | NA | NA | NA | NA | | NA | NA
Sensitivity and specificity | NA | NA | NA | NA | NA | | NA | NA
Positive and negative predictive value | NA | NA | NA | NA | NA | | NA | NA
Cross-lab validity | 3;291 | NA | Indirect | Consistent | Precise | CAP Report Data | NA | High

a Five studies (N = 3252) contributed data to the meta-analysis.

b Eleven studies (N = 8626) contributed to the meta-analysis)

Abbreviations: CI = confidence interval; N = number; NA = not applicable.

Table D-4 KRAS for colorectal carcinoma

Outcome | Study Design: No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Other | Result/ Effect Size (CI) | Strength of Evidence
Risk of Recurrence | Cohort studies: 5 (4,085) | Medium | Indirect | Consistent | Precise | NA | Wild type vs. mutated: HR, 1.02 (0.91 to 1.14); no association found in adjusted analyses; | Low
Cancer-specific mortality | 2 (1,747) | Medium | Indirect | Inconsistent | Imprecise | NA | Wild type vs. mutated: HR, 1.30 (1.02 to 1.66) KRAS mutation for the association between KRAS mutation and CSS | Insufficient
Overall survival | Cohort studies: 10 (5,328) | Medium | Indirect | Inconsistent | Imprecise | NA | Wild type vs. mutated: HR, 1.22 (0.95 to 1.55); | Low
Decisions about treatment | 0 (0) | NA | NA | NA | NA | NA | NA | Insufficient
Analytic Validity | 5;576 | Low | Direct | Consistent | Precise | | NA | High
Sensitivity and specificity | 5;576 | Low | Direct | Consistent | Precise | | NA | High
Positive and negative predictive value | 5;576 | Low | Direct | Consistent | Precise | | NA | High
Cross-lab validity | 5;747 | Low | Direct | Consistent | Precise | CAP Report Data | NA | High

Abbreviations: CI = confidence interval; N = number; NA = not applicable.

Table D-5 BRAF for colorectal carcinoma

Outcome | Study Design: No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Other | Result/ Effect Size (CI) | Strength of Evidence
Risk of Recurrence | Cohort studies: 5 (4,106) | Medium | Indirect | Inconsistent | Imprecise | NA | Wild type vs. mutation: HR, 1.07 (0.76 to 1.52); | Low
Cancer-specific mortality | Cohort studies: 7 (5,409) | Medium | Indirect | Consistent (all trend for association of mutation with worse outcome) | CND | NA | Wild type vs. mutation: HR, 1.5 (1.27 to 1.77) for the association between mutation and cancer-specific mortality | Insufficient
Overall survival | Cohort studies: 11 (7,610) | Medium | Indirect | Consistent | CND | NA | Wild type vs. mutation: HR 1.45 (1.29 to 1.62),) for the association between mutation and survival | Insufficient
Decisions about treatment | 0 (0) | NA | NA | NA | NA | NA | NA | Insufficient
Analytic Validity | 1;117 | Medium | Direct | Consistency Unknown (Single Study) | Imprecise | | | Low
Sensitivity and specificity | 1;117 | Medium | Direct | Consistency Unknown (Single Study) | Imprecise | | | Low
Positive and negative predictive value | 1;117 | Medium | Direct | Consistency Unknown (Single Study) | Imprecise | | | Low
Cross-lab validity | 3;533 | NA | Direct | Consistent | Precise | CAP Report Data | NA | High

Abbreviations: CI = confidence interval; N = number; NA = not applicable.

Table D-6 Oncotype Dx colon multi-gene assay for colorectal carcinoma

Outcome | Study Design: No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Other | Result/ Effect Size (CI) | Strength of Evidence
Risk of Recurrence | Cohort: 1 (690) | Medium | Indirect | Unknown | Imprecise | NA | HR, 1.68 (1.18 to 2.38) | Insufficient
Cancer-specific mortality | 0 (0) | NA | NA | NA | NA | NA | NA | Insufficient
Overall survival | 0 (0) | NA | NA | NA | NA | NA | NA | Insufficient
Decisions about treatment | 0 (0)^a^ | NA | NA | NA | NA | NA | NA | Insufficient
Analytic Validity | 1;NR | Medium | Indirect | Consistency Unknown (Single Study) | Precise | | NA | Low
Sensitivity and specificity | NA | NA | NA | NA | NA | | NA | NA
Positive and negative predictive value | NA | NA | NA | NA | NA | | NA | NA
Cross-lab validity | NA | NA | NA | NA | NA | | NA | NA

a We identified no low or medium risk of bias studies. But we found three studies rated as high1 or unclear2 risk of bias that evaluated decisions of a total of 221 physicians (502 patients)

Abbreviations: CI = confidence interval; N = number; NA = not applicable.

Table D-7 Oncotype Dx breast multi-gene assay for breast carcinoma

Outcome | Study Design: No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Other | Result/ Effect Size (CI) | Strength of Evidence
Risk of Recurrence | Cohort: 6 (N=3,222) Case-control: 1 (N=40) | Medium | Indirect | Consistent | Precise | None | 2.97 (2.19,4.02)^a^ High Risk vs. Low Risk | Insufficient
Cancer-specific mortality | Cohort: 1 (N=668) Case-control: 1 (N=566) | Low | Indirect | Consistent | Imprecise | None | 2.02 (1.35, 3.00) High Risk vs. Low Risk | Low
Overall survival | Cohort: 1 (N=668) | Low | Indirect | Unknown | Unknown | None | HR, 1.77 (1.35, 2.33) High Risk vs. Low Risk | Insufficient
Decisions about treatment | Cohort: 6 (N=990) Uncontrolled trial: 10 (N=1,261) | Low | Indirect | Consistent | Precise | None | ~30% of tx decisions changed by test | Moderate
Analytic Validity | NA | NA | NA | NA | NA | | NA | NA
Sensitivity and specificity | NA | NA | NA | NA | NA | | NA | NA
Positive and negative predictive value | NA | NA | NA | NA | NA | | NA | NA
Cross-lab validity | NA | NA | NA | NA | NA | | NA | NA

a Four studies (N = 2327) contributed data to the meta-analysis.

Abbreviations: CI = confidence interval; N = number; NA = not applicable; tx = treatment.

Table D-8 Mammaprint multi-gene assay for breast carcinoma

Outcome | Study Design: No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Other | Result/ Effect Size (CI) | Strength of Evidence
Risk of Recurrence | Cohort: 6 (N=1,913) | Medium | Indirect | Consistent | Imprecise | None | 2.84 (2.11,3.82) For poor prognosis vs. good prognosis | Insufficient
Cancer-specific mortality | Cohort: 5 (N=1615) | Medium | Indirect | Consistent | Imprecise | None | 3.3 (2.22, 4.9) for poor prognosis vs. good prognosis | Insufficient
Overall survival | Cohort: 1 (N = 144) | Medium | Indirect | Unknown (single study) | Unknown (single study) | None | HR, 1.67 (0.73, 3.82) for poor prognosis vs. poor prognosis | Insufficient
Decisions about treatment | Cohort: 1 (N=427) | Low | Indirect | Unknown (single study) | Unknown (single study) | None | NA | Insufficient
Analytic Validity | 2;399 | Medium | Indirect | Consistent | Imprecise | | NA | Moderate
Sensitivity and specificity | 2;399 | Medium | Indirect | Consistent | Imprecise | | NA | Moderate
Positive and negative predictive value | 2;399 | Medium | Indirect | Consistent | Imprecise | | NA | Moderate
Cross-lab validity | 1; 100 | Low | Indirect | Consistent | Imprecise | | NA | Low

Abbreviations: BRCA = breast cancer; CI = confidence interval; N = number; NA = not applicable.

Table D-9 Urovysion multi-gene assay for urinary bladder carcinoma

Outcome | Study Design: No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Other | Result/ Effect Size (CI) | Strength of Evidence
Risk of Recurrence | Cohort study: 2 (168) | Low | Indirect | Consistent | Imprecise | Actual adjusted data NR in the larger (N=126) study, just qualitative description | Association between mutation and risk of recurrence in 2 small studies;^a^ no evidence that test use leads to improved outcomes | Insufficient
Cancer-specific mortality | 0 (0) | NA | NA | NA | NA | NA | NA | Insufficient
Overall survival | 0 (0) | NA | NA | NA | NA | NA | NA | Insufficient
Decisions about treatment | 0 (0) | NA | NA | NA | NA | NA | NA | Insufficient
Analytic Validity | NA | NA | NA | NA | NA | | NA | NA
Sensitivity and specificity | NA | NA | NA | NA | NA | | NA | NA
Positive and negative predictive value | NA | NA | NA | NA | NA | | NA | NA
Cross-lab validity | 4;555 | NA | Indirect | Consistent | Precise | CAP Report Data | NA | High

a One study (N=126) only reported unadjusted data, and reported that the association between FISH results and tumor recurrence “persisted after accounting for other disease factors (stage, grade, history of prior tumors, concomitant CIS, use of post-operative mitomycin, etc.) at all time points.”

Abbreviations: CI = confidence interval; N = number; NA = not applicable.

## References

1 Cartwright T, Chao C, Lee M, et al. Effect of the 12-gene colon cancer assay results on adjuvant treatment recommendations in patients with stage II colon cancer. Curr Med Res Opin. 2013. Nov. 7. [pmid: 24127781].
2 Srivastava G, Renfro LA, Behrens RJ, et al. Prospective evaluation of a 12-gene assay on treatment recommendations in patients with stage II colon cancer. ASCO Gastrointestinal Symposium. 2013. January. San Francisco, CA.