# Exclusions

Exclusion Code Key:

- EXC1: Systematic Review
- EXC2: Wrong publication type
- EXC3: Wrong population
- EXC4: Wrong intervention
- EXC5: Wrong or no comparator
- EXC6: Wrong or no outcome
- EXC7: Wrong study design
- EXC8: Does not apply to a key question
- EXC9: Irretrievable

1 Bladder cancer surveillance (Structured abstract). Health Technology Assessment Database. 2007;(3). EXC1.
2 Epidermal growth factor receptor mutations and tyrosine kinase inhibitor therapy in advanced non-small-cell lung cancer (Structured abstract). Health Technology Assessment Database. 2007;(3). EXC2.
3 CYP2D6 pharmacogenomics of tamoxifen treatment (Structured abstract). Health Technology Assessment Database. 2008;(3). EXC2.
4 Oncotype DX prognostic and predictive test for early breast cancer (Structured abstract). Health Technology Assessment Database. 2008;(3). EXC2.
5 KRAS mutations and epidermal growth factor receptor inhibitor therapy in metastatic colorectal cancer (Structured abstract). Health Technology Assessment Database. 2008;(3). EXC2.
6 MammaPrint (gene test) for breast cancer - prognostic test: horizon scanning technology briefing (Project record). Health Technology Assessment Database. 2009;(3). EXC2.
7 Gene expression profiling in women with lymph-node-positive breast cancer to select adjuvant chemotherapy treatment (Structured abstract). Health Technology Assessment Database. 2010;(3). EXC2.
8 KRAS testing for anti-EGFR therapy in advanced colorectal cancer: an evidence-based and economic analysis (Provisional abstract). Database of Abstracts of Reviews of Effects. 2010;(3):1. EXC2.
9 Epidermal growth factor receptor mutation (EGFR) testing for prediction of response to EGFR-targeting tyrosine kinase inhibitor (TKI) drugs in patients with advanced non-small-cell lung cancer: an evidence-based analysis (Provisional abstract). Database of Abstracts of Reviews of Effects. 2010;(3):1. EXC1.
10 Aaltonen L, Johns L, Jarvinen H, et al. Explaining the familial colorectal cancer risk associated with mismatch repair (MMR)-deficient and MMR-stable tumors. Clin Cancer Res. Jan. 1. 2007;13(1):356-361. EXC3. [pmid: 17200375].
11 Abbott, et al. Diagnosis and Management of Bladder Cancer Testing Technology to Identify New and Recurrent Bladder Cancer Evidence to support UroVysion Bladder Cancer Kit. 2013. EXC2.
12 Abbott Molecular. UroVysion Bladder Cancer Kit, Package Insert. 30-608385/R4. 2012. EXC6.
13 Abd El Kader Y, Emera G, Safwat E, et al. The KRAS StripAssay for detection of KRAS mutation in Egyptian patients with colorectal cancer (CRC): a pilot study. J Egypt Natl Canc Inst. Mar. 2013;25(1):37-41. EXC5. [pmid: 23499205].
14 Abdel Salam I, Gaballa HE, Abdel Wahab N. Serum levels of epidermal growth factor and HER-2 neu in non small-cell lung cancer: prognostic correlation. Med Oncol. 2009;26(2):161-166. EXC4. [pmid: 19093231].
15 Abe Y, Masuda H, Okubo R. Microsatellite instability of each tumor in sporadic synchronous multiple colorectal cancers. Oncol Rep. Mar-Apr. 2001;8(2):299-304. EXC4. [pmid: 11182044].
16 Abedi-Ardekani B, Dar NA, Mir MM, et al. Epidermal growth factor receptor (EGFR) mutations and expression in squamous cell carcinoma of the esophagus in central Asia. BMC Cancer. 2012;12(602). MEDLINE PMID 23244191 (http://www.ncbi.nlm.nih.gov/pubmed/23244191) FULL TEXT LINK http://dx.doi.org/10.1186/1471-2407-2412-2602. EXC3.
17 Abubaker J, Bavi P, Al-Haqawi W, et al. Prognostic significance of alterations in KRAS isoforms KRAS-4A/4B and KRAS mutations in colorectal carcinoma. J Pathol. Dec. 2009;219(4):435-445. EXC5. [pmid: 19824059].
18 Ach RA, Floore A, Curry B, et al. Robust interlaboratory reproducibility of a gene expression signature measurement consistent with the needs of a new generation of diagnostic tools. BMC Genomics. 2007;8:148. EXC5. [pmid: 17553173].
19 Achille A, Biasi MO, Zamboni G, et al. Cancers of the papilla of vater: mutator phenotype is associated with good prognosis. Clin Cancer Res. Oct. 1997;3(10):1841-1847. EXC4. [pmid: 9815572].
20 Acs G, Esposito NN, Kiluk J, et al. A mitotically active, cellular tumor stroma and/or inflammatory cells associated with tumor cells may contribute to intermediate or high Oncotype DX Recurrence Scores in low-grade invasive breast carcinomas. Mod Pathol. Apr. 2012;25(4):556-566. EXC5. [pmid: 22173289].
21 Addison CL, Ding K, Zhao H, et al. Plasma transforming growth factor alpha and amphiregulin protein levels in NCIC Clinical Trials Group BR.21. J Clin Oncol. Dec. 20. 2010;28(36):5247-5256. EXC7. [pmid: 21079146].
22 Ademuyiwa FO, Thorat MA, Jain RK, et al. Expression of Forkhead-box protein A1, a marker of luminal A type breast cancer, parallels low Oncotype DX 21-gene recurrence scores. Mod Pathol. Feb. 2010;23(2):270-275. EXC6. [pmid: 19946260].
23 Agostini M, Enzo MV, Morandi L, et al. A ten markers panel provides a more accurate and complete microsatellite instability analysis in mismatch repair-deficient colorectal tumors. Cancer Biomarkers. 2009;6(1):49-61. EXC4. [pmid: 20164541].
24 Ahlquist DA, Zou H, Domanico M, et al. Next-generation stool DNA test accurately detects colorectal cancer and large adenomas. Gastroenterology. Feb. 2012;142(2):248-256. quiz e25-6. EXC5. [pmid: 22062357].
25 Ahn HK, Choi YL, Han JH, et al. Epidermal growth factor receptor mutation and treatment outcome of mediastinoscopic N2 positive non-small cell lung cancer patients treated with neoadjuvant chemoradiotherapy followed by surgery. Lung Cancer. Mar. 2013;79(3):300-306. EXC3. [pmid: 23261144].
26 Ahn JB, Chung WB, Maeda O, et al. DNA methylation predicts recurrence from resected stage III proximal colon cancer. Cancer. May. 1. 2011;117(9):1847-1854. EXC6. [pmid: 21509761].
27 Ahn JH, Kim SW, Hong SM, et al. Epidermal growth factor receptor (EGFR) expression in operable non-small cell lung carcinoma. J Korean Med Sci. Aug. 2004;19(4):529-535. EXC4. [pmid: 15308843].
28 Ahn MJ, Park BB, Ahn JS, et al. Are there any ethnic differences in molecular predictors of erlotinib efficacy in advanced non-small cell lung cancer?. Clin Cancer Res. Jun. 15. 2008;14(12):3860-3866. EXC3. [pmid: 18559606].
29 Akashi-Tanaka S, Shimizu C, Ando M, et al. 21-Gene expression profile assay on core needle biopsies predicts responses to neoadjuvant endocrine therapy in breast cancer patients. Breast. Jun. 2009;18(3):171-174. EXC5. [pmid: 19410462].
30 Akca H, Demiray A, Yaren A, et al. Utility of serum DNA and pyrosequencing for the detection of EGFR mutations in non-small cell lung cancer. Cancer Genet. Mar. 2013;206(3):73-80. EXC6. [pmid: 23491080].
31 Al Zobair AA, Al Obeidy BF, Yang L, et al. Concomitant overexpression of EGFR and CXCR4 is associated with worse prognosis in a new molecular subtype of non-small cell lung cancer. Oncol Rep. Apr. 2013;29(4):1524-1532. EXC4. [pmid: 23443279].
32 Albain K, Barlow W, Shak S, et al. Prognostic and predictive value of the 21-gene recurrence score assay in postmenopausal, node-positive, ER-positive breast cancer (S8814, INT0100). Breast Cancer Res Treat. Jun. 2008;109(3):585. Exc6.
33 Albain KS, Barlow WE, Shak S, et al. Prognostic and predictive value of the 21-gene recurrence score assay in postmenopausal women with node-positive, oestrogen-receptor-positive breast cancer on chemotherapy: a retrospective analysis of a randomised trial. Lancet Oncol. Jan. 2010;11(1):55-65. EXC4. [pmid: 20005174].
34 Alberts SR, Sargent DJ, Nair S, et al. Effect of oxaliplatin, fluorouracil, and leucovorin with or without cetuximab on survival among patients with resected stage III colon cancer: a randomized trial. JAMA. Apr. 4. 2012;307(13):1383-1393. EXC6. [pmid: 22474202].
35 Alemayehu A, Tomkova K, Zavodna K, et al. The role of clinical criteria, genetic and epigenetic alterations in Lynch-syndrome diagnosis. Neoplasma. 2007;54(5):391-401. EXC6. [pmid: 17688369].
36 Algars A, Lintunen M, Carpen O, et al. EGFR gene copy number assessment from areas with highest EGFR expression predicts response to anti-EGFR therapy in colorectal cancer. Br J Cancer. Jul. 12. 2011;105(2):255-262. EXC3. [pmid: 21694725].
37 Alldinger I, Schaefer KL, Goedde D, et al. Microsatellite instability in Ewing tumor is not associated with loss of mismatch repair protein expression. J Cancer Res Clin Oncol. 2007;133(10):749-759. EXC3. [pmid: 17530287].
38 Allegrini S, Antona J, Mezzapelle R, et al. Epidermal growth factor receptor gene analysis with a highly sensitive molecular assay in routine cytologic specimens of lung adenocarcinoma. Am J Clin Pathol. Sep. 2012;138(3):377-381. EXC3. [pmid: 22912354].
39 Allison KH, Kandalaft PL, Sitlani CM, et al. Routine pathologic parameters can predict Oncotype DX recurrence scores in subsets of ER positive patients: who does not always need testing?. Breast Cancer Res Treat. Jan. 2012;131(2):413-424. EXC6. [pmid: 21369717].
40 Aloulou N, Bastuji-Garin S, Le Gouvello S, et al. Involvement of the leptin receptor in the immune response in intestinal cancer. Cancer Res. 2008;68(22):9413-9422. EXC4. [pmid: 19010916].
41 Al-Saad S, Al-Shibli K, Donnem T, et al. Clinical significance of epidermal growth factor receptors in non-small cell lung cancer and a prognostic role for HER2 gene copy number in female patients. J Thorac Oncol. Oct. 2010;5(10):1536-1543. EXC4. [pmid: 20802349].
42 Altomare DF, Guanti G, Hoch J, et al. Noncolonic cancer stem cells in bone marrow of colorectal cancer patients. Colorectal Dis. Mar. 2010;12(3):206-212. EXC5. [pmid: 19183332].
43 Alvarez K, Hurtado C, Hevia MA, et al. Spectrum of MLH1 and MSH2 mutations in Chilean families with suspected Lynch syndrome. Dis Colon Rectum. Apr. 2010;53(4):450-459. EXC6. [pmid: 20305446].
44 Amado RG, Wolf M, Peeters M, et al. Wild-type KRAS is required for panitumumab efficacy in patients with metastatic colorectal cancer. J Clin Oncol. 2008;(10):1626-1634. EXC7. [pmid: 18316791].
45 Amann JM, Lee JW, Roder H, et al. Genetic and proteomic features associated with survival after treatment with erlotinib in first-line therapy of non-small cell lung cancer in Eastern Cooperative Oncology Group 3503. J Thorac Oncol. Feb. 2010;5(2):169-178. EXC5. [pmid: 20035238].
46 Ambrosini-Spaltro A, Campanini N, Bortesi B, et al. EGFR mutation-specific antibodies in pulmonary adenocarcinoma: a comparison with DNA direct sequencing. Appl Immunohistochem Mol Morphol. Jul. 2012;20(4):356-362. EXC4. [pmid: 22710815].
47 American Cancer Society. Cancer Facts & Figures 2011. Atlanta, GA. 2011. www.cancer.org/acs/groups/content/@epidemiologysurveilance/documents/document/acspc-029771.pdf EXC8.
48 American Joint Committee on Cancer. Cancer Staging Manual. 7th ed. New York. Springer. 2010. EXC2.
49 Amira N, Rivet J, Soliman H, et al. Microsatellite instability in urothelial carcinoma of the upper urinary tract. J Urol. 2003;170(4I):1151-1154. EXC6. [pmid: 14501713].
50 An CH, Kim SS, Kang MR, et al. Frameshift mutations of ATBF1, WNT9A, CYLD and PARK2 in gastric and colorectal carcinomas with high microsatellite instability. Pathology (Phila). 2010;42(6):583-585. EXC4. [pmid: 20854080].
51 Andersen CL, Lamy P, Thorsen K, et al. Frequent genomic loss at chr16p13.2 is associated with poor prognosis in colorectal cancer. Int J Cancer. 2011;129(8):1848-1858. EXC4. [pmid: 21154748].
52 Anderson JC, Rangasamy P, Rustagi T, et al. Risk factors for sessile serrated adenomas. J Clin Gastroenterol. Sep. 2011;45(8):694-699. EXC3. [pmid: 21325950].
53 Andreason M, Zhang C, Onitilo AA, et al. Rural versus urban differences among patients (pts) with hormone-receptor positive (HR+) breast cancer (BC) and a 21-gene assay recurrence score (RS). ASCO. 2012. EXC6.
54 Angulo B, Garcia-Garcia E, Martinez R, et al. A commercial real-time PCR kit provides greater sensitivity than direct sequencing to detect KRAS mutations: a morphology-based approach in colorectal carcinoma. J Mol Diagn. May. 2010;12(3):292-299. EXC3. [pmid: 20203003].
55 Ann MJ, Park BB, Ann JS, et al. Are there any ethnic differences in molecular predictors of erlotinib efficacy in advanced non-small cell lung cancer?. Clin Cancer Res. 2008;14(12):3860-3866. EXC3. [pmid: 18559606].
56 Ansen S, Bangard C, Querings S, et al. Osteoblastic response in patients with non-small cell lung cancer with activating EGFR mutations and bone metastases during treatment with EGFR kinase inhibitors. J Thorac Oncol. 2010;5(3):407-409. EXC7. [pmid: 20186030].
57 Antelo M, Balaguer F, Shia J, et al. A High Degree of LINE-1 Hypomethylation Is a Unique Feature of Early-Onset Colorectal Cancer. PLoS One. 2012;7(9). EXC4.
58 Aoyagi H, Iida S, Uetake H, et al. Effect of classification based on combination of mutation and methylation in colorectal cancer prognosis. Oncol Rep. Mar. 2011;25(3):789-794. EXC6. [pmid: 21174064].
59 Aparicio T, Schischmanoff O, Poupardin C, et al. Deficient mismatch repair phenotype is a prognostic factor for colorectal cancer in elderly patients. Dig Liver Dis. Mar. 2013;45(3):245-250. EXC7. [pmid: 23102497].
60 Arain MA, Sawhney M, Sheikh S, et al. CIMP status of interval colon cancers: another piece to the puzzle. Am J Gastroenterol. May. 2010;105(5):1189-1195. EXC4. [pmid: 20010923].
61 Araki K, Hashimoto K, Ardyanto TD, et al. Co-expression of Cox-2 and EGFR in stage I human bronchial adenocarcinomas. Lung Cancer. Aug. 2004;45(2):161-169. EXC4. [pmid: 15246187].
62 Arcila ME, Oxnard GR, Nafa K, et al. Rebiopsy of lung cancer patients with acquired resistance to EGFR inhibitors and enhanced detection of the T790M mutation using a locked nucleic acid-based assay. Clin Cancer Res. Mar. 1. 2011;17(5):1169-1180. EXC4. [pmid: 21248300].
63 Ardavanis A, Koumna S, Fragos I, et al. Erlotinib monotherapy in patients with advanced non-small cell lung cancer: an effective approach with low toxicity. Anticancer Res. Jul-Aug. 2008;28(4C):2409-2415. EXC4. [pmid: 18751427].
64 Argiris A, Hensing T, Yeldandi A, et al. Combined analysis of molecular and clinical predictors of gefitinib activity in advanced non-small cell lung cancer: epidermal growth factor receptor mutations do not tell the whole story. J Thorac Oncol. Jan. 2006;1(1):52-60. EXC6. [pmid: 17409827].
65 Arnold CN, Nagasaka T, Goel A, et al. Molecular characteristics and predictors of survival in patients with malignant neuroendocrine tumors. Int J Cancer. Oct. 1. 2008;123(7):1556-1564. EXC5. [pmid: 18646189].
66 Arrieta O, Campos-Parra AD, Zuloaga C, et al. Clinical and pathological characteristics, outcome and mutational profiles regarding non-small-cell lung cancer related to wood-smoke exposure. J Thorac Oncol. 2012;7(8):1228-1234. EXC6. [pmid: 22659961].
67 Arrieta O, Saavedra-Perez D, Kuri R, et al. Brain metastasis development and poor survival associated with carcinoembryonic antigen (CEA) level in advanced non-small cell lung cancer: a prospective analysis. BMC Cancer. 2009;9:119. EXC4. [pmid: 19386089].
68 Artac M, Pehlivan S, Akcan S, et al. The role of microsatellite instability to predict clinical benefit from irinotecan-based regimens in metastatic colorectal cancer. Turkish Journal of Cancer. 2008;38(2):49-56. EXC3.
69 Artale S, Sartore-Bianchi A, Veronese SM, et al. Mutations of KRAS and BRAF in primary and matched metastatic sites of colorectal cancer. J Clin Oncol. Sep. 1. 2008;26(25):4217-4219. EXC2. [pmid: 18757341].
70 Artinyan A, Essani R, Lake J, et al. Molecular predictors of lymph node metastasis in colon cancer: increased risk with decreased thymidylate synthase expression. J Gastrointest Surg. Dec. 2005;9(9):1216-1221. discussion 21. EXC5. [pmid: 16332476].
71 Asad J, Jacobson AF, Estabrook A, et al. Does oncotype DX recurrence score affect the management of patients with early-stage breast cancer?. Am J Surg. Oct. 2008;196(4):527-529. EXC5. [pmid: 18809056].
72 Ashktorab H, Brim H, Al-Riyami M, et al. Sporadic colon cancer: mismatch repair immunohistochemistry and microsatellite instability in Omani subjects. Dig Dis Sci. Oct. 2008;53(10):2723-2731. EXC4. [pmid: 18299982].
73 Ashktorab H, Smoot DT, Carethers JM, et al. High incidence of microsatellite instability in colorectal cancer from African Americans. Clin Cancer Res. Mar. 2003;9(3):1112-1117. EXC6. [pmid: 12631615].
74 Asseburg C, Frank M, Kohne CH, et al. Cost-effectiveness of targeted therapy with cetuximab in patients with K-ras wild-type colorectal cancer presenting with initially unresectable metastases limited to the liver in a German setting (Structured abstract). Clin Ther. 2011;(4):482-497. EXC7. [pmid: 21635994].
75 Au HJ, Karapetis CS, O'Callaghan CJ, et al. Health-related quality of life in patients with advanced colorectal cancer treated with cetuximab: overall and KRAS-specific results of the NCIC CTG and AGITG CO. 17 Trial. J Clin Oncol. Apr. 10. 2009;27(11):1822-1828. EXC3. [pmid: 19273701].
76 Azzoni C, Bottarelli L, Cecchini S, et al. Sporadic colorectal carcinomas with low-level microsatellite instability: A distinct subgroup with specific clinicopathological and molecular features. Int J Colorectal Dis. 2011;26(4):445-453. EXC4. [pmid: 21336644].
77 Baba T, Shiota H, Kuroda K, et al. Cancer/testis antigen expression as a predictor for epidermal growth factor receptor mutation and prognosis in lung adenocarcinoma. Eur J Cardiothorac Surg. Apr. 2013;43(4):759-764. EXC7. [pmid: 22826471].
78 Baba Y, Huttenhower C, Nosho K, et al. Epigenomic diversity of colorectal cancer indicated by LINE-1 methylation in a database of 869 tumors. Molecular Cancer. 2010;9. EXC4.
79 Baba Y, Nosho K, Shima K, et al. Relationship of CDX2 loss with molecular features and prognosis in colorectal cancer. Clin Cancer Res. Jul. 15. 2009;15(14):4665-4673. EXC6. [pmid: 19584150].
80 Baba Y, Nosho K, Shima K, et al. PTGER2 overexpression in colorectal cancer is associated with microsatellite instability, independent of CpG island methylator phenotype. Cancer Epidemiology Biomarkers and Prevention. 2010;19(3):822-831. EXC4.
81 Baba Y, Nosho K, Shima K, et al. Phosphorylated AKT expression is associated with PIK3CA mutation, low stage, and favorable outcome in 717 colorectal cancers. Cancer. Apr. 1. 2011;117(7):1399-1408. EXC6. [pmid: 21425139].
82 Baba Y, Nosho K, Shima K, et al. Hypomethylation of the IGF2 DMR in colorectal tumors, detected by bisulfite pyrosequencing, is associated with poor prognosis. Gastroenterology. Dec. 2010;139(6):1855-1864. EXC4. [pmid: 20682317].
83 Baba Y, Nosho K, Shima K, et al. HIF1A overexpression is associated with poor prognosis in a cohort of 731 colorectal cancers. Am J Pathol. May. 2010;176(5):2292-2301. EXC4. [pmid: 20363910].
84 Badalian G, Barbai T, Raso E, et al. Phenotype of bone metastases of non-small cell lung cancer: epidermal growth factor receptor expression and K-RAS mutational status. Pathol Oncol Res. 2007;13(2):99-104. EXC4. [pmid: 17607370].
85 Bae JM, Cho NY, Kim TY, et al. Clinicopathologic and molecular characteristics of synchronous colorectal cancers: heterogeneity of clinical outcome depending on microsatellite instability status of individual tumors. Dis Colon Rectum. Feb. 2012;55(2):181-190. EXC6. [pmid: 22228162].
86 Bae JM, Kim MJ, Kim JH, et al. Differential clinicopathological features in microsatellite instability-positive colorectal cancers depending on CIMP status. Virchows Arch. Jul. 2011;459(1):55-63. EXC7. [pmid: 21494758].
87 Bae NC, Chae MH, Lee MH, et al. EGFR, ERBB2, and KRAS mutations in Korean non-small cell lung cancer patients. Cancer Genet Cytogenet. Mar. 2007;173(2):107-113. EXC6. [pmid: 17321325].
88 Baehner FL, Achacoso N, Maddala T, et al. Human epidermal growth factor receptor 2 assessment in a case-control study: comparison of fluorescence in situ hybridization and quantitative reverse transcription polymerase chain reaction performed by central laboratories. J Clin Oncol. Oct. 1. 2010;28(28):4300-4306. EXC7. [pmid: 20697093].
89 Baehner FL, Yoshizawa CN, Butler SM, et al. The Development of the DCIS Score: Scaling and Normalization in the Marin Medical Laboratories Cohort: Marin Medical Laboratories. 2012. EXC7.
90 Bago-Horvath Z, Sieghart W, Grusch M, et al. Synergistic effects of erlotinib and everolimus on bronchial carcinoids and large-cell neuroendocrine carcinomas with activated EGFR/AKT/mTOR pathway. Neuroendocrinology. 2012;96(3):228-237. EXC4. [pmid: 22378048].
91 Bai H, Mao L, Wang HS, et al. Epidermal growth factor receptor mutations in plasma DNA samples predict tumor response in Chinese patients with stages IIIB to IV non-small-cell lung cancer. J Clin Oncol. Jun. 1. 2009;27(16):2653-2659. EXC5. [pmid: 19414683].
92 Bai H, Wang Z, Wang Y, et al. Detection and clinical significance of intratumoral EGFR mutational heterogeneity in Chinese patients with advanced non-small cell lung cancer. PLoS One. 2013;8(2):e54170. EXC3. [pmid: 23418425].
93 Balleste B, Bessa X, Pinol V, et al. Detection of metachronous neoplasms in colorectal cancer patients: identification of risk factors. Dis Colon Rectum. Jul. 2007;50(7):971-980. EXC6. [pmid: 17468913].
94 Bando H, Yoshino T, Tsuchihara K, et al. KRAS mutations detected by the amplification refractory mutation system-Scorpion assays strongly correlate with therapeutic effect of cetuximab. Br J Cancer. Jul. 26. 2011;105(3):403-406. EXC6. [pmid: 21730978].
95 Banerjea A, Feakins RM, Nickols CD, et al. Immunogenic hsp-70 is overexpressed in colorectal cancers with high-degree microsatellite instability. Dis Colon Rectum. Dec. 2005;48(12):2322-2328. EXC6. [pmid: 16258706].
96 Banerjea A, Hands RE, Powar MP, et al. Microsatellite and chromosomal stable colorectal cancers demonstrate poor immunogenicity and early disease recurrence. Colorectal Dis. Jul. 2009;11(6):601-608. EXC5. [pmid: 18637931].
97 Barault L, Charon-Barra C, Jooste V, et al. Hypermethylator phenotype in sporadic colon cancer: study on a population-based series of 582 cases. Cancer Res. Oct. 15. 2008;68(20):8541-8546. EXC6. [pmid: 18922929].
98 Barault L, Veyrie N, Jooste V, et al. Mutations in the RAS-MAPK, PI(3)K (phosphatidylinositol-3-OH kinase) signaling network correlate with poor survival in a population-based series of colon cancers. Int J Cancer. May. 15. 2008;122(10):2255-2259. EXC6. [pmid: 18224685].
99 Barratt PL, Seymour MT, Stenning SP, et al. DNA markers predicting benefit from adjuvant fluorouracil in patients with colon cancer: a molecular study. Lancet. Nov. 2. 2002;360(9343):1381-1391. EXC4. [pmid: 12423985].
100 Bartley AN, Luthra R, Saraiya DS, et al. Identification of cancer patients with Lynch syndrome: clinically significant discordances and problems in tissue-based mismatch repair testing. Cancer Prev Res (Phila). Feb. 2012;5(2):320-327. EXC3. [pmid: 22086678].
101 Bast RC Jr, Hortobagyi GN. Individualized care for patients with cancer - a work in progress. N Engl J Med. Dec. 30. 2004;351(27):2865-2867. EXC2. [pmid: 15591336].
102 Becouarn Y, Rullier A, Gorry P, et al. Value of microsatellite instability typing in detecting hereditary non-polyposis colorectal cancer. A prospective multicentric study by the Association Aquitaine Gastro. Gastroenterol Clin Biol. Jun-Jul. 2005;29(6-7):667-675. EXC6. [pmid: 16142001].
103 Bedwell C, Rowe D, Moulton D, et al. Cytogenetically complex SEC31A-ALK fusions are recurrent in ALK-positive large B-cell lymphomas. Haematologica. Feb. 2011;96(2):343-346. EXC3. [pmid: 21109691].
104 Bell DW, Lynch TJ, Haserlat SM, et al. Epidermal growth factor receptor mutations and gene amplification in non-small-cell lung cancer: molecular analysis of the IDEAL/INTACT gefitinib trials. J Clin Oncol. Nov. 1. 2005;23(31):8081-8092. EXC3. [pmid: 16204011].
105 Belt EJ, Fijneman RJ, van den Berg EG, et al. Loss of lamin A/C expression in stage II and III colon cancer is associated with disease recurrence. Eur J Cancer. Aug. 2011;47(12):1837-1845. EXC7. [pmid: 21621406].
106 Belt EJ, te Velde EA, Krijgsman O, et al. High lymph node yield is related to microsatellite instability in colon cancer. Ann Surg Oncol. Apr. 2012;19(4):1222-1230. EXC7. [pmid: 21989661].
107 Benatti P, Gafa R, Barana D, et al. Microsatellite instability and colorectal cancer prognosis. Clin Cancer Res. 2005;11(23):8332-8340. EXC4. [pmid: 16322293].
108 Benes C. Discovery of candidate biomarkers of anticancer drug sensitivity by high-throughput cell line screening. Molecul Cancer Therapeut. 2011;10(11). EXC2.
109 Benmoussa A, Badre W, Pedroni M, et al. Clinical and molecular characterization of colorectal cancer in young Moroccan patients. Turk J Gastroenterol. 2012. 2012;23(6):686-690. FULL TEXT LINK http://dx.doi.org/10.4318/tjg.2012.0474. EXC3.
110 Bennett L, Zhao Z, Barber B, et al. Health-related quality of life in patients with metastatic colorectal cancer treated with panitumumab in first- or second-line treatment. Br J Cancer. Nov. 8. 2011;105(10):1495-1502. EXC6. [pmid: 21989186].
111 Bentivegna A, Conconi D, Panzeri E, et al. Biological heterogeneity of putative bladder cancer stem-like cell populations from human bladder transitional cell carcinoma samples. Cancer Sci. Feb. 2010;101(2):416-424. EXC4. [pmid: 19961489].
112 Berardi R, Santinelli A, Brunelli A, et al. Epidermal growth factor receptor status in stages of resected non-small cell lung cancer: implications for treatment with epidermal growth factor receptor inhibitors. Anal Quant Cytol Histol. Aug. 2011;33(4):196-204. EXC4. [pmid: 21980623].
113 Berg M, Danielsen SA, Ahlquist T, et al. DNA sequence profiles of the colorectal cancer critical gene set KRAS-BRAF-PIK3CA-PTEN-TP53 related to age at disease onset. PLoS One. 2010;5(11):e13978. EXC5. [pmid: 21103049].
114 Berghmans T, Mascaux C, Haller A, et al. EGFR, TTF-1 and Mdm2 expression in stage III non-small cell lung cancer: a positive association. Lung Cancer. Oct. 2008;62(1):35-44. EXC4. [pmid: 18355939].
115 Bergman J, Reznichek RC, Rajfer J. Surveillance of patients with bladder carcinoma using fluorescent in-situ hybridization on bladder washings. BJU Int. Jan. 2008;101(1):26-29. EXC6. [pmid: 17850364].
116 Berney CR, Fisher RJ, Yang J, et al. Genomic alterations (LOH, MI) on chromosome 17q21-23 and prognosis of sporadic colorectal cancer. Int J Cancer. Jan. 20. 2000;89(1):1-7. EXC4. [pmid: 10719723].
117 Berney CR, Fisher RJ, Yang JL, et al. Genomic alterations (LOH, MI) on chromosome 17q21-23 and prognosis of sporadic colorectal cancer. Int J Cancer. 2000;89(1):1-7. EXC6. [pmid: 10719723].
118 Bertagnolli MM, Niedzwiecki D, Compton CC, et al. Microsatellite instability predicts improved response to adjuvant therapy with irinotecan, fluorouracil, and leucovorin in stage III colon cancer: Cancer and Leukemia Group B Protocol 89803. J Clin Oncol. Apr. 10. 2009;27(11):1814-1821. EXC6. [pmid: 19273709].
119 Bertagnolli MM, Redston M, Compton CC, et al. Microsatellite instability and loss of heterozygosity at chromosomal location 18q: prospective evaluation of biomarkers for stages II and III colon cancer--a study of CALGB 9581 and 89803. J Clin Oncol. 2011;(23):3153-3162. EXC4. [pmid: 21747089].
120 Bertagnolli MM, Warren RS, Niedzwiecki D, et al. p27Kip1 in stage III colon cancer: implications for outcome following adjuvant chemotherapy in cancer and leukemia group B protocol 89803. Clin Cancer Res. Mar. 15. 2009;15(6):2116-2122. EXC5. [pmid: 19276255].
121 Bettstetter M, Dechant S, Ruemmele P, et al. Distinction of hereditary nonpolyposis colorectal cancer and sporadic microsatellite-unstable colorectal cancer through quantification of MLH1 methylation by real-time PCR. Clin Cancer Res. Jun. 1. 2007;13(11):3221-3228. EXC6. [pmid: 17545526].
122 Bettstetter M, Dechant S, Ruemmele P, et al. MethyQESD, a robust and fast method for quantitative methylation analyses in HNPCC diagnostics using formalin-fixed and paraffin-embedded tissue samples. Lab Invest. 2008;88(12):1367-1375. EXC3. [pmid: 18936738].
123 Betz BL, Roh MH, Weigelin HC, et al. The application of molecular diagnostic studies interrogating EGFR and KRAS mutations to stained cytologic smears of lung carcinoma. Am J Clin Pathol. 2011;136(4):564-571. EXC6. [pmid: 21917678].
124 Bianchini G, Zantheni M, Mariani P, et al. Recurrence score by oncotype DX evaluated on the primary breast tumor predicts the 2-year survival after first relapse. Breast Cancer Res Treat. Dec. suppl 1. 2007;106:S55-S. EXC2.
125 Bibeau F, Lopez-Crapez E, Di Fiore F, et al. Impact of Fc{gamma}RIIa-Fc{gamma}RIIIa polymorphisms and KRAS mutations on the clinical outcome of patients with metastatic colorectal cancer treated with cetuximab plus irinotecan. J Clin Oncol. Mar. 1. 2009;27(7):1122-1129. EXC3. [pmid: 19164213].
126 Bighin C, Del Mastro L, Canavese G, et al. Use in current clinical practice of 70-gene signature in early breast cancer. Int J Cancer. 2010;127(11):2736-2737. EXC2. [pmid: 20162670].
127 Billah S, Stewart J, Staerkel G, et al. EGFR and KRAS mutations in lung carcinoma: molecular testing by using cytology specimens. Cancer Cytopathol. Apr. 25. 2011;119(2):111-117. EXC5. [pmid: 21400670].
128 Bleeker WA, Hayes VM, Karrenbeld A, et al. Impact of KRAS and TP53 mutations on survival in patients with left- and right-sided Dukes' C colon cancer. Am J Gastroenterol. Oct. 2000;95(10):2953-2957. EXC5. [pmid: 11051374].
129 Blohmer JU, Rezai M, Kummel S, et al. Using the 21-gene assay to guide adjuvant chemotherapy decision-making in early-stage breast cancer: a cost-effectiveness evaluation in the German setting. J Med Econ. 2013;16(1):30-40. EXC 7. [pmid: 22966753].
130 Blons H, Cote JF, Le Corre D, et al. Epidermal growth factor receptor mutation in lung cancer are linked to bronchioloalveolar differentiation. Am J Surg Pathol. 2006;30(10):1309-1315. EXC6. [pmid: 17001163].
131 Boissiere-Michot F, Lopez-Crapez E, Frugier H, et al. KRAS genotyping in rectal adenocarcinoma specimens with low tumor cellularity after neoadjuvant treatment. Mod Pathol. May. 2012;25(5):731-739. EXC3. [pmid: 22282307].
132 Bokemeyer C, Bondarenko I, Hartmann JT, et al. Efficacy according to biomarker status of cetuximab plus FOLFOX-4 as first-line treatment for metastatic colorectal cancer: the OPUS study. Ann Oncol. Jul. 2011;22(7):1535-1546. EXC6. [pmid: 21228335].
133 Bokemeyer C, Bondarenko I, Makhson A, et al. Fluorouracil, leucovorin, and oxaliplatin with and without cetuximab in the first-line treatment of metastatic colorectal cancer. J Clin Oncol. 2009;27(5):663-671. EXC7. [pmid: 19114683].
134 Bokemeyer C, Cutsem EV, Rougier P, et al. Addition of cetuximab to chemotherapy as first-line treatment for KRAS wild-type metastatic colorectal cancer: pooled analysis of the CRYSTAL and OPUS randomised clinical trials. Eur J Cancer. Jul. 2012;48(10):1466-1475. EXC5. [pmid: 22446022].
135 Boland JM, Erdogan S, Vasmatzis G, et al. Anaplastic lymphoma kinase immunoreactivity correlates with ALK gene rearrangement and transcriptional up-regulation in non-small cell lung carcinomas. Hum Pathol. Aug. 2009;40(8):1152-1158. EXC4. [pmid: 19386350].
136 Boldrini L, Ali G, Gisfredi S, et al. Epidermal growth factor receptor and K-RAS mutations in 411 lung adenocarcinoma: a population-based prospective study. Oncol Rep. Oct. 2009;22(4):683-691. EXC6. [pmid: 19724844].
137 Boldrini L, Gisfredi S, Ursino S, et al. Mutational analysis in cytological specimens of advanced lung adenocarcinoma: a sensitive method for molecular diagnosis. J Thorac Oncol. Dec. 2007;2(12):1086-1090. EXC6. [pmid: 18090579].
138 Bollmann D, Bollmann M, Bankfalvi A, et al. Quantitative molecular grading of bladder tumours: a tool for objective assessment of the biological potential of urothelial neoplasias. Oncol Rep. Jan. 2009;21(1):39-47. EXC6. [pmid: 19082441].
139 Bollmann M, Heller H, Bankfalvi A, et al. Quantitative molecular urinary cytology by fluorescence in situ hybridization: a tool for tailoring surveillance of patients with superficial bladder cancer?. BJU Int. Jun. 2005;95(9):1219-1225. EXC7. [pmid: 15892805].
140 Bonanno L, Schiavon M, Nardo G, et al. Prognostic and predictive implications of EGFR mutations, EGFR copy number and KRAS mutations in advanced stage lung adenocarcinoma. Anticancer Res. Dec. 2010;30(12):5121-5128. EXC6. [pmid: 21187500].
141 Bond CE, Umapathy A, Ramsnes I, et al. p53 mutation is common in microsatellite stable, BRAF mutant colorectal cancers. Int J Cancer. Apr. 1. 2012;130(7):1567-1576. EXC6. [pmid: 21557216].
142 Bonis PA, Trikalinos TA, Chung M, et al. Hereditary nonpolyposis colorectal cancer: diagnostic strategies and their implications (Structured abstract). Database of Abstracts of Reviews of Effects. 2007;(3):180. EXC3.
143 Bonnet D, Selves J, Toulas C, et al. Simplified identification of Lynch syndrome: a prospective, multicenter study. Dig Liver Dis. Jun. 2012;44(6):515-522. EXC3. [pmid: 22480969].
144 Genomic comparison of paired primary breast carcinomas and macrometastatic lymph node metastases using quantitative RT-PCR by Oncotype DX: Assessment of the Recurrence Score and quantitative single genes. SABCS. 2011. EXC6.
145 Bosman FT, Yan P, Tejpar S, et al. Tissue biomarker development in a multicentre trial context: a feasibility study on the PETACC3 stage II and III colon cancer adjuvant treatment trial. Clin Cancer Res. 2009;(17):5528-5533. EXC7. [pmid: 19690194].
146 Bossuyt V, Fadare O, Martel M, et al. Remarkably high frequency of EGFR expression in breast carcinomas with squamous differentiation. Int J Surg Pathol. Oct. 2005;13(4):319-327. EXC4. [pmid: 16273187].
147 Bouzourene H, Taminelli L, Chaubert P, et al. A cost-effective algorithm for hereditary nonpolyposis colorectal cancer detection. Am J Clin Pathol. Jun. 2006;125(6):823-831. EXC6. [pmid: 16690480].
148 Evaluation of variables that may impact chemotherapy (CT) administration after determination of Oncotype DX (ODX) recurrence score (RS). ASCO. 2012. EXC6.
149 Bowles DW, Rabinovitch R, Borges V, et al. A young woman with a small ER-positive breast cancer, a micrometastatic axillary lymph node, and an intermediate oncotype DX recurrence score. Oncology (Williston Park). Sep. 2007;21(10):1212-1217. EXC2. [pmid: 17926799].
150 Bozzetti C, Tiseo M, Lagrasta C, et al. Comparison between epidermal growth factor receptor (EGFR) gene expression in primary non-small cell lung cancer (NSCLC) and in fine-needle aspirates from distant metastatic sites. J Thorac Oncol. Jan. 2008;3(1):18-22. EXC6. [pmid: 18166836].
151 Brabender J, Danenberg KD, Metzger R, et al. Epidermal growth factor receptor and HER2-neu mRNA expression in non-small cell lung cancer Is correlated with survival. Clin Cancer Res. Jul. 2001;7(7):1850-1855. EXC4. [pmid: 11448895].
152 Brassett C, Joyce JA, Froggatt NJ, et al. Microsatellite instability in early onset and familial colorectal cancer. J Med Genet. 1996;33(12):981-985. EXC4. [pmid: 9004127].
153 Brattstrom D, Wester K, Bergqvist M, et al. HER-2, EGFR, COX-2 expression status correlated to microvessel density and survival in resected non-small cell lung cancer. Acta Oncol. 2004;43(1):80-86. EXC4. [pmid: 15068324].
154 Brazowski E, Rozen P, Pel S, et al. Can a gastrointestinal pathologist identify microsatellite instability in colorectal cancer with reproducibility and a high degree of specificity?. Familial Cancer. 2012;11(2):249-257. EXC5. [pmid: 22246243].
155 Brenner BM, Swede H, Jones BA, et al. Genomic instability measured by inter-(simple sequence repeat) PCR and high-resolution microsatellite instability are prognostic of colorectal carcinoma survival after surgical resection. Ann Surg Oncol. Jan. 2012;19(1):344-350. EXC4. [pmid: 21487966].
156 Brosens RP, Belt EJ, Haan JC, et al. Deletion of chromosome 4q predicts outcome in stage II colon cancer patients. Cell Oncol (Dordr). Jun. 2011;34(3):215-223. EXC7. [pmid: 21717218].
157 Brotto K, Malisic E, Cavic M, et al. The Usability of Allele-Specific PCR and Reverse-Hybridization Assays for KRAS Genotyping in Serbian Colorectal Cancer Patients. Dig Dis Sci. Apr. 2013;58(4):998-1003. EXC3. [pmid: 23108567].
158 Brueckl WM, Moesch C, Brabletz T, et al. Relationship between microsatellite instability, response and survival in palliative patients with colorectal cancer undergoing first-line chemotherapy. Anticancer Res. Mar-Apr. 2003;23(2C):1773-1777. EXC3. [pmid: 12820457].
159 Brugger W, Triller N, Blasinska-Morawiec M, et al. Prospective molecular marker analyses of EGFR and KRAS from a randomized, placebo-controlled study of erlotinib maintenance therapy in advanced non-small-cell lung cancer. J Clin Oncol. Nov. 1. 2011;29(31):4113-4120. EXC4. [pmid: 21969500].
160 Bruijn MT, Raats DA, Tol J, et al. Combined KRAS and TP53 mutation status is not predictive in CAPOX-treated metastatic colorectal cancer. Anticancer Res. 2011;(4):1379-1385. EXC8. [pmid: 21508389].
161 Bruin SC, He Y, Mikolajewska-Hanclich I, et al. Molecular alterations associated with liver metastases development in colorectal cancer patients. Br J Cancer. Jul. 12. 2011;105(2):281-287. EXC6. [pmid: 21673680].
162 Bruno P, Mariotta S, Ricci A, et al. Reliability of direct sequencing of EGFR: comparison between cytological and histological samples from the same patient. Anticancer Res. Dec. 2011;31(12):4207-4210. EXC6. [pmid: 22199282].
163 Bubendorf L, Grilli B, Sauter G, et al. Multiprobe FISH for enhanced detection of bladder cancer in voided urine specimens and bladder washings. Am J Clin Pathol. Jul. 2001;116(1):79-86. EXC3. [pmid: 11447756].
164 Buckowitz A, Knaebel HP, Benner A, et al. Microsatellite instability in colorectal cancer is associated with local lymphocyte infiltration and low frequency of distant metastases. Br J Cancer. May. 9. 2005;92(9):1746-1753. EXC3. [pmid: 15856045].
165 Burger M, Denzinger S, Hammerschmied CG, et al. Elevated microsatellite alterations at selected tetranucleotides (EMAST) and mismatch repair gene expression in prostate cancer. J Mol Med. 2006;84(10):833-841. EXC3. [pmid: 16924473].
166 Burke E, Baehner F, Yoshizawa C, et al. The 21-gene Breast Cancer Assay: Summary of Clinical Evidence. Redwood City, CA. Genomic Health, Inc. 2013. EXC6.
167 Busby K, Morris A. Detection of BRAF mutations in colorectal tumours and peritoneal washings using a mismatch ligation assay. J Clin Pathol. Apr. 2005;58(4):372-375. EXC4. [pmid: 15790700].
168 Buxhofer-Ausch V, Ausch C, Zeillinger R, et al. Duplex reverse-hybridization assay for the simultaneous detection of KRAS/BRAF mutations in FFPE-extracted genomic DNA from colorectal cancer specimens. Dis Markers. 2013;34(3):171-177. EXC4. [pmid: 23324583].
169 Byrne BJ, Garst J. Epidermal growth factor receptor inhibitors and their role in non-small-cell lung cancer. Curr Oncol Rep. Jul. 2005;7(4):241-247. EXC4. [pmid: 15946581].
170 Cadranel J, Mauguen A, Faller M, et al. Impact of systematic EGFR and KRAS mutation evaluation on progression-free survival and overall survival in patients with advanced non-small-cell lung cancer treated by erlotinib in a French prospective cohort (ERMETIC project-Part 2). J Thorac Oncol. 2012;7(10):1490-1502. EXC3. [pmid: 22982650].
171 Calistri D, Presciuttini S, Buonsanti G, et al. Microsatellite instability in colorectal-cancer patients with suspected genetic predisposition. Int J Cancer. Jan. 20. 2000;89(1):87-91. EXC3. [pmid: 10719736].
172 Calistri D, Rengucci C, Bocchini R, et al. Fecal multiple molecular tests to detect colorectal cancer in stool. Clin Gastroenterol Hepatol. Sep. 2003;1(5):377-383. EXC6. [pmid: 15017656].
173 Camidge DR, Kono SA, Lu X, et al. Anaplastic lymphoma kinase gene rearrangements in non-small cell lung cancer are associated with prolonged progression-free survival on pemetrexed. J Thorac Oncol. Apr. 2011;6(4):774-780. EXC6. [pmid: 21336183].
174 Camidge DR, Theodoro M, Maxson DA, et al. Correlations between the percentage of tumor cells showing an anaplastic lymphoma kinase (ALK) gene rearrangement, ALK signal copy number, and response to crizotinib therapy in ALK fluorescence in situ hybridization-positive nonsmall cell lung cancer. Cancer. Sep. 15. 2012;118(18):4486-4494. EXC5. [pmid: 22282074].
175 Campanella C, Mottolese M, Cianciulli A, et al. Epidermal growth factor receptor gene copy number in 101 advanced colorectal cancer patients treated with chemotherapy plus cetuximab. J Transl Med. 2010;8:36. EXC6. [pmid: 20398370].
176 Camps C, Jantus-Lewintre E, Cabrera A, et al. The identification of KRAS mutations at codon 12 in plasma DNA is not a prognostic factor in advanced non-small cell lung cancer patients. Lung Cancer. Jun. 2011;72(3):365-369. EXC4. [pmid: 21074889].
177 Capper D, Berghoff AS, Magerle M, et al. Immunohistochemical testing of BRAF V600E status in 1,120 tumor tissue samples of patients with brain metastases. Acta Neuropathol (Berl). 2012;123(2):223-233. EXC3. [pmid: 22012135].
178 Capper D, Voigt A, Bozukova G, et al. BRAF V600E-specific immunohistochemistry for the exclusion of Lynch syndrome in MSI-H colorectal cancer. Int J Cancer. Oct. 1. 2013;133(7):1624-1630. EXC6. [pmid: 23553055].
179 Cappuzzo F, Ciuleanu T, Stelmakh L, et al. Erlotinib as maintenance treatment in advanced non-small-cell lung cancer: a multicentre, randomised, placebo-controlled phase 3 study. Lancet Oncol. 2010;(6):521-529. EXC5. [pmid: 20493771].
180 Cappuzzo F, Gregorc V, Rossi E, et al. Gefitinib in pretreated non-small-cell lung cancer (NSCLC): analysis of efficacy and correlation with HER2 and epidermal growth factor receptor expression in locally advanced or metastatic NSCLC. J Clin Oncol. Jul. 15. 2003;21(14):2658-2663. EXC4. [pmid: 12860941].
181 Cappuzzo F, Hirsch FR, Rossi E, et al. Epidermal growth factor receptor gene and protein and gefitinib sensitivity in non-small-cell lung cancer. J Natl Cancer Inst. May. 4. 2005;97(9):643-655. EXC3. [pmid: 15870435].
182 Cappuzzo F, Ligorio C, Janne PA, et al. Prospective study of gefitinib in epidermal growth factor receptor fluorescence in situ hybridization-positive/phospho-Akt-positive or never smoker patients with advanced non-small-cell lung cancer: the ONCOBELL trial. J Clin Oncol. Jun. 1. 2007;25(16):2248-2255. EXC6. [pmid: 17538169].
183 Cappuzzo F, Ligorio C, Toschi L, et al. EGFR and HER2 gene copy number and response to first-line chemotherapy in patients with advanced non-small cell lung cancer (NSCLC). J Thorac Oncol. May. 2007;2(5):423-429. EXC4. [pmid: 17473658].
184 Cappuzzo F, Marchetti A, Skokan M, et al. Increased MET gene copy number negatively affects survival of surgically resected non-small-cell lung cancer patients. J Clin Oncol. Apr. 1. 2009;27(10):1667-1674. EXC4. [pmid: 19255323].
185 Cappuzzo F, Varella-Garcia M, Finocchiaro G, et al. Primary resistance to cetuximab therapy in EGFR FISH-positive colorectal cancer patients. Br J Cancer. Jul. 8. 2008;99(1):83-89. EXC3. [pmid: 18577988].
186 Caraway NP, Khanna A, Fernandez RL, et al. Fluorescence in situ hybridization for detecting urothelial carcinoma: a clinicopathologic study. Cancer Cytopathol. Oct. 25. 2010;118(5):259-268. EXC6. [pmid: 20665656].
187 Cardoso F, Van't Veer L, Rutgers E, et al. Clinical application of the 70-gene profile: the MINDACT trial. J Clin Oncol. Feb. 10. 2008;26(5):729-735. EXC2. [pmid: 18258980].
188 Carethers JM, Smith EJ, Behling CA, et al. Use of 5-fluorouracil and survival in patients with microsatellite-unstable colorectal cancer. Gastroenterology. Feb. 2004;126(2):394-401. EXC3. [pmid: 14762775].
189 Carlson JJ, Garrison LP, Ramsey SD, et al. The potential clinical and economic outcomes of pharmacogenomic approaches to EGFR-tyrosine kinase inhibitor therapy in non-small-cell lung cancer (Structured abstract). Value in Health. 2009;(1):20-27. EXC7. [pmid: 18647257].
190 Carneiro BA, Ramanathan RK, Fakih MG, et al. Phase II study of irinotecan and cetuximab given every 2 weeks as second-line therapy for advanced colorectal cancer. Clin Colorectal Cancer. Mar. 2012;11(1):53-59. EXC3. [pmid: 21813336].
191 Carotenuto P, Roma C, Rachiglio AM, et al. Detection of KRAS mutations in colorectal carcinoma patients with an integrated PCR/sequencing and real-time PCR approach. Pharmacogenomics. Aug. 2010;11(8):1169-1179. EXC3. [pmid: 20712532].
192 Carrillo EF, Arias YR, Perdomo SJ, et al. Oncogene amplification as tumor marker in a group of Colombian lung cancer patients. Colombia Medica. 2009;40(2):148-157. EXC7.
193 Cartwright T, Chao C, Lee M, et al. Effect of the 12-gene colon cancer assay results on adjuvant treatment recommendations in patients with stage II colon cancer. Curr Med Res Opin. 2013. Nov. 7. [pmid: 24127781].
194 Casali C, Rossi G, Marchioni A, et al. A single institution-based retrospective study of surgically treated bronchioloalveolar adenocarcinoma of the lung: clinicopathologic analysis, molecular features, and possible pitfalls in routine practice. J Thorac Oncol. Jun. 2010;5(6):830-836. EXC6. [pmid: 20521350].
195 Castro AS, Parente B, Goncalves I, et al. Epidermal growth factor receptor mutation study for 5 years, in a population of patients with non-small cell lung cancer. Rev Port Pneumol. Jan-Feb. 2013;19(1):7-12. EXC6. [pmid: 23265235].
196 Catalano V, Loupakis F, Graziano F, et al. Mucinous histology predicts for poor response rate and overall survival of patients with colorectal cancer and treated with first-line oxaliplatin- and/or irinotecan-based chemotherapy. Br J Cancer. Mar. 24. 2009;100(6):881-887. EXC4. [pmid: 19259089].
197 Cavallini A, Valentini AM, Lippolis C, et al. KRAS genotyping as biomarker in colorectal cancer: a comparison of three commercial kits on histologic material. Anticancer Res. Dec. 2010;30(12):5251-5256. EXC3. [pmid: 21187522].
198 Cawkwell L, Gray S, Murgatroyd H, et al. Choice of management strategy for colorectal cancer based on a diagnostic immunohistochemical test for defective mismatch repair. Gut. 1999;45(3):409-415. EXC4. [pmid: 10446111].
199 Cawkwell L, Li D, Lewis FA, et al. Microsatellite instability in colorectal cancer: improved assessment using fluorescent polymerase chain reaction. Gastroenterology. Aug. 1995;109(2):465-471. EXC4. [pmid: 7615195].
200 Cejas P, Lopez-Gomez M, Aguayo C, et al. KRAS mutations in primary colorectal cancer tumors and related metastases: a potential role in prediction of lung metastasis. PLoS One. 2009;4(12):e8199. EXC6. [pmid: 20020061].
201 Cejas P, Lopez-Gomez M, Aguayo C, et al. Analysis of the concordance in the EGFR pathway status between primary tumors and related metastases of colorectal cancer patients:implications for cancer therapy. Curr Cancer Drug Targets. Feb. 2012;12(2):124-131. EXC6. [pmid: 22229245].
202 Ceppi P, Volante M, Novello S, et al. ERCC1 and RRM1 gene expressions but not EGFR are predictive of shorter survival in advanced non-small-cell lung cancer treated with cisplatin and gemcitabine. Ann Oncol. Dec. 2006;17(12):1818-1825. EXC6. [pmid: 16980606].
203 Chagpar A, Magliocco A, Kerviche A, et al. The Replication Error Phenotype Is Associated with the Development of Distant Metastases in Hormonally Treated Patients with Breast Carcinoma. Cancer. 2004;100(5):913-919. EXC4. [pmid: 14983485].
204 Chai SM, Zeps N, Shearwood AM, et al. Screening for defective DNA mismatch repair in stage II and III colorectal cancer patients. Clin Gastroenterol Hepatol. Nov. 2004;2(11):1017-1025. EXC4. [pmid: 15551255].
205 Chan JA, Meyerhardt JA, Niedzwiecki D, et al. Association of family history with cancer recurrence and survival among patients with stage III colon cancer. JAMA. Jun. 4. 2008;299(21):2515-2523. EXC4. [pmid: 18523220].
206 Chang EY, Dorsey PB, Frankhouse J, et al. Combination of microsatellite instability and lymphocytic infiltrate as a prognostic indicator in colon cancer. Arch Surg. Jun. 2009;144(6):511-515. EXC4. [pmid: 19528382].
207 Chang EY, Dorsey PB, Johnson N, et al. A prospective analysis of microsatellite instability as a molecular marker in colorectal cancer. Am J Surg. May. 2006;191(5):646-651. EXC4. [pmid: 16647353].
208 Chang JW, Liu HP, Hsieh MH, et al. Increased epidermal growth factor receptor (EGFR) gene copy number is strongly associated with EGFR mutations and adenocarcinoma in non-small cell lung cancers: a chromogenic in situ hybridization study of 182 patients. Lung Cancer. Sep. 2008;61(3):328-339. EXC6. [pmid: 18304690].
209 Chang KL, Lau SK. EGFR mutations in non-small cell lung carcinomas may predict response to gefitinib: extension of an emerging paradigm. Adv Anat Pathol. Mar. 2005;12(2):47-52. EXC4. [pmid: 15731572].
210 Chang MH, Ahn HK, Lee J, et al. Clinical impact of amphiregulin expression in patients with epidermal growth factor receptor (EGFR) wild-type nonsmall cell lung cancer treated with EGFR-tyrosine kinase inhibitors. Cancer. 2011;117(1):143-151. EXC4. [pmid: 20803614].
211 Chang SC, Lin JK, Lin TC, et al. Loss of heterozygosity: an independent prognostic factor of colorectal cancer. World J Gastroenterol. Feb. 14. 2005;11(6):778-784. EXC4. [pmid: 15682467].
212 Chang YS, Yeh KT, Hsu NC, et al. Detection of N-, H-, and KRAS codons 12, 13, and 61 mutations with universal RAS primer multiplex PCR and N-, H-, and KRAS-specific primer extension. Clin Biochem. Feb. 2010;43(3):296-301. EXC6. [pmid: 19879255].
213 Chapusot C, Martin L, Puig PL, et al. What is the best way to assess microsatellite instability status in colorectal cancer? Study on a population base of 462 colorectal cancers. Am J Surg Pathol. Dec. 2004;28(12):1553-1559. EXC4. [pmid: 15577673].
214 Charara M, Edmonston TB, Burkholder S, et al. Microsatellite status and cell cycle associated markers in rectal cancer patients undergoing a combined regimen of 5-FU and CPT-11 chemotherapy and radiotherapy. Anticancer Res. 2004;24(5 B):3161-3167. EXC6. [pmid: 15510606].
215 Chaves P, Cruz C, Lage P, et al. Immunohistochemical detection of mismatch repair gene proteins as a useful tool for the identification of colorectal carcinoma with the mutator phenotype. J Pathol. Aug. 2000;191(4):355-360. EXC4. [pmid: 10918209].
216 Chen HJ, Mok TS, Chen ZH, et al. Clinicopathologic and molecular features of epidermal growth factor receptor T790M mutation and c-MET amplification in tyrosine kinase inhibitor-resistant Chinese non-small cell lung cancer. Pathol Oncol Res. Dec. 2009;15(4):651-658. EXC6. [pmid: 19381876].
217 Chen KY, Chen JH, Shih JY, et al. Octogenarians with advanced non-small cell lung cancer: treatment modalities, survival, and prognostic factors. J Thorac Oncol. Jan. 2010;5(1):82-89. EXC4. [pmid: 19884854].
218 Chen P, Wang L, Liu B, et al. EGFR-targeted therapies combined with chemotherapy for treating advanced non-small-cell lung cancer: a meta-analysis (Structured abstract). Eur J Clin Pharmacol. 2011;(3):235-243. EXC1. [pmid: 21207017].
219 Chen TD, Chang IC, Liu HP, et al. Correlation of anaplastic lymphoma kinase overexpression and the EML4-ALK fusion gene in non-small cell lung cancer by immunohistochemical study. Chang Gung Med J. Jul-Aug. 2012;35(4):309-317. EXC6. [pmid: 22913857].
220 Chen WS, Chen JY, Liu JM, et al. Microsatellite instability in sporadic-colon-cancer patients with and without liver metastases. Int J Cancer. Aug. 22. 1997;74(4):470-474. EXC4. [pmid: 9291442].
221 Chen X, Li W, Hu X, et al. Effect of gefitinib challenge to initial treatment with non-small cell lung cancer. Biomed Pharmacother. Dec. 2011;65(8):542-546. EXC6. [pmid: 21840160].
222 Chen YM, Tsai CM, Fan WC, et al. Phase II randomized trial of erlotinib or vinorelbine in chemonaive, advanced, non-small cell lung cancer patients aged 70 years or older. J Thorac Oncol. Feb. 2012;7(2):412-418. EXC6. [pmid: 22157367].
223 Cheng C, Wu YL, Gu LJ, et al. [Predicting efficacy of neoadjuvant cheomotherapy on resectable stage IIIA non-small cell lung cancer by multi-gene expressions]. Ai zheng = Aizheng = Chinese journal of cancer. 2005;(7):846-849. EXC2. [pmid: 16004813].
224 Chiosea S, Shuai Y, Cieply K, et al. EGFR fluorescence in situ hybridization-positive lung adenocarcinoma: incidence of coexisting KRAS and BRAF mutations. Hum Pathol. Aug. 2010;41(8):1053-1060. EXC6. [pmid: 20381121].
225 Chiosea SI, Sherer CK, Jelic T, et al. KRAS mutant allele-specific imbalance in lung adenocarcinoma. Mod Pathol. Dec. 2011;24(12):1571-1577. EXC5. [pmid: 21743433].
226 Cho MC, Choi CM, Kim S, et al. Direct sequencing in cytological specimens as a useful strategy for detecting EGFR mutations in non-small cell lung cancer patients. Clin Chem Lab Med. Mar. 2012;50(3):565-572. EXC4. [pmid: 21899495].
227 Cho SH, Park LC, Ji JH, et al. Efficacy of EGFR tyrosine kinase inhibitors for non-adenocarcinoma NSCLC patients with EGFR mutation. Cancer Chemother Pharmacol. 2012;70(2):315-320. EXC3. [pmid: 22760226].
228 Choi CM, Seo KW, Jang SJ, et al. Chromosomal instability is a risk factor for poor prognosis of adenocarcinoma of the lung: Fluorescence in situ hybridization analysis of paraffin-embedded tissue from Korean patients. Lung Cancer. Apr. 2009;64(1):66-70. EXC4. [pmid: 18814932].
229 Choi DR, Lee DH, Choi CM, et al. Erlotinib in first-line therapy for non-small cell lung cancer: a prospective phase II study. Anticancer Res. Oct. 2011;31(10):3457-3462. EXC6. [pmid: 21965761].
230 Choi H, Kratz J, Pham P, et al. Development of a rapid and practical mutation screening assay for human lung adenocarcinoma. Int J Oncol. Jun. 2012;40(6):1900-1906. EXC4. [pmid: 22407457].
231 Choi H, Paeng JC, Kim DW, et al. Metabolic and metastatic characteristics of ALK-rearranged lung adenocarcinoma on FDG PET/CT. Lung Cancer. Mar. 2013;79(3):242-247. EXC6. [pmid: 23261227].
232 Choi SW, Lee KJ, Bae YA, et al. Genetic classification of colorectal cancer based on chromosomal loss and microsatellite instability predicts survival. Clin Cancer Res. Jul. 2002;8(7):2311-2322. EXC4. [pmid: 12114436].
233 Choi YJ, Cho BC, Jeong YH, et al. Correlation Between 18F-Fluorodeoxyglucose Uptake and Epidermal Growth Factor Receptor Mutations in Advanced Lung Cancer. Nuclear Med Molec Imaging. 2012;46(3):169-175. EXC3.
234 Choi YL, Soda M, Yamashita Y, et al. EML4-ALK mutations in lung cancer that confer resistance to ALK inhibitors. N Engl J Med. Oct. 28. 2010;363(18):1734-1739. EXC2. [pmid: 20979473].
235 Cholongitas E, Kokolakis G, Ioannidou D. How important is the pus culture obtained from epithelial growth factor receptor (EGFR) inhibitors'associated rash?. Int J Dermatol. 2008;47(11):1203-1204. EXC8. [pmid: 18986464].
236 Chou TY, Chiu CH, Li LH, et al. Mutation in the tyrosine kinase domain of epidermal growth factor receptor is a predictive and prognostic factor for gefitinib treatment in patients with non-small cell lung cancer. Clin Cancer Res. May. 15. 2005;11(10):3750-3757. EXC6. [pmid: 15897572].
237 Christensen M, Katballe N, Wikman F, et al. Antibody-based screening for hereditary nonpolyposis colorectal carcinoma compared with microsatellite analysis and sequencing. Cancer. Dec. 1. 2002;95(11):2422-2430. EXC3. [pmid: 12436451].
238 Chua W, Goldstein D, Lee CK, et al. Molecular markers of response and toxicity to FOLFOX chemotherapy in metastatic colorectal cancer. Br J Cancer. Sep. 15. 2009;101(6):998-1004. EXC3. [pmid: 19672255].
239 Chuko J, Yeh MK, Chen BJ, et al. Efficacy of cetuximab on wild-type and mutant KRAS in colorectal cancer: systematic review and meta-analysis (Structured abstract). J Med Sciences. 2010;(5):189-198. EXC2.
240 Chung CH, Seeley EH, Roder H, et al. Detection of tumor epidermal growth factor receptor pathway dependence by serum mass spectrometry in cancer patients. Cancer Epidemiology Biomarkers and Prevention. 2010;19(2):358-365. EXC4.
241 Chung FT, Lee KY, Wang CW, et al. Tumor-associated macrophages correlate with response to epidermal growth factor receptor-tyrosine kinase inhibitors in advanced non-small cell lung cancer. Int J Cancer. Aug. 1. 2012;131(3):E227-E235. EXC4. [pmid: 22174092].
242 Chung JH, Choe G, Jheon S, et al. Epidermal growth factor receptor mutation and pathologic-radiologic correlation between multiple lung nodules with ground-glass opacity differentiates multicentric origin from intrapulmonary spread. J Thorac Oncol. Dec. 2009;4(12):1490-1495. EXC6. [pmid: 19844187].
243 Chung KP, Wu SG, Wu JY, et al. Clinical outcomes in non-small cell lung cancers harboring different exon 19 deletions in EGFR. Clin Cancer Res. 2012;18(12):3470-3477. EXC6. [pmid: 22510346].
244 Chung KY, Kim NG, Li LS, et al. Clinicopathologic characteristics related to the high variability of coding mononucleotide repeat sequences in tumors with high-microsatellite instability. Oncol Rep. Mar-Apr. 2003;10(2):439-444. EXC6. [pmid: 12579286].
245 Cicek MS, Lindor NM, Gallinger S, et al. Quality assessment and correlation of microsatellite instability and immunohistochemical markers among population- and clinic-based colorectal tumors results from the Colon Cancer Family Registry. J Mol Diagn. May. 2011;13(3):271-281. EXC4. [pmid: 21497289].
246 Ciledag A, Kaya A, Yetkin O, et al. The prognostic value of serum epidermal growth factor receptor level in patients with non-small cell lung cancer. Tuberk Toraks. 2008;56(4):390-395. EXC4. [pmid: 19123074].
247 Clark GM, Zborowski DM, Santabarbara P, et al. Smoking history and epidermal growth factor receptor expression as predictors of survival benefit from erlotinib for patients with non-small-cell lung cancer in the National Cancer Institute of Canada Clinical Trials Group study BR.21. Clin Lung Cancer. May. 2006;7(6):389-394. EXC5. [pmid: 16800964].
248 Cobleigh MA, Tabesh B, Bitterman P, et al. Tumor gene expression and prognosis in breast cancer patients with 10 or more positive lymph nodes. Clin Cancer Res. Dec. 15. 2005;11(24 Pt 1):8623-8631. EXC4. [pmid: 16361546].
249 Cohn AL, Shumaker GC, Khandelwal P, et al. An open-label, single-arm, phase 2 trial of panitumumab plus FOLFIRI as second-line therapy in patients with metastatic colorectal cancer. Clin Colorectal Cancer. Sep. 2011;10(3):171-177. EXC3. [pmid: 21855038].
250 Cohn DE, Pavelka JC, Frankel WL, et al. Correlation between patient weight and defects in DNA mismatch repair: Is this the link between an increased risk of previous cancer in thinner women with endometrial cancer?. Int J Gynecol Cancer. 2008;18(1):136-140. EXC5. [pmid: 17466051].
251 Colebatch A, Hitchins M, Williams R, et al. The role of MYH and microsatellite instability in the development of sporadic colorectal cancer. Br J Cancer. Nov. 6. 2006;95(9):1239-1243. EXC6. [pmid: 17031395].
252 Colombino M, Cossu A, Manca A, et al. Prevalence and prognostic role of microsatellite instability in patients with rectal carcinoma. Ann Oncol. Sep. 2002;13(9):1447-1453. EXC7. [pmid: 12196371].
253 Colucci G, Giuliani F, Garufi C, et al. Cetuximab plus FOLFOX-4 in untreated patients with advanced colorectal cancer: a Gruppo Oncologico dell'Italia Meridionale Multicenter phase II study. Oncology. 2010;79(5-6):415-422. EXC3. [pmid: 21474966].
254 Conde E, Angulo B, Tang M, et al. Molecular context of the EGFR mutations: evidence for the activation of mTOR/S6K signaling. Clin Cancer Res. Feb. 1. 2006;12(3 Pt 1):710-717. EXC6. [pmid: 16467080].
255 Conklin CM, Craddock KJ, Have C, et al. Immunohistochemistry is a reliable screening tool for identification of ALK rearrangement in non-small-cell lung carcinoma and is antibody dependent. J Thorac Oncol. Jan. 2013;8(1):45-51. EXC4. [pmid: 23196275].
256 Coolbaugh-Murphy MI, Xu JP, Ramagli LS, et al. Microsatellite instability in the peripheral blood leukocytes of HNPCC patients. Hum Mutat. Mar. 2010;31(3):317-324. EXC3. [pmid: 20052760].
257 Cooper WA, Yu B, Yip PY, et al. EGFR mutant-specific immunohistochemistry has high specificity and sensitivity for detecting targeted activating EGFR mutations in lung adenocarcinoma. J Clin Pathol. Sep. 2013;66(9):744-748. EXC4. [pmid: 23757037].
258 Coppola D, Nebozhyn M, Khalil F, et al. Unique ectopic lymph node-like structures present in human primary colorectal carcinoma are identified by immune gene array profiling. Am J Pathol. Jul. 2011;179(1):37-45. EXC4. [pmid: 21703392].
259 Cornianu M, Tudose N. Immunohistochemical markers in the morphological diagnosis of lung carcinoma. Rom J Morphol Embryol. Jul-Dec. 1997;43(3-4):181-191. EXC4. [pmid: 9747120].
260 Cortas T, Eisenberg R, Fu P, et al. Activation state EGFR and STAT-3 as prognostic markers in resected non-small cell lung cancer. Lung Cancer. Mar. 2007;55(3):349-355. EXC4. [pmid: 17161498].
261 Cortot AB, Italiano A, Burel-Vandenbos F, et al. KRAS mutation status in primary nonsmall cell lung cancer and matched metastases. Cancer. Jun. 1. 2010;116(11):2682-2687. EXC5. [pmid: 20336783].
262 Cosler LE, Kuderer NM, Hornberger J, et al. 21-gene RT-PCR assay in lymph node negative (LN-), estrogen receptor positive (ER+) breast cancer: An economic analysis including prognostic and predictive information. J Clin Oncol. Jun. 20. 2006;24(18):307s-s. EXC2.
263 Cosler LE, Lyman GH. Economic analysis of gene expression profile data to guide adjuvant treatment in women with early-stage breast cancer. Cancer Invest. Dec. 2009;27(10):953-959. EXC6. [pmid: 19909009].
264 Cox G, Jones JL, Andi A, et al. A biological staging model for operable non-small cell lung cancer. Thorax. Jul. 2001;56(7):561-566. EXC4. [pmid: 11413356].
265 Cox G, Louise Jones J, Andi A, et al. Bcl-2 is an independent prognostic factor and adds to a biological model for predicting outcome in operable non-small cell lung cancer. Lung Cancer. Dec. 2001;34(3):417-426. EXC4. [pmid: 11714539].
266 CsToth I, Anthoine G, Berghmans T, et al. C-erbB-3 expression in non-small cell lung cancer (NSCLC) patients treated by Erlotinib. Anticancer Res. Jan. 2011;31(1):281-285. EXC4. [pmid: 21273611].
267 Cuadros-Celorrio M, Llanos-Mendez A, Villegas-Portero R. Mammaprint (Structured abstract). Health Technology Assessment Database. 2010;(3). EXC2.
268 Cuffe S, Bourredjem A, Graziano S, et al. A pooled exploratory analysis of the effect of tumor size and KRAS mutations on survival benefit from adjuvant platinum-based chemotherapy in node-negative non-small cell lung cancer. J Thorac Oncol. Jun. 2012;7(6):963-972. EXC6. [pmid: 22588152].
269 Curtin K, Samowitz WS, Ulrich CM, et al. Nutrients in folate-mediated, one-carbon metabolism and the risk of rectal tumors in men and women. Nutr Cancer. 2011;63(3):357-366. EXC6. [pmid: 21462086].
270 Curtin K, Ulrich CM, Samowitz WS, et al. Thymidylate synthase polymorphisms and colon cancer: associations with tumor stage, tumor characteristics and survival. Int J Cancer. May. 15. 2007;120(10):2226-2232. EXC6. [pmid: 17290389].
271 Cushman-Vokoun AM, Crowley AM, Rapp SA, et al. Comparison study of the performance of the QIAGEN EGFR RGQ and EGFR pyro assays for mutation analysis in non-small cell lung cancer. Am J Clin Pathol. Jul. 2013;140(1):7-19. EXC4. [pmid: 23765529].
272 Cutsem E, Köhne CH, Láng I, et al. Cetuximab plus irinotecan, fluorouracil, and leucovorin as first-line treatment for metastatic colorectal cancer: updated analysis of overall survival according to tumor KRAS and BRAF mutation status. J Clin Oncol. 2011;(15):2011-2019. EXC6. [pmid: 21502544].
273 Dacic S, Flanagan M, Cieply K, et al. Significance of EGFR protein expression and gene amplification in non-small cell lung carcinoma. Am J Clin Pathol. Jun. 2006;125(6):860-865. EXC4. [pmid: 16690485].
274 Dacic S, Shuai Y, Yousem S, et al. Clinicopathological predictors of EGFR/KRAS mutational status in primary lung adenocarcinomas. Mod Pathol. Feb. 2010;23(2):159-168. EXC6. [pmid: 19855375].
275 Dahabreh IJ, Linardou H, Siannis F, et al. Somatic EGFR mutation and gene copy gain as predictive biomarkers for response to tyrosine kinase inhibitors in non-small cell lung cancer (Provisional abstract). Clin Cancer Res. 2010;(1):291-303. EXC1. [pmid: 20028749].
276 Dahlin AM, Henriksson ML, Van Guelpen B, et al. Colorectal cancer prognosis depends on T-cell infiltration and molecular characteristics of the tumor. Mod Pathol. 2011;24(5):671-682. EXC4. [pmid: 21240258].
277 Dahlin AM, Palmqvist R, Henriksson ML, et al. The role of the CpG island methylator phenotype in colorectal cancer prognosis depends on microsatellite instability screening status. Clin Cancer Res. Mar. 15. 2010;16(6):1845-1855. EXC6. [pmid: 20197478].
278 Dahse R, Berndt A, Kosmehl H. PCR-based testing for therapy-related EGFR mutations in patients with non-small cell lung cancer. Anticancer Res. Jul-Aug. 2008;28(4B):2265-2270. EXC6. [pmid: 18751405].
279 D'Angelo SP, Janjigian YY, Ahye N, et al. Distinct clinical course of EGFR-mutant resected lung cancers: results of testing of 1118 surgical specimens and effects of adjuvant gefitinib and erlotinib. J Thorac Oncol. Dec. 2012;7(12):1815-1822. EXC7. [pmid: 23154553].
280 Daniele L, Cassoni P, Bacillo E, et al. Epidermal growth factor receptor gene in primary tumor and metastatic sites from non-small cell lung cancer. J Thorac Oncol. Jun. 2009;4(6):684-688. EXC6. [pmid: 19404216].
281 Daniely M, Rona R, Kaplan T, et al. Combined morphologic and fluorescence in situ hybridization analysis of voided urine samples for the detection and follow-up of bladder cancer in patients with benign urine cytology. Cancer. 2007;111(6):517-524. EXC5. [pmid: 17963263].
282 Daniely M, Rona R, Kaplan T, et al. Combined analysis of morphology and fluorescence in situ hybridization significantly increases accuracy of bladder cancer detection in voided urine samples. Urology. Dec. 2005;66(6):1354-1359. EXC5. [pmid: 16360483].
283 A prospective clinical utility study of the impact of the 21-gene recurrence score assay (Oncotype DX) in estrogen receptor positive (ER+) node negative (pN0) breast cancer in academic Canadian centers. ASCO. 2012. Exc-2.
284 Davies JM, Trembath D, Deal AM, et al. Phospho-ERK and AKT status, but not KRAS mutation status, are associated with outcomes in rectal cancer treated with chemoradiotherapy. Radiat Oncol. 2011;6:114. EXC6. [pmid: 21910869].
285 De Bruijn MT, Raats DAE, Tol J, et al. Combined KRAS and TP53 mutation status is not predictive in CAPOX-treated metastatic colorectal cancer. Anticancer Res. 2011;31(4):1379-1385. EXC5. [pmid: 21508389].
286 de Lima Lopes G, Chien R, Hornberger J. Cost-benefit of the 21-gene breast cancer recurrence score assay for patients in Singapore. Breast J. Mar-Apr. 2013;19(2):220-221. EXC2. [pmid: 23320386].
287 De Oliveira Duarte Achcar R, Nikiforova MN, Yousem SA. Micropapillary lung adenocarcinoma: EGFR, K-ras, and BRAF mutational profile. Am J Clin Pathol. May. 2009;131(5):694-700. EXC6. [pmid: 19369630].
288 De Pas T, Toffalorio F, Manzotti M, et al. Activity of epidermal growth factor receptor-tyrosine kinase inhibitors in patients with non-small cell lung cancer harboring rare epidermal growth factor receptor mutations. J Thorac Oncol. Nov. 2011;6(11):1895-1901. EXC4. [pmid: 21841502].
289 De Roock W, Claes B, Bernasconi D, et al. Effects of KRAS, BRAF, NRAS, and PIK3CA mutations on the efficacy of cetuximab plus chemotherapy in chemotherapy-refractory metastatic colorectal cancer: a retrospective consortium analysis. Lancet Oncol. Aug. 2010;11(8):753-762. EXC3. [pmid: 20619739].
290 De Roock W, Jonker DJ, Di Nicolantonio F, et al. Association of KRAS p.G13D mutation with outcome in patients with chemotherapy-refractory metastatic colorectal cancer treated with cetuximab. JAMA. Oct. 27. 2010;304(16):1812-1820. EXC3. [pmid: 20978259].
291 De Roock W, Piessevaux H, De Schutter J, et al. KRAS wild-type state predicts survival and is associated to early radiological response in metastatic colorectal cancer treated with cetuximab. Ann Oncol. Mar. 2008;19(3):508-515. EXC3. [pmid: 17998284].
292 De Ruyck K, Sabbe N, Oberije C, et al. Development of a multicomponent prediction model for acute esophagitis in lung cancer patients receiving chemoradiotherapy. Int J Radiat Oncol Biol Phys. Oct. 1. 2011;81(2):537-544. EXC4. [pmid: 21605946].
293 de Vos tot Nederveen Cappel WH, Meulenbeld HJ, Kleibeuker JH, et al. Survival after adjuvant 5-FU treatment for stage III colon cancer in hereditary nonpolyposis colorectal cancer. Int J Cancer. Apr. 10. 2004;109(3):468-471. EXC4. [pmid: 14961589].
294 Debniak T, Gorski B, Cybulski C, et al. Comparison of Alu-PCR, microsatellite instability, and immunohistochemical analyses in finding features characteristic for hereditary nonpolyposis colorectal cancer. J Cancer Res Clin Oncol. 2001;127(9):565-569. EXC3. [pmid: 11570578].
295 Deeb G, Wang J, Ramnath N, et al. Altered E-cadherin and epidermal growth factor receptor expressions are associated with patient survival in lung cancer: a study utilizing high-density tissue microarray and immunohistochemistry. Mod Pathol. Apr. 2004;17(4):430-439. EXC4. [pmid: 14739904].
296 Denice Smith G, Sangle NA, Wilson A, et al. A retrospective review of UroVysion fish interpretations over 8.6 years: A major shift in the patient test population. Diagn Cytopathol. May. 2013;41(5):437-447. MEDLINE PMID 22865746 (http://www.ncbi.nlm.nih.gov/pubmed/22865746) FULL TEXT LINK http://dx.doi.org/10.1002/dc.22881. EXC6. [pmid: 22865746].
297 Denzinger S, Stoehr R, Schwarz S, et al. Low level STK15 amplification in histologically benign urothelium of patients with bladder cancer adversely predicts patient outcome following cystectomy. Int J Oncol. Oct. 2007;31(4):793-802. EXC6. [pmid: 17786310].
298 Des Guetz G, Lecaille C, Mariani P, et al. Prognostic impact of microsatellite instability in colorectal cancer patients treated with adjuvant FOLFOX. Anticancer Res. Oct. 2010;30(10):4297-4301. EXC4. [pmid: 21036755].
299 des Guetz G, Mariani P, Cucherousset J, et al. Microsatellite instability and sensitivitiy to FOLFOX treatment in metastatic colorectal cancer. Anticancer Res. Jul-Aug. 2007;27(4C):2715-2719. EXC3. [pmid: 17695437].
300 Deschoolmeester V, Baay M, Van Marck E, et al. Tumor infiltrating lymphocytes: an intriguing player in the survival of colorectal cancer patients. BMC Immunol. 2010;11:19. EXC4. [pmid: 20385003].
301 Deschoolmeester V, Van Damme N, Baay M, et al. Microsatellite instability in sporadic colon carcinomas has no independent prognostic value in a Belgian study population. Eur J Cancer. Oct. 2008;44(15):2288-2295. EXC4. [pmid: 18707864].
302 Dewdney A, Cunningham D, Tabernero J, et al. Multicenter randomized phase II clinical trial comparing neoadjuvant oxaliplatin, capecitabine, and preoperative radiotherapy with or without cetuximab followed by total mesorectal excision in patients with high-risk rectal cancer (EXPERT-C). J Clin Oncol. May. 10. 2012;30(14):1620-1627. EXC5. [pmid: 22473163].
303 Di Bartolomeo M, Dotti KF, Pietrantonio F, et al. Biological analysis of phase ii study evaluating the activity of cetuximab combined to oxaliplatin and fluoropirimidine (TEGAFOX-E) as first line treatment in metastatic colorectal cancer (mCRC) pts by the italian trials in medical oncology (I.T.M.O.) group. Eur J Cancer. 2011;47:S433. EXC6.
304 Di Maio M, Leighl NB, Gallo C, et al. Quality of life analysis of TORCH, a randomized trial testing first-line erlotinib followed by second-line cisplatin/gemcitabine chemotherapy in advanced non-small-cell lung cancer. J Thorac Oncol. Dec. 2012;7(12):1830-1844. EXC3. [pmid: 23154555].
305 Di Nicolantonio F, Martini M, Molinari F, et al. Wild-type BRAF is required for response to panitumumab or cetuximab in metastatic colorectal cancer. J Clin Oncol. Dec. 10. 2008;26(35):5705-5712. EXC3. [pmid: 19001320].
306 Diaz-Rubio E, Gomez-Espana A, Massuti B, et al. Role of Kras Status in Patients with Metastatic Colorectal Cancer Receiving First-Line Chemotherapy plus Bevacizumab: A TTD Group Cooperative Study. PLoS One. 2012;7(10). EXC3.
307 Dicuonzo G, Angeletti S, Garcia-Foncillas J, et al. Colorectal carcinomas and PTEN/MMAC1 gene mutations. Clin Cancer Res. Dec. 2001;7(12):4049-4053. EXC8. [pmid: 11751500].
308 Dienstmann R, Serpico D, Rodon J, et al. Molecular profiling of patients with colorectal cancer and matched targeted therapy in phase I clinical trials. Molecul Cancer Therapeut. 2012;11(9):2062-2071. EXC4.
309 Diep CB, Thorstensen L, Meling GI, et al. Genetic tumor markers with prognostic impact in Dukes' stages B and C colorectal cancer patients. J Clin Oncol. Mar. 1. 2003;21(5):820-829. EXC4. [pmid: 12610180].
310 Dietmaier W, Wallinger S, Bocker T, et al. Diagnostic microsatellite instability: definition and correlation with mismatch repair protein expression. Cancer Res. Nov. 1. 1997;57(21):4749-4756. EXC4. [pmid: 9354436].
311 Dimou A, Agarwal S, Anagnostou V, et al. Standardization of epidermal growth factor receptor (EGFR) measurement by quantitative immunofluorescence and impact on antibody-based mutation detection in non-small cell lung cancer. Am J Pathol. Aug. 2011;179(2):580-589. EXC4. [pmid: 21722621].
312 Dittadi R, Gion M, Pagan V, et al. Epidermal growth factor receptor in lung malignancies. Comparison between cancer and normal tissue. Br J Cancer. Oct. 1991;64(4):741-744. EXC4. [pmid: 1654986].
313 Dodurga Y, Avc ICB, S YI, et al. UroVysion fluorescence in situ hybridization (UroVysion FISH) assay for detection of bladder cancer in voided urine of Turkish patients: A preliminary study. Wspolczesna Onkologia. 2013. 2013;17(2):156-160. FULL TEXT LINK http://dx.doi.org/10.5114/wo.2013.34619. EXC4.
314 Doebele RC, Lu X, Sumey C, et al. Oncogene status predicts patterns of metastatic spread in treatment-naive nonsmall cell lung cancer. Cancer. 2012;118(18):4502-4511. EXC3. [pmid: 22282022].
315 Dogan S, Shen R, Ang DC, et al. Molecular epidemiology of EGFR and KRAS mutations in 3,026 lung adenocarcinomas: higher susceptibility of women to smoking-related KRAS-mutant cancers. Clin Cancer Res. Nov. 15. 2012;18(22):6169-6177. EXC6. [pmid: 23014527].
316 Doi T, Tahara M, Yoshino T, et al. Tumor KRAS status predicts responsiveness to panitumumab in Japanese patients with metastatic colorectal cancer. Jpn J Clin Oncol. Feb. 2011;41(2):210-216. EXC3. [pmid: 21169348].
317 Dolcetti R, Viel A, Doglioni C, et al. High prevalence of activated intraepithelial cytotoxic T lymphocytes and increased neoplastic cell apoptosis in colorectal carcinomas with microsatellite instability. Am J Pathol. Jun. 1999;154(6):1805-1813. EXC4. [pmid: 10362805].
318 Dong HS, Dong KC, Kim YH, et al. Effectiveness of each bethesda marker in defining microsatellite instability when screening for Lynch syndrome. Hepatogastroenterology. 2009;56(91-92):672-676. EXC3. [pmid: 19621678].
319 Dong J, Dai J, Shu Y, et al. Polymorphisms in EGFR and VEGF contribute to non-small-cell lung cancer survival in a Chinese population. Carcinogenesis. 2010;31(6):1080-1086. EXC5. [pmid: 20400478].
320 Dongiovanni D, Daniele L, Barone C, et al. Gefitinib (ZD1839): therapy in selected patients with non-small cell lung cancer (NSCLC)?. Lung Cancer. Jul. 2008;61(1):73-81. EXC6. [pmid: 18243402].
321 Donovan MJ, Kotsianti A, Bayer-Zubek V, et al. A systems pathology model for predicting overall survival in patients with refractory, advanced non-small-cell lung cancer treated with gefitinib. Eur J Cancer. May. 2009;45(8):1518-1526. EXC6. [pmid: 19272767].
322 Dorard C, De Thonel A, Collura A, et al. Expression of a mutant HSP110 sensitizes colorectal cancer cells to chemotherapy and improves disease prognosis. Nat Med. 2011;17(10):1283-1289. EXC4. [pmid: 21946539].
323 Dotan E, Meropol NJ, Zhu F, et al. Relationship of increased aurora kinase A gene copy number, prognosis and response to chemotherapy in patients with metastatic colorectal cancer. Br J Cancer. 2012;106(4):748-755. EXC4. [pmid: 22240781].
324 Douillard JY, Shepherd FA, Hirsh V, et al. Molecular predictors of outcome with gefitinib and docetaxel in previously treated non-small-cell lung cancer: data from the randomized phase III INTEREST trial. J Clin Oncol. 2010;(5):744-752. EXC5. [pmid: 20038723].
325 Douillard JY, Siena S, Cassidy J, et al. Randomized, phase III trial of panitumumab with infusional fluorouracil, leucovorin, and oxaliplatin (FOLFOX4) versus FOLFOX4 alone as first-line treatment in patients with previously untreated metastatic colorectal cancer: the PRIME study. J Clin Oncol. Nov. 1. 2010;28(31):4697-4705. EXC3. [pmid: 20921465].
326 Dove-Edwin I, de Jong AE, Adams J, et al. Prospective Results of Surveillance Colonoscopy in Dominant Familial Colorectal Cancer With and Without Lynch Syndrome. Gastroenterology. 2006;130(7):1995-2000. EXC6. [pmid: 16762622].
327 Dragani TA, Hirohashi S, Juji T, et al. Population-based mapping of pulmonary adenoma susceptibility 1 locus. Cancer Res. Sep. 15. 2000;60(18):5017-5020. EXC4. [pmid: 11016621].
328 Dragnev KH, Ma T, Cyrus J, et al. Bexarotene plus erlotinib suppress lung carcinogenesis independent of KRAS mutations in two clinical trials and transgenic models. Cancer Prev Res (Phila). Jun. 2011;4(6):818-828. EXC4. [pmid: 21636548].
329 Dragnev KH, Petty WJ, Shah S, et al. Bexarotene and erlotinib for aerodigestive tract cancer. J Clin Oncol. Dec. 1. 2005;23(34):8757-8764. EXC6. [pmid: 16314636].
330 Drukker CA, Bueno-de-Mesquita JM, Retel VP, et al. A prospective evaluation of a breast cancer prognosis signature in the observational RASTER study. Int J Cancer. 2013. Jan. 31. EXC 6. [pmid: 23371464].
331 Dudek AZ, Kmak KL, Koopmeiners J, et al. Skin rash and bronchoalveolar histology correlates with clinical benefit in patients treated with gefitinib as a therapy for previously treated advanced or metastatic non-small cell lung cancer. Lung Cancer. Jan. 2006;51(1):89-96. EXC6. [pmid: 16290256].
332 Dufort S, Richard MJ, Lantuejoul S, et al. Pyrosequencing, a method approved to detect the two major EGFR mutations for anti EGFR therapy in NSCLC. J Exp Clin Cancer Res. 2011;30:57. EXC6. [pmid: 21575212].
333 Dutu T, Michiels S, Fouret P, et al. Differential expression of biomarkers in lung adenocarcinoma: a comparative study between smokers and never-smokers. Ann Oncol. Dec. 2005;16(12):1906-1914. EXC4. [pmid: 16219624].
334 Dziadziuszko R, Holm B, Skov BG, et al. Epidermal growth factor receptor gene copy number and protein level are not associated with outcome of non-small-cell lung cancer patients treated with chemotherapy. Ann Oncol. Mar. 2007;18(3):447-452. EXC4. [pmid: 17082511].
335 Dziadziuszko R, Witta SE, Cappuzzo F, et al. Epidermal growth factor receptor messenger RNA expression, gene dosage, and gefitinib sensitivity in non-small cell lung cancer. Clin Cancer Res. May. 15. 2006;12(10):3078-3084. EXC6. [pmid: 16707605].
336 Eberhard DA, Johnson BE, Amler LC, et al. Mutations in the epidermal growth factor receptor and in KRAS are predictive and prognostic indicators in patients with non-small-cell lung cancer treated with chemotherapy alone and in combination with erlotinib. J Clin Oncol. Sep. 1. 2005;23(25):5900-5909. EXC6. [pmid: 16043828].
337 Ebinger M, Sotlar K, Weber A, et al. Simplified detection of microsatellite instability in colorectal cancer without the need for corresponding germline DNA analysis. J Clin Pathol. 2006;59(10):1114-1115. EXC4. [pmid: 17021141].
338 Ecri. Microsatellite instability testing for hereditary nonpolyposis colorectal cancer (Structured abstract). Health Technology Assessment Database. 2002;(3):28. EXC3.
339 Edmonston TB, Cuesta KH, Burkholder S, et al. Colorectal carcinomas with high microsatellite instability: defining a distinct immunologic and molecular entity with respect to prognostic markers. Hum Pathol. Dec. 2000;31(12):1506-1514. EXC8. [pmid: 11150376].
340 Eichler AF, Kahle KT, Wang DL, et al. EGFR mutation status and survival after diagnosis of brain metastasis in nonsmall cell lung cancer. Neuro Oncol. Nov. 2010;12(11):1193-1199. EXC6. [pmid: 20627894].
341 Ellison G, Donald E, McWalter G, et al. A comparison of ARMS and DNA sequencing for mutation analysis in clinical biopsy samples. J Exp Clin Cancer Res. 2010;29:132. EXC3. [pmid: 20925915].
342 El-Osta H, Falchook G, Tsimberidou A, et al. BRAF mutations in advanced cancers: Clinical characteristics and outcomes. PLoS One. 2011;6(10). EXC4.
343 Elsaleh H, Cserni G, Iacopetta B. Extent of nodal involvement in Stage III colorectal carcinoma: relationship to clinicopathologic variables and genetic alterations. Dis Colon Rectum. Sep. 2002;45(9):1218-1222. EXC4. [pmid: 12352240].
344 Elsaleh H, Iacopetta B. Microsatellite instability is a predictive marker for survival benefit from adjuvant chemotherapy in a population-based series of stage III colorectal carcinoma. Clin Colorectal Cancer. Aug. 2001;1(2):104-109. EXC4. [pmid: 12445368].
345 Elsaleh H, Powell B, McCaul K, et al. P53 alteration and microsatellite instability have predictive value for survival benefit from chemotherapy in stage III colorectal carcinoma. Clin Cancer Res. May. 2001;7(5):1343-1349. EXC4. [pmid: 11350904].
346 Elsaleh H, Powell B, Soontrapornchai P, et al. p53 gene mutation, microsatellite instability and adjuvant chemotherapy: impact on survival of 388 patients with Dukes' C colon carcinoma. Oncology. 2000;58(1):52-59. EXC4. [pmid: 10644941].
347 Emterling A, Wallin A, Arbman G, et al. Clinicopathological significance of microsatellite instability and mutated RIZ in colorectal cancer. Ann Oncol. Feb. 2004;15(2):242-246. EXC4. [pmid: 14760116].
348 Endo K, Konishi A, Sasaki H, et al. Epidermal growth factor receptor gene mutation in non-small cell lung cancer using highly sensitive and fast TaqMan PCR assay. Lung Cancer. Dec. 2005;50(3):375-384. EXC6. [pmid: 16199108].
349 Endo K, Sasaki H, Yano M, et al. Evaluation of the epidermal growth factor receptor gene mutation and copy number in non-small cell lung cancer with gefitinib therapy. Oncol Rep. Sep. 2006;16(3):533-541. EXC6. [pmid: 16865253].
350 Endoh H, Ishibashi Y, Yamaki E, et al. Immunohistochemical analysis of phosphorylated epidermal growth factor receptor might provide a surrogate marker of EGFR mutation. Lung Cancer. Feb. 2009;63(2):241-246. EXC4. [pmid: 18585821].
351 Endoh H, Yatabe Y, Kosaka T, et al. PTEN and PIK3CA expression is associated with prolonged survival after gefitinib treatment in EGFR-mutated lung cancer patients. J Thorac Oncol. Sep. 2006;1(7):629-634. EXC6. [pmid: 17409929].
352 Erb C, Fox K, Patel M. Evaluation of practice patterns in the treatment of node-negative, hormone-receptor positive breast cancer patients with the use of the Oncotype DX assay at the University of Pennsylvania. 30th Annual San Antonio Breast Cancer Symposium. Breast Cancer Res Treat. 2007;106:A3082. EXC2.
353 Erdamar S, Ucaryilmaz E, Demir G, et al. Importance of MutL homologue MLH1 and MutS homologue MSH2 expression in Turkish patients with sporadic colorectal cancer. World J Gastroenterol. Sep. 7. 2007;13(33):4437-4444. EXC4. [pmid: 17724798].
354 Esemuede I, Forslund A, Khan SA, et al. Improved testing for microsatellite instability in colorectal cancer using a simplified 3-marker assay. Ann Surg Oncol. Dec. 2010;17(12):3370-3378. EXC5. [pmid: 20703819].
355 Espinel CF, Keating S, Hibshoosh H, et al. MammaPrint Feasibility in a Large Tertiary Urban Medical Center: An Initial Experience. Scientifica. 2012;2012:1-5. EXC6.
356 Espinosa E, Sanchez-Navarro I, Gamez-Pozo A, et al. Comparison of prognostic gene profiles using qRT-PCR in paraffin samples: a retrospective study in patients with early breast cancer. PLoS One. 2009;4(6):e5911. EXC5. [pmid: 19547727].
357 Esserman LJ, Berry DA, Cheang MC, et al. Chemotherapy response and recurrence-free survival in neoadjuvant breast cancer depends on biomarker profiles: results from the I-SPY 1 TRIAL (CALGB 150007/150012; ACRIN 6657). Breast Cancer Res Treat. Apr. 2012;132(3):1049-1062. EXC6. [pmid: 22198468].
358 Esserman LJ, Berry DA, DeMichele A, et al. Pathologic complete response predicts recurrence-free survival more effectively by cancer subset: results from the I-SPY 1 TRIAL--CALGB 150007/150012, ACRIN 6657. J Clin Oncol. Sep. 10. 2012;30(26):3242-3249. EXC4. [pmid: 22649152].
359 Esserman LJ, Shieh Y, Rutgers EJT, et al. Impact of mammographic screening on the detection of good and poor prognosis breast cancers. Breast Cancer Res Treat. 2011;130(3):725-734. EXC5. [pmid: 21892702].
360 Evertson S, Wallin A, Arbman G, et al. Microsatellite instability and MBD4 mutation in unselected colorectal cancer. Anticancer Res. Jul-Aug. 2003;23(4):3569-3574. EXC4. [pmid: 12926109].
361 Fan X, Liu B, Xu H, et al. Immunostaining with EGFR mutation-specific antibodies: a reliable screening method for lung adenocarcinomas harboring EGFR mutation in biopsy and resection samples. Hum Pathol. Aug. 2013;44(8):1499-1507. EXC4. [pmid: 23465272].
362 Farina G, Longo F, Martelli O, et al. Rationale for treatment and study design of tailor: a randomized phase III trial of second-line erlotinib versus docetaxel in the treatment of patients affected by advanced non-small-cell lung cancer with the absence of epidermal growth factor receptor mutations. Clin Lung Cancer. 2011;(2):138-141. EXC2. [pmid: 21550561].
363 Farrington SM, Lin-Goerke J, Ling J, et al. Systematic analysis of hMSH2 and hMLH1 in young colon cancer patients and controls. Am J Hum Gene. 1998;63(3):749-759. EXC2.
364 Farrington SM, McKinley AJ, Carothers AD, et al. Evidence for an age-related influence of microsatellite instability on colorectal cancer survival. Int J Cancer. Apr. 20. 2002;98(6):844-850. EXC4. [pmid: 11948461].
365 Fassina A, Gazziero A, Zardo D, et al. Detection of EGFR and KRAS mutations on trans-thoracic needle aspiration of lung nodules by high resolution melting analysis. J Clin Pathol. Dec. 2009;62(12):1096-1102. EXC6. [pmid: 19640859].
366 Feeley KM, Fullard JF, Heneghan MA, et al. Microsatellite instability in sporadic colorectal carcinoma is not an indicator of prognosis. J Pathol. May. 1999;188(1):14-17. EXC4. [pmid: 10398134].
367 Felip E, Rojo F, Reck M, et al. A phase II pharmacodynamic study of erlotinib in patients with advanced non-small cell lung cancer previously treated with platinum-based chemotherapy. Clin Cancer Res. Jun. 15. 2008;14(12):3867-3874. EXC6. [pmid: 18559607].
368 Feliu Batlle J, Cuadrado E, Castro J, et al. Irinotecan-cetuximab-bevacizumab as a salvage treatment in heavily pretreated metastatic colorectal cancer patients: A retrospective observational study. Chemotherapy. 2011;57(2):138-144. EXC8. [pmid: 21447947].
369 Fernandez-Peralta AM, Nejda N, Oliart S, et al. Significance of mutations in TGFBR2 and BAX in neoplastic progression and patient outcome in sporadic colorectal tumors with high-frequency microsatellite instability. Cancer Genet Cytogenet. 2005;157(1):18-24. EXC4. [pmid: 15676142].
370 Fernando Lopez-Rios F, Angulo B, Gomez B, et al. Comparison of molecular testing methods for the detection of EGFR mutations in formalin-fixed paraffin-embedded tissue (FFPET) specimens of non-small cell lung cancer (NSCLC). ESMO Lung. 2012. Geneva. EXC9.
371 Fernebro E, Halvarsson B, Baldetorp B, et al. Predominance of CIN versus MSI in the development of rectal cancer at young age. BMC Cancer. Oct. 14. 2002;2:25. EXC6. [pmid: 12379157].
372 Ferra S, Denley R, Herr H, et al. Reflex UroVysion testing in suspicious urine cytology cases. Cancer. Feb. 25. 2009;117(1):7-14. EXC3. [pmid: 19347824].
373 Fidler MJ, Argiris A, Patel JD, et al. The potential predictive value of cyclooxygenase-2 expression and increased risk of gastrointestinal hemorrhage in advanced non-small cell lung cancer patients treated with erlotinib and celecoxib. Clin Cancer Res. Apr. 1. 2008;14(7):2088-2094. EXC6. [pmid: 18381949].
374 Fidler MJ, Morrison LE, Basu S, et al. PTEN and PIK3CA gene copy numbers and poor outcomes in non-small cell lung cancer patients with gefitinib therapy. Br J Cancer. Dec. 6. 2011;105(12):1920-1926. EXC3. [pmid: 22095222].
375 Finberg KE, Sequist LV, Joshi VA, et al. Mucinous differentiation correlates with absence of EGFR mutation and presence of KRAS mutation in lung adenocarcinomas with bronchioloalveolar features. J Mol Diagn. Jul. 2007;9(3):320-326. EXC6. [pmid: 17591931].
376 Firestein R, Shima K, Nosho K, et al. CDK8 expression in 470 colorectal cancers in relation to beta-catenin activation, other molecular alterations and patient survival. Int J Cancer. Jun. 15. 2010;126(12):2863-2873. EXC6. [pmid: 19790197].
377 Fisher B, Dignam J, Wolmark N, et al. Tamoxifen and chemotherapy for lymph node-negative, estrogen receptor-positive breast cancer. J Natl Cancer Inst. Nov. 19. 1997;89(22):1673-1682. EXC6. [pmid: 9390536].
378 Evaluation of Oncotype DX testing and subsequent patterns of care in patients (pts) with early-stage breast cancer (ESBC). ASCO. 2012. EXC6.
379 Flaig TW, Wilson S, van Bokhoven A, et al. Detection of circulating tumor cells in metastatic and clinically localized urothelial carcinoma. Urology. Oct. 2011;78(4):863-867. EXC5. [pmid: 21813167].
380 Flanagan MB, Dabbs DJ, Brufsky AM, et al. Histopathologic variables predict Oncotype DX recurrence score. Mod Pathol. Oct. 2008;21(10):1255-1261. EXC6. [pmid: 18360352].
381 Fong KM, Zimmerman PV, Smith PJ. KRAS codon 12 mutations in Australian non-small cell lung cancer. Aust N Z J Med. Apr. 1998;28(2):184-189. EXC6. [pmid: 9612526].
382 Fontanini G, De Laurentiis M, Vignati S, et al. Evaluation of epidermal growth factor-related growth factors and receptors and of neoangiogenesis in completely resected stage I-IIIA non-small-cell lung cancer: amphiregulin and microvessel count are independent prognostic indicators of survival. Clin Cancer Res. Jan. 1998;4(1):241-249. EXC4. [pmid: 9516978].
383 Fornaro L, Baldi GG, Masi G, et al. Cetuximab plus irinotecan after irinotecan failure in elderly metastatic colorectal cancer patients: clinical outcome according to KRAS and BRAF mutational status. Crit Rev Oncol Hematol. Jun. 2011;78(3):243-251. EXC3. [pmid: 20619672].
384 Forster S, Sattler HP, Hack M, et al. Microsatellite instability in sporadic carcinomas of the proximal colon: association with diploid DNA content, negative protein expression of p53, and distinct histomorphologic features. Surgery. Jan. 1998;123(1):13-18. EXC4. [pmid: 9457218].
385 Frattini M, Saletti P, Romagnani E, et al. PTEN loss of expression predicts cetuximab efficacy in metastatic colorectal cancer patients. Br J Cancer. Oct. 22. 2007;97(8):1139-1145. EXC6. [pmid: 17940504].
386 Freidlin B, McShane LM, Korn EL. Randomized clinical trials with biomarkers: design issues. J Natl Cancer Inst. Feb. 3. 2010;102(3):152-160. EXC7. [pmid: 20075367].
387 French AJ, Sargent DJ, Burgart LJ, et al. Prognostic significance of defective mismatch repair and BRAF V600E in patients with colon cancer. Clin Cancer Res. Jun. 1. 2008;14(11):3408-3415. EXC7. [pmid: 18519771].
388 Frigerio S, Padberg BC, Strebel RT, et al. Improved detection of bladder carcinoma cells in voided urine by standardized microsatellite analysis. Int J Cancer. Jul. 15. 2007;121(2):329-338. EXC6. [pmid: 17373664].
389 Fu XL, Zhu XZ, Shi DR, et al. Study of prognostic predictors for non-small cell lung cancer. Lung Cancer. Feb. 1999;23(2):143-152. EXC4. [pmid: 10217618].
390 Fujimoto K, Shitaune M, Shigeta M, et al. Combinatorial detection of urinary tract cancer in voided urine by cytology, nmp22, and urovysion fish test. Acta Cytol. May. SUPPL 1. 2013;57:149. EXC6.
391 Fujino S, Enokibori T, Katsura A, et al. Relationship between epidermal growth factor receptor expression and various prognostic factors in human non-small cell lung cancer. Japan J Lung Cancer. 1994;34(1):89-94. EXC2.
392 Fujino S, Enokibori T, Tezuka N, et al. A comparison of epidermal growth factor receptor levels and other prognostic parameters in non-small cell lung cancer. Eur J Cancer. Nov. 1996;32A(12):2070-2074. EXC4. [pmid: 9014747].
393 Fujita Y, Suda K, Kimura H, et al. Highly sensitive detection of EGFR T790M mutation using colony hybridization predicts favorable prognosis of patients with lung cancer harboring activating EGFR mutation. J Thorac Oncol. Nov. 2012;7(11):1640-1644. EXC6. [pmid: 22899358].
394 Fujiwara Y, Kiura K, Toyooka S, et al. Elevated serum level of sialylated glycoprotein KL-6 predicts a poor prognosis in patients with non-small cell lung cancer treated with gefitinib. Lung Cancer. Jan. 2008;59(1):81-87. EXC6. [pmid: 17765355].
395 Fukui T, Ohe Y, Tsuta K, et al. Prospective study of the accuracy of EGFR mutational analysis by high-resolution melting analysis in small samples obtained from patients with non-small cell lung cancer. Clin Cancer Res. Aug. 1. 2008;14(15):4751-4757. EXC4. [pmid: 18676744].
396 Fukui T, Tsuta K, Furuta K, et al. Epidermal growth factor receptor mutation status and clinicopathological features of combined small cell carcinoma with adenocarcinoma of the lung. Cancer Sci. Nov. 2007;98(11):1714-1719. EXC6. [pmid: 17784875].
397 Fukuoka M, Wu YL, Thongprasert S, et al. Biomarker analyses and final overall survival results from a phase III, randomized, open-label, first-line study of gefitinib versus carboplatin/paclitaxel in clinically selected patients with advanced non-small-cell lung cancer in Asia (IPASS). J Clin Oncol. Jul. 20. 2011;29(21):2866-2874. EXC5. [pmid: 21670455].
398 Furlan D, Carnevali IW, Bernasconi B, et al. Hierarchical clustering analysis of pathologic and molecular data identifies prognostically and biologically distinct groups of colorectal carcinomas. Mod Pathol. Jan. 2011;24(1):126-137. EXC6. [pmid: 20852594].
399 Furlan D, Tibiletti MG, Taborelli M, et al. The value of microsatellite instability in the detection of HNPCC families and of sporadic colorectal cancers with special biological features: an investigation on a series of 100 consecutive cases. Ann Oncol. Aug. 1998;9(8):901-906. EXC6. [pmid: 9789614].
400 Gadgeel SM, Ruckdeschel JC, Heath EI, et al. Phase II study of gefitinib, an epidermal growth factor receptor tyrosine kinase inhibitor (EGFR-TKI), and celecoxib, a cyclooxygenase-2 (COX-2) inhibitor, in patients with platinum refractory non-small cell lung cancer (NSCLC). J Thorac Oncol. Apr. 2007;2(4):299-305. EXC6. [pmid: 17409801].
401 Gaedcke J, Grade M, Jung K, et al. KRAS and BRAF mutations in patients with rectal cancer treated with preoperative chemoradiotherapy. Radiother Oncol. Jan. 2010;94(1):76-81. EXC7. [pmid: 19913317].
402 Gafa R, Maestri I, Matteuzzi M, et al. Sporadic colorectal adenocarcinomas with high-frequency microsatellite instability. Cancer. Nov. 15. 2000;89(10):2025-2037. EXC4. [pmid: 11066042].
403 Galvan AB, Salido M, Espinet B, et al. A multicolor fluorescence in situ hybridization assay: A monitoring tool in the surveillance of patients with a history of non-muscle-invasive urothelial cell carcinoma: A prospective study. Cancer Cytopathol. Dec. 25. 2011;119(6):395-403. EXC6. [pmid: 21717592].
404 Gandara DR, Grimminger P, Mack PC, et al. Association of epidermal growth factor receptor activating mutations with low ERCC1 gene expression in non-small cell lung cancer. J Thorac Oncol. Dec. 2010;5(12):1933-1938. EXC6. [pmid: 20975603].
405 Gao B, Sun Y, Zhang J, et al. Spectrum of LKB1, EGFR, and KRAS mutations in Chinese lung adenocarcinomas. J Thorac Oncol. 2010;5(8):1130-1135. EXC6. [pmid: 20559149].
406 Gao J, Wang TT, Yu JW, et al. Wild-Type KRAS and BRAF could predict response to cetuximab in Chinese colorectal cancer patients. Chin J Cancer Res. 2011;23(4):271-275. EXC7. [pmid: 23357879].
407 Gao JF, Arbman G, Wadhra TI, et al. Relationships of tumor inflammatory infiltration and necrosis with microsatellite instability in colorectal cancers. World J Gastroenterol. Apr. 14. 2005;11(14):2179-2183. EXC4. [pmid: 15810089].
408 Garcia-Aguilar J, Chen Z, Smith DD, et al. Identification of a biomarker profile associated with resistance to neoadjuvant chemoradiation therapy in rectal cancer. Ann Surg. Sep. 2011;254(3):486-492. discussion 92-3. EXC6. [pmid: 21865946].
409 Garcia-Albeniz X, Pericay C, Alonso-Espinaco V, et al. Serum matrilysin correlates with poor survival independently of KRAS and BRAF status in refractory advanced colorectal cancer patients treated with irinotecan plus cetuximab. Tumour Biol. Apr. 2011;32(2):417-424. EXC3. [pmid: 21104178].
410 Can Oncotype DX recurrence score (RS) be used in luminal A and luminal B breast cancer patients (pts) to predict the likely benefit of chemotherapy? A retrospective study in the Spanish population. ASCO. 2012. EXC6.
411 Garcia-Solano J, Conesa-Zamora P, Carbonell P, et al. Microsatellite pathologic score does not efficiently identify high microsatellite instability in colorectal serrated adenocarcinoma. Hum Pathol. May. 2013;44(5):759-765. EXC6. [pmid: 23089493].
412 Garm Spindler KL, Pallisgaard N, Rasmussen AA, et al. The importance of KRAS mutations and EGF61A>G polymorphism to the effect of cetuximab and irinotecan in metastatic colorectal cancer. Ann Oncol. May. 2009;20(5):879-884. EXC3. [pmid: 19179548].
413 Garrido-Laguna I, Hong DS, Janku F, et al. KRASness and PIK3CAness in patients with advanced colorectal cancer: outcome after treatment with early-phase trials with targeted pathway inhibitors. PLoS One. 2012;7(5):e38033. EXC3. [pmid: 22675430].
414 Gasinska A, Kolodziejski L, Niemiec J, et al. Clinical significance of biological differences between cavitated and solid form of squamous cell lung cancer. Lung Cancer. Aug. 2005;49(2):171-179. EXC4. [pmid: 16022910].
415 Gausachs M, Mur P, Corral J, et al. MLH1 promoter hypermethylation in the analytical algorithm of Lynch syndrome: a cost-effectiveness study. Eur J Hum Genet. Jul. 2012;20(7):762-768. EXC3. [pmid: 22274583].
416 Gautschi O, Huegli B, Ziegler A, et al. Origin and prognostic value of circulating KRAS mutations in lung cancer patients. Cancer Lett. Sep. 8. 2007;254(2):265-273. EXC4. [pmid: 17449174].
417 Gayed BA, Seideman C, Lotan Y. Cost-effectiveness of fluorescence in situ hybridization in patients with atypical cytology for the detection of urothelial carcinoma. J Urol. Oct. 2013;190(4):1181-1186. EXC7. [pmid: 23583531].
418 Geffen DB, Amir N, Sion-Vardy N, et al. Stage I breast cancer in a regional oncology practice in Israel 2002–2006: clinicopathologic features, risk estimation and planned therapy of 328 consecutive patients. Breast. Oct. 2009;18(5):316-321. EXC7. [pmid: 19819143].
419 Genomic Health. Scientific Publications and Presentations. OncotypeDX Breast Cancer Assay. Uncover the Unexpected. 2012. EXC2.
420 Georgieva M, Krasteva M, Angelova E, et al. Analysis of the K-ras/B-raf/Erk signal cascade, p53 and CMAP as markers for tumor progression in colorectal cancer patients. Oncol Rep. Jul. 2008;20(1):3-11. EXC8. [pmid: 18575712].
421 Gerson Cwilich R, Alban de la Torre LF, Villalobos Prieto A, et al. [Clinicopathological features, prognosis and influence in the adjuvant treatment of the risk recurrence groups determined by the 21 gene expression profile, Oncotype Dx(R), in early breast cancer]. Gac Med Mex. Mar-Apr. 2012;148(2):117-124. EXC2. [pmid: 22622310].
422 Gervaz P, Cerottini JP, Bouzourene H, et al. Comparison of microsatellite instability and chromosomal instability in predicting survival of patients with T3N0 colorectal cancer. Surgery. Feb. 2002;131(2):190-197. EXC7. [pmid: 11854698].
423 Gevensleben H, Gohring UJ, Buttner R, et al. Comparison of MammaPrint and TargetPrint results with clinical parameters in German patients with early stage breast cancer. Int J Mol Med. Dec. 2010;26(6):837-843. EXC5. [pmid: 21042777].
424 Giaccone G. The role of EGFR-TK inhibition in non-small cell lung cancer. Onkologie. Dec. 2005;28(12):619-620. EXC3. [pmid: 16370043].
425 Gianni L, Zambetti M, Clark K, et al. Gene expression profiles in paraffin-embedded core biopsy tissue predict response to chemotherapy in women with locally advanced breast cancer. J Clin Oncol. Oct. 10. 2005;23(29):7265-7277. EXC4. [pmid: 16145055].
426 Giatromanolaki A, Koukourakis MI, O'Byrne K, et al. Non-small cell lung cancer: c-erbB-2 overexpression correlates with low angiogenesis and poor prognosis. Anticancer Res. Nov-Dec. 1996;16(6B):3819-3825. EXC6. [pmid: 9042264].
427 Gille JJP, Hogervorst FBL, Pals G, et al. Genomic deletions of MSH2 and MLH1 in colorectal cancer families detected by a novel mutation detection approach. Br J Cancer. 2002;87(8):892-897. EXC3. [pmid: 12373605].
428 Gillern SM, Chua TC, Stojadinovic A, et al. KRAS status in patients with colorectal cancer peritoneal carcinomatosis and its impact on outcome. Am J Clin Oncol. Oct. 2010;33(5):456-460. EXC3. [pmid: 19952717].
429 Giovannetti E, Zucali PA, Peters GJ, et al. Association of polymorphisms in AKT1 and EGFR with clinical outcome and toxicity in non-small cell lung cancer patients treated with gefitinib. Mol Cancer Ther. Mar. 2010;9(3):581-593. EXC6. [pmid: 20159991].
430 Girard N, Deshpande C, Azzoli CG, et al. Use of epidermal growth factor receptor/Kirsten rat sarcoma 2 viral oncogene homolog mutation testing to define clonal relationships among multiple lung adenocarcinomas: comparison with clinical guidelines. Chest. Jan. 2010;137(1):46-52. EXC2. [pmid: 19376842].
431 Girard N, Jacoulet P, Gainet M, et al. Third-line chemotherapy in advanced non-small cell lung cancer: identifying the candidates for routine practice. J Thorac Oncol. Dec. 2009;4(12):1544-1549. EXC6. [pmid: 19884862].
432 Girard N, Sima CS, Jackman DM, et al. Nomogram to predict the presence of EGFR activating mutation in lung adenocarcinoma. Eur Respir J. Feb. 2012;39(2):366-372. EXC2. [pmid: 21778168].
433 Glas AM, Floore A, Delahaye LJ, et al. Converting a breast cancer microarray signature into a high-throughput diagnostic test. BMC Genomics. 2006;7:278. EXC7. [pmid: 17074082].
434 Gluck S, de Snoo F, Peeters J, et al. Molecular subtyping of early-stage breast cancer identifies a group of patients who do not benefit from neoadjuvant chemotherapy. Breast Cancer Res Treat. Jun. 2013;139(3):759-767. EXC6. [pmid: 23756626].
435 Prospective comparison of recurrence score and independent central pathology assessment of prognostic tools in early breast cancer (BC): Focus on HER2, ER, PR, Ki-67 results from the phase III WSG-Plan B trial. ASCO. 2012. EXC6.
436 Prospective comparison of Recurrence Score and different definitions of luminal subtypes by central pathology assessment of single markers in early breast cancer: results from the phase III WSG-planB. SABCS. 2012. EXC6.
437 Gnanasampanthan G, Elsaleh H, McCaul K, et al. Ki-ras mutation type and the survival benefit from adjuvant chemotherapy in Dukes' C colorectal cancer. J Pathol. 2001;195(5):543-548. EXC6. [pmid: 11745689].
438 Goel A, Nagasaka T, Hamelin R, et al. An optimized pentaplex PCR for detecting DNA mismatch repair-deficient colorectal cancers. PLoS One. 2010;5(2):e9393. EXC5. [pmid: 20195377].
439 Gofrit ON, Zorn KC, Silvestre J, et al. The predictive value of multi-targeted fluorescent in-situ hybridization in patients with history of bladder cancer. Urol Oncol. May-Jun. 2008;26(3):246-249. EXC6. [pmid: 18452813].
440 Goldhirsch A, Winer EP, Coates AS, et al. Personalizing the treatment of women with early breast cancer: highlights of the St Gallen International Expert Consensus on the Primary Therapy of Early Breast Cancer 2013. Ann Oncol. Sep. 2013;24(9):2206-2223. EXC7. [pmid: 23917950].
441 Goncalves A, Esteyries S, Taylor-Smedra B, et al. A polymorphism of EGFR extracellular domain is associated with progression free-survival in metastatic colorectal cancer patients receiving cetuximab-based treatment. BMC Cancer. 2008;8:169. EXC3. [pmid: 18544172].
442 Gormally E, Vineis P, Matullo G, et al. TP53 and KRAS2 mutations in plasma DNA of healthy subjects and subsequent cancer occurrence: a prospective study. Cancer Res. Jul. 1. 2006;66(13):6871-6876. EXC4. [pmid: 16818665].
443 Goss G, Ferry D, Wierzbicki R, et al. Randomized phase II study of gefitinib compared with placebo in chemotherapy-naive patients with advanced non-small-cell lung cancer and poor performance status. J Clin Oncol. May. 1. 2009;27(13):2253-2260. EXC6. [pmid: 19289623].
444 Goto K, Ichinose Y, Ohe Y, et al. Epidermal growth factor receptor mutation status in circulating free DNA in serum: from IPASS, a phase III study of gefitinib or carboplatin/paclitaxel in non-small cell lung cancer. J Thorac Oncol. Jan. 2012;7(1):115-121. EXC4. [pmid: 21900837].
445 Gow CH, Chang YL, Hsu YC, et al. Comparison of epidermal growth factor receptor mutations between primary and corresponding metastatic tumors in tyrosine kinase inhibitor-naive non-small-cell lung cancer. Ann Oncol. Apr. 2009;20(4):696-702. EXC5. [pmid: 19088172].
446 Gow CH, Chien CR, Chang YL, et al. Radiotherapy in lung adenocarcinoma with brain metastases: effects of activating epidermal growth factor receptor mutations on clinical response. Clin Cancer Res. Jan. 1. 2008;14(1):162-168. EXC6. [pmid: 18172267].
447 Gray RG, Quirke P, Handley K, et al. Validation study of a quantitative multigene reverse transcriptase-polymerase chain reaction assay for assessment of recurrence risk in patients with stage II colon cancer. J Clin Oncol. Dec. 10. 2011;29(35):4611-4619. EXC6. [pmid: 22067390].
448 Graziano F, Canestrari E, Loupakis F, et al. Genetic modulation of the Let-7 microRNA binding to KRAS 3'-untranslated region and survival of metastatic colorectal cancer patients treated with salvage cetuximab-irinotecan. Pharmacogenomics J. Oct. 2010;10(5):458-464. EXC3. [pmid: 20177422].
449 Greenson JK, Huang SC, Herron C, et al. Pathologic predictors of microsatellite instability in colorectal cancer. Am J Surg Pathol. Jan. 2009;33(1):126-133. EXC6. [pmid: 18830122].
450 Gregorc V, Ceresoli GL, Floriani I, et al. Effects of gefitinib on serum epidermal growth factor receptor and HER2 in patients with advanced non-small cell lung cancer. Clin Cancer Res. Sep. 15. 2004;10(18 Pt 1):6006-6012. EXC4. [pmid: 15447984].
451 Grob TJ, Hoenig T, Clauditz TS, et al. Frequent intratumoral heterogeneity of EGFR gene copy gain in non-small cell lung cancer. Lung Cancer. Mar. 2013;79(3):221-227. EXC6. [pmid: 23238037].
452 Grommes C, Oxnard GR, Kris MG, et al. "Pulsatile" high-dose weekly erlotinib for CNS metastases from EGFR mutant non-small cell lung cancer. Neuro Oncol. Dec. 2011;13(12):1364-1369. EXC3. [pmid: 21865399].
453 Grossi F, Spizzo R, Bordo D, et al. Prognostic stratification of stage IIIA pN2 non-small cell lung cancer by hierarchical clustering analysis of tissue microarray immunostaining data: an Alpe Adria Thoracic Oncology Multidisciplinary Group study (ATOM 014). J Thorac Oncol. Sep. 2010;5(9):1354-1360. EXC4. [pmid: 20631638].
454 Guastadisegni C, Colafranceschi M, Ottini L, et al. Microsatellite instability as a marker of prognosis and response to therapy: a meta-analysis of colorectal cancer survival data (Provisional abstract). Eur J Cancer. 2010;(15):2788-2798. EXC3. [pmid: 20627535].
455 Guo GF, Jiang WQ, Zhang B, et al. Autophagy-related proteins Beclin-1 and LC3 predict cetuximab efficacy in advanced colorectal cancer. World J Gastroenterol. Nov. 21. 2011;17(43):4779-4786. EXC3. [pmid: 22147978].
456 Guo H, Wan Y, Tian G, et al. EGFR mutations predict a favorable outcome for malignant pleural effusion of lung adenocarcinoma with Tarceva therapy. Oncol Rep. Mar. 2012;27(3):880-890. EXC3. [pmid: 22134479].
457 Gupta AK, Soto DE, Feldman MD, et al. Signaling pathways in NSCLC as a predictor of outcome and response to therapy. Lung. 2004;182(3):151-162. EXC4. [pmid: 15526754].
458 Gupta S, Ashfaq R, Kapur P, et al. Microsatellite instability among individuals of Hispanic origin with colorectal cancer. Cancer. Nov. 1. 2010;116(21):4965-4972. EXC5. [pmid: 20665498].
459 Gustafsson B, Angelini S, Sander B, et al. Mutations in the BRAF and N-ras genes in childhood acute lymphoblastic leukaemia [11]. Leukemia. 2005;19(2):310-312. EXC3. [pmid: 15538400].
460 Gustafsson SB, Palmqvist R, Henriksson ML, et al. High tumour cannabinoid CB1 receptor immunoreactivity negatively impacts disease-specific survival in stage II microsatellite stable colorectal cancer. PLoS One. 2011;6(8):e23003. EXC4. [pmid: 21901119].
461 Gwin K, Pinto M, Tavassoli FA. Complementary value of the Ki-67 proliferation index to the oncotype DX recurrence score. Int J Surg Pathol. Aug. 2009;17(4):303-310. EXC7. [pmid: 19578051].
462 Ha D, Choi H, Almeida FA, et al. Histologic and molecular characterization of lung cancer with tissue obtained by electromagnetic navigation bronchoscopy. J Bronchology Interv Pulmonol. Jan. 2013;20(1):10-15. EXC6. [pmid: 23328135].
463 Habel L, Quesenberry C, Jacobs M, et al. Gene expression and breast cancer mortality in Northern California Kaiser Permanente patients: a large population-based case control study. Proc Am Soc Clin Oncol. 2005;24:603a. EXC2.
464 Haddad R, Ogilvie RT, Croitoru M, et al. Microsatellite instability as a prognostic factor in resected colorectal cancer liver metastases. Ann Surg Oncol. Nov. 2004;11(11):977-982. EXC5. [pmid: 15525826].
465 Hadziavdic V, Pavlovic-Calic N, Eminovic I. Molecular analysis: microsatellity instability and loss of heterozygosity of tumor suppressor gene in hereditary non-polyposis colorectal cancers (HNPCC). Bosn J Basic Med Sci. Feb. 2009;9(1):10-18. EXC6. [pmid: 19284389].
466 Haibe-Kains B, Desmedt C, Piette F, et al. Comparison of prognostic gene expression signatures for breast cancer. BMC Genomics. 2008;9:394. EXC5. [pmid: 18717985].
467 Hall G, Clarkson A, Shi A, et al. Immunohistochemistry for PMS2 and MSH6 alone can replace a four antibody panel for mismatch repair deficiency screening in colorectal adenocarcinoma. Pathology (Phila). 2010;42(5):409-413. EXC6. [pmid: 20632815].
468 Hall MJ, Manne SL, Winkel G, et al. Effects of a decision support intervention on decisional conflict associated with microsatellite instability testing. Cancer epidemiology, biomarkers & prevention: a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. 2011;(2):249-254. EXC4.
469 Hall PS, McCabe C, Stein RC, et al. Economic evaluation of genomic test-directed chemotherapy for early-stage lymph node-positive breast cancer. J Natl Cancer Inst. Jan. 4. 2012;104(1):56-66. EXC7. [pmid: 22138097].
470 Halling KC, French AJ, McDonnell SK, et al. Microsatellite instability and 8p allelic imbalance in stage B2 and C colorectal cancers. J Natl Cancer Inst. Aug. 4. 1999;91(15):1295-1303. EXC4. [pmid: 10433618].
471 Halling KC, King W, Sokolova IA, et al. A comparison of BTA stat, hemoglobin dipstick, telomerase and Vysis UroVysion assays for the detection of urothelial carcinoma in urine. J Urol. May. 2002;167(5):2001-2006. EXC6. [pmid: 11956427].
472 Halling KC, King W, Sokolova IA, et al. A comparison of cytology and fluorescence in situ hybridization for the detection of urothelial carcinoma. J Urol. Nov. 2000;164(5):1768-1775. EXC6. [pmid: 11025767].
473 Halling KC, Rickman OB, Kipp BR, et al. A comparison of cytology and fluorescence in situ hybridization for the detection of lung cancer in bronchoscopic specimens. Chest. Sep. 2006;130(3):694-701. EXC4. [pmid: 16963665].
474 Hallqvist A, Wagenius G, Rylander H, et al. Concurrent cetuximab and radiotherapy after docetaxel-cisplatin induction chemotherapy in stage III NSCLC: satellite--a phase II study from the Swedish Lung Cancer Study Group. Lung Cancer. Feb. 2011;71(2):166-172. EXC4. [pmid: 20541833].
475 Halvarsson B, Anderson H, Domanska K, et al. Clinicopathologic factors identify sporadic mismatch repair-defective colon cancers. Am J Clin Pathol. Feb. 2008;129(2):238-244. EXC6. [pmid: 18208804].
476 Halvarsson B, Lindblom A, Rambech E, et al. Microsatellite instability analysis and/or immunostaining for the diagnosis of hereditary nonpolyposis colorectal cancer?. Virchows Arch. Feb. 2004;444(2):135-141. EXC5. [pmid: 14652751].
477 Hameed F, Goldberg PA, Hall P, et al. Immunohistochemistry detects mismatch repair gene defects in colorectal cancer. Colorectal Dis. Jun. 2006;8(5):411-417. EXC6. [pmid: 16684085].
478 Hampel H, Frankel W, Panescu J, et al. Screening for Lynch syndrome (hereditary nonpolyposis colorectal cancer) among endometrial cancer patients. Cancer Res. Aug. 1. 2006;66(15):7810-7817. EXC5. [pmid: 16885385].
479 Hampel H, Frankel WL, Martin E, et al. Feasibility of screening for Lynch syndrome among patients with colorectal cancer. J Clin Oncol. Dec. 10. 2008;26(35):5783-5788. EXC4. [pmid: 18809606].
480 Han HS, Lim SN, An JY, et al. Detection of EGFR mutation status in lung adenocarcinoma specimens with different proportions of tumor cells using two methods of differential sensitivity. J Thorac Oncol. Feb. 2012;7(2):355-364. EXC6. [pmid: 22157369].
481 Han SW, Hwang PG, Chung DH, et al. Epidermal growth factor receptor (EGFR) downstream molecules as response predictive markers for gefitinib (Iressa, ZD1839) in chemotherapy-resistant non-small cell lung cancer. Int J Cancer. Jan. 1. 2005;113(1):109-115. EXC6. [pmid: 15386420].
482 Han SW, Kim TY, Hwang PG, et al. Predictive and prognostic impact of epidermal growth factor receptor mutation in non-small-cell lung cancer patients treated with gefitinib. J Clin Oncol. Apr. 10. 2005;23(11):2493-2501. EXC6. [pmid: 15710947].
483 Han SW, Kim TY, Jeon YK, et al. Optimization of patient selection for gefitinib in non-small cell lung cancer by combined analysis of epidermal growth factor receptor mutation, K-ras mutation, and Akt phosphorylation. Clin Cancer Res. Apr. 15. 2006;12(8):2538-2544. EXC6. [pmid: 16638863].
484 Han SW, Kim TY, Lee KH, et al. Clinical predictors versus epidermal growth factor receptor mutation in gefitinib-treated non-small-cell lung cancer patients. Lung Cancer. Nov. 2006;54(2):201-207. EXC6. [pmid: 16956694].
485 Han SW, Lee HJ, Bae JM, et al. Methylation and microsatellite status and recurrence following adjuvant FOLFOX in colorectal cancer. Int J Cancer. May. 1. 2013;132(9):2209-2216. EXC3. [pmid: 23034738].
486 Han Y, Xu JM, Duan HQ, et al. Epidermal growth factor receptor mutations, HER2/3 protein expressions and clinical outcome in the chinese patients with advanced nonsmall cell lung cancer treated with gefitinib. Chinese Journal of Cancer. 2010;29(1):64-70. EXC3.
487 Haneda H, Sasaki H, Lindeman N, et al. A correlation between EGFR gene mutation status and bronchioloalveolar carcinoma features in Japanese patients with adenocarcinoma. Jpn J Clin Oncol. Feb. 2006;36(2):69-75. EXC6. [pmid: 16449241].
488 Haneda H, Sasaki H, Shimizu S, et al. Epidermal growth factor receptor gene mutation defines distinct subsets among small adenocarcinomas of the lung. Lung Cancer. Apr. 2006;52(1):47-52. EXC6. [pmid: 16503085].
489 Hanna N, Lilenbaum R, Ansari R, et al. Phase II trial of cetuximab in patients with previously treated non-small-cell lung cancer. J Clin Oncol. Nov. 20. 2006;24(33):5253-5258. EXC6. [pmid: 17114658].
490 Hannouf MB, Xie B, Brackstone M, et al. Cost-effectiveness of a 21-gene recurrence score assay versus Canadian clinical practice in women with early-stage estrogen- or progesterone-receptor-positive, axillary lymph-node negative breast cancer. BMC Cancer. 2012;12:447. EXC7. [pmid: 23031196].
491 Harle A, Busser B, Rouyer M, et al. Comparison of COBAS 4800 KRAS, TaqMan PCR and high resolution melting PCR assays for the detection of KRAS somatic mutations in formalin-fixed paraffin embedded colorectal carcinomas. Virchows Arch. Mar. 2013;462(3):329-335. EXC3. [pmid: 23400679].
492 Harrell FE, Lee KL, Mark DB. Tutorial in Biostatistics. Multivariable prognostic models: Issues in developing models, evaluating assumptions and adequacy, and measuring and reducing errors. Stat Med. 1996;15:361-387. EXC2. [pmid: 8668867].
493 Harris L, Fritsche H, Mennel R, et al. American Society of Clinical Oncology 2007 update of recommendations for the use of tumor markers in breast cancer. J Clin Oncol. Nov. 20. 2007;25(33):5287-5312. EXC7. [pmid: 17954709].
494 Hartmann S, Gerber B, Elling D, et al. The 70-gene signature as prognostic factor for elderly women with hormone receptor-positive, HER2-negative breast cancer. Breast Care. 2012;7(1):19-24. EXC5. [pmid: 22553468].
495 Hassett MJ, O'Malley AJ, Pakes JR, et al. Frequency and cost of chemotherapy-related serious adverse effects in a population sample of women with breast cancer. J Natl Cancer Inst. Aug. 16. 2006;98(16):1108-1117. EXC6. [pmid: 16912263].
496 Hassett MJ, Silver SM, Hughes ME, et al. Adoption of gene expression profile testing and association with use of chemotherapy among women with breast cancer. J Clin Oncol. Jun. 20. 2012;30(18):2218-2226. Exc-6. [pmid: 22585699].
497 Hata A, Yoshioka H, Fujita S, et al. Complex mutations in the epidermal growth factor receptor gene in non-small cell lung cancer. J Thorac Oncol. Oct. 2010;5(10):1524-1528. EXC6. [pmid: 20808254].
498 Hatch SB, Lightfoot HM Jr, Garwacki CP, et al. Microsatellite instability testing in colorectal carcinoma: choice of markers affects sensitivity of detection of mismatch repair-deficient tumors. Clin Cancer Res. Mar. 15. 2005;11(6):2180-2187. EXC5. [pmid: 15788665].
499 Hawkins NJ, Tomlinson I, Meagher A, et al. Microsatellite-stable diploid carcinoma: a biologically distinct and aggressive subset of sporadic colorectal cancer. Br J Cancer. Jan. 2001;84(2):232-236. EXC7. [pmid: 11161382].
500 Hawkins NJ, Ward RL. Sporadic colorectal cancers with microsatellite instability and their possible origin in hyperplastic polyps and serrated adenomas. J Natl Cancer Inst. Sep. 5. 2001;93(17):1307-1313. EXC6. [pmid: 11535705].
501 Hayashi H, Okamoto I, Kimura H, et al. Clinical outcomes of thoracic radiotherapy for locally advanced NSCLC with EGFR mutations or EML4-ALK rearrangement. Anticancer Res. Oct. 2012;32(10):4533-4537. EXC3. [pmid: 23060582].
502 Hayes, Inc. Ancillary UroVysion fluorescence in situ hybridization (FISH) testing for bladder cancer screening and detection (Structured abstract). Health Technology Assessment Database. 2008;(3). EXC2.
503 Hayes, Inc. KRAS sequence variant analysis for non-small cell lung cancer (NSCLC) (Structured abstract). Health Technology Assessment Database. 2008;(3). EXC2.
504 Hayes, Inc. Oncotype DX for prognosis of breast cancer recurrence (Structured abstract). Health Technology Assessment Database. 2010;(3). EXC2.
505 Hayes, Inc. MammaPrint for prognosis of breast cancer recurrence (Structured abstract). Health Technology Assessment Database. 2011;(3). EXC2.
506 Hayes, Inc. VeriStrat® Test to predict response to Epidermal Growth Factor Receptor (EGFR) Tyrosine Kinase Inhibitors (TKIs) in Non-Small Cell Lung Cancer (NSCLC) (Structured abstract). Health Technology Assessment Database. 2012;(3). EXC2.
507 Hayes, Inc. Epidermal Growth Factor Receptor (EGFR) sequence variant analysis for predicting response to Non-Small Cell Lung Cancer (NSCLC) drug therapy (Structured abstract). Health Technology Assessment Database. 2012;(3). EXC2.
508 Hayes, Inc. Ki-67 (MKI67) proliferation marker testing in ductal carcinoma in situ (DCIS) and breast cancer (Structured abstract). Health Technology Assessment Database. 2012;(4). EXC9.
509 Hayes, Inc. Anaplastic lymphoma kinase (ALK) gene rearrangement testing in non-small cell lung cancer (NSCLC) (Structured abstract). Health Technology Assessment Database. 2012;(4). EXC9.
510 Hayes, Inc. KRAS sequence variant analysis for predicting response to epidermal growth factor receptor (EGFR) tyrosine kinase inhibitors (TKIs) in the treatment of non-small cell lung cancer (NSCLC) (Structured abstract). Health Technology Assessment Database. 2012;(4). EXC9.
511 Hayes I. KRAS sequence variant analysis for predicting response to colorectal cancer drug therapy (Structured abstract). Health Technology Assessment Database. 2008;(3). EXC2.
512 Hayes I. BRAF p.Val600Glu (V600E) testing for assessment of treatment options in metastatic colorectal cancer (Structured abstract). Health Technology Assessment Database. 2010;(3). EXC2.
513 Hayes I. Neuroblastoma RAS Viral Oncogene (NRAS) testing to predict treatment response in colorectal cancer (Structured abstract). Health Technology Assessment Database. 2012;(3). EXC2.
514 He C, Liu M, Zhou C, et al. Detection of epidermal growth factor receptor mutations in plasma by mutant-enriched PCR assay for prediction of the response to gefitinib in patients with non-small-cell lung cancer. Int J Cancer. Nov. 15. 2009;125(10):2393-2399. EXC4. [pmid: 19530244].
515 He M, Capelletti M, Nafa K, et al. EGFR exon 19 insertions: a new family of sensitizing EGFR mutations in lung adenocarcinoma. Clin Cancer Res. Mar. 15. 2012;18(6):1790-1797. EXC6. [pmid: 22190593].
516 He Y, Van't Veer LJ, Mikolajewska-Hanclich I, et al. PIK3CA mutations predict local recurrences in rectal cancer patients. Clin Cancer Res. Nov. 15. 2009;15(22):6956-6962. EXC6. [pmid: 19903786].
517 Hecht JR, Mitchell E, Chidiac T, et al. A randomized phase IIIB trial of chemotherapy, bevacizumab, and panitumumab compared with chemotherapy and bevacizumab alone for metastatic colorectal cancer. J Clin Oncol. Feb. 10. 2009;27(5):672-680. EXC3. [pmid: 19114685].
518 Hecht JR, Mitchell E, Neubauer MA, et al. Lack of correlation between epidermal growth factor receptor status and response to Panitumumab monotherapy in metastatic colorectal cancer. Clin Cancer Res. Apr. 1. 2010;16(7):2205-2213. EXC5. [pmid: 20332321].
519 Hellebrekers DM, Lentjes MH, van den Bosch SM, et al. GATA4 and GATA5 are potential tumor suppressors and biomarkers in colorectal cancer. Clin Cancer Res. Jun. 15. 2009;15(12):3990-3997. EXC5. [pmid: 19509152].
520 Hemminki A, Mecklin JP, Jarvinen H, et al. Microsatellite instability is a favorable prognostic indicator in patients with colorectal cancer receiving chemotherapy. Gastroenterology. 2000;119(4):921-928. EXC8. [pmid: 11040179].
521 Hendriks Y, Franken P, Dierssen JW, et al. Conventional and tissue microarray immunohistochemical expression analysis of mismatch repair in hereditary colorectal tumors. Am J Pathol. 2003;162(2):469-477. EXC3. [pmid: 12547705].
522 Hendriks YM, Wagner A, Morreau H, et al. Cancer risk in hereditary nonpolyposis colorectal cancer due to MSH6 mutations: impact on counseling and surveillance. Gastroenterology. Jul. 2004;127(1):17-25. EXC6. [pmid: 15236168].
523 Heon S, Yeap BY, Britt GJ, et al. Development of central nervous system metastases in patients with advanced non-small cell lung cancer and somatic EGFR mutations treated with gefitinib or erlotinib. Clin Cancer Res. Dec. 1. 2010;16(23):5873-5882. EXC6. [pmid: 21030498].
524 Heon S, Yeap BY, Lindeman NI, et al. The impact of initial gefitinib or erlotinib versus chemotherapy on central nervous system progression in advanced non-small cell lung cancer with EGFR mutations. Clin Cancer Res. 2012;18(16):4406-4414. EXC5. [pmid: 22733536].
525 Herbst RS, Kelly K, Chansky K, et al. Phase II selection design trial of concurrent chemotherapy and cetuximab versus chemotherapy followed by cetuximab in advanced-stage non-small-cell lung cancer: Southwest Oncology Group study S0342. J Clin Oncol. Nov. 1. 2010;28(31):4747-4754. EXC6. [pmid: 20921467].
526 Herbst RS, Maddox AM, Rothenberg ML, et al. Selective oral epidermal growth factor receptor tyrosine kinase inhibitor ZD1839 is generally well-tolerated and has activity in non-small-cell lung cancer and other solid tumors: results of a phase I trial. J Clin Oncol. Sep. 15. 2002;20(18):3815-3825. EXC4. [pmid: 12228201].
527 Herbst RS, Prager D, Hermann R, et al. TRIBUTE: a phase III trial of erlotinib hydrochloride (OSI-774) combined with carboplatin and paclitaxel chemotherapy in advanced non-small-cell lung cancer. J Clin Oncol. Sep. 1. 2005;23(25):5892-5899. EXC6. [pmid: 16043829].
528 Hijiya N, Miyawaki M, Kawahara K, et al. Phosphorylation status of epidermal growth factor receptor is closely associated with responsiveness to gefitinib in pulmonary adenocarcinoma. Hum Pathol. Mar. 2008;39(3):316-323. EXC6. [pmid: 18261621].
529 Hirsch FR, Dziadziuszko R, Thatcher N, et al. Epidermal growth factor receptor immunohistochemistry: comparison of antibodies and cutoff points to predict benefit from gefitinib in a phase 3 placebo-controlled study in advanced nonsmall-cell lung cancer. Cancer. 2008;(5):1114-1121. EXC4. [pmid: 18219661].
530 Hirsch FR, Herbst RS, Olsen C, et al. Increased EGFR gene copy number detected by fluorescent in situ hybridization predicts outcome in non-small-cell lung cancer patients treated with cetuximab and chemotherapy. J Clin Oncol. Jul. 10. 2008;26(20):3351-3357. EXC4. [pmid: 18612151].
531 Hirsch FR, Varella-Garcia M, Bunn PA Jr, et al. Molecular predictors of outcome with gefitinib in a phase III placebo-controlled study in advanced non-small-cell lung cancer. J Clin Oncol. Nov. 1. 2006;24(31):5034-5042. EXC6. [pmid: 17075123].
532 Hirsch FR, Varella-Garcia M, Dziadziuszko R, et al. Fluorescence in situ hybridization subgroup analysis of TRIBUTE, a phase III trial of erlotinib plus carboplatin and paclitaxel in non-small cell lung cancer. Clin Cancer Res. Oct. 1. 2008;14(19):6317-6323. EXC4. [pmid: 18829515].
533 Hirsch FR, Varella-Garcia M, McCoy J, et al. Increased epidermal growth factor receptor gene copy number detected by fluorescence in situ hybridization associates with increased sensitivity to gefitinib in patients with bronchioloalveolar carcinoma subtypes: a Southwest Oncology Group Study. J Clin Oncol. Oct. 1. 2005;23(28):6838-6845. EXC4. [pmid: 15998906].
534 Ho JW, Yuen ST, Chung LP, et al. Distinct clinical features associated with microsatellite instability in colorectal cancers of young patients. Int J Cancer. Jul. 20. 2000;89(4):356-360. EXC6. [pmid: 10956410].
535 Hochstein N, Honsel D, Kappmeier C, et al. Pyrosequencing and its applications. QIAGEN. Hilden, Germany. EXC2.
536 Hoedema R, Monroe T, Bos C, et al. testing for hereditary nonpolyposis colorectal cancer. Am Surg. May. 2003;69(5):387-391. discussion 91-2. EXC6. [pmid: 12769209].
537 Holdhoff M, Schmidt K, Diehl F, et al. Detection of tumor DNA at the margins of colorectal cancer liver metastasis. Clin Cancer Res. Jun. 1. 2011;17(11):3551-3557. EXC6. [pmid: 21531819].
538 Holdhoff M, Schmidt K, Donehower R, et al. Analysis of circulating tumor DNA to confirm somatic KRAS mutations. J Natl Cancer Inst. Sep. 16. 2009;101(18):1284-1285. EXC2. [pmid: 19641175].
539 Hollebecque A, Levy A, Broutin S, et al. First case report of intrathecal panitumumab for treatment of meningeal carcinomatousis in an EGFR mutant lung adenocarcinoma patient. Lung Cancer. Apr. 2013;80(1):113-114. EXC7. [pmid: 23352031].
540 Cost-effectiveness evaluation of the Oncotype DX® breast cancer assay in clinical practice in the U.K. San Antonio Breast Cancer Symposium. 2011. December. San Antonio, TX. EXC6.
541 Hong T, Zhang R, Cai D, et al. Second-line epidermal growth factor receptor inhibitors followed by third-line pemetrexed or the reverse sequence: a retrospective analysis of 83 Chinese patients with advanced lung adenocarcinoma. J Cancer Res Clin Oncol. Feb. 2012;138(2):285-291. EXC4. [pmid: 22116317].
542 Hoogerbrugge N, Willems R, Van Krieken HJ, et al. Very low incidence of microsatellite instability in rectal cancers from families at risk for HNPCC. Clin Genet. Jan. 2003;63(1):64-70. EXC6. [pmid: 12519374].
543 Ho-Pun-Cheung A, Assenat E, Bascoul-Mollevi C, et al. EGFR and HER3 mRNA expression levels predict distant metastases in locally advanced rectal cancer. Int J Cancer. Jun. 15. 2011;128(12):2938-2946. EXC4. [pmid: 20824716].
544 Hoque MO, Brait M, Rosenbaum E, et al. Genetic and epigenetic analysis of erbB signaling pathway genes in lung cancer. J Thorac Oncol. Dec. 2010;5(12):1887-1893. EXC6. [pmid: 21102258].
545 Horiike A, Kimura H, Nishio K, et al. Detection of epidermal growth factor receptor mutation in transbronchial needle aspirates of non-small cell lung cancer. Chest. Jun. 2007;131(6):1628-1634. EXC5. [pmid: 17565015].
546 Hornberger J, Chien R, Krebs K, et al. US insurance program's experience with a multigene assay for early-stage breast cancer (Structured abstract). Journal of Oncology Practice. 2011;(3 Supplement):e38s-e45s. EXC5. [pmid: 21886510].
547 Hornberger J, Chien R, Krebs K, et al. US insurance program's experience with a multigene assay for early-stage breast cancer. Am J Manag Care. May. 2011;17(5 Spec No):e194-e202. EXC6. [pmid: 21711071].
548 Hornberger J, Lyman GH, Chien R. Economic implications of 21-gene recurrence score assay: US multicenter experience. J Clin Oncol. Aug. 1. 2010;28(22):e382. author reply e3. EXC2. [pmid: 20498396].
549 Horndler C, Gallego R, Garcia-Albeniz X, et al. Co-expression of matrix metalloproteinase-7 (MMP-7) and phosphorylated insulin growth factor receptor I (pIGF-1R) correlates with poor prognosis in patients with wild-type KRAS treated with cetuximab or panitumumab: a GEMCAD study. Cancer Biol Ther. Jan. 15. 2011;11(2):177-183. EXC4. [pmid: 21099348].
550 Horstmann M, Patschan O, Hennenlotter J, et al. Combinations of urine-based tumour markers in bladder cancer surveillance. Scand J Urol Nephrol. 2009;43(6):461-466. EXC6. [pmid: 19903092].
551 Hoshi K, Takakura H, Mitani Y, et al. Rapid detection of epidermal growth factor receptor mutations in lung cancer by the SMart-Amplification Process. Clin Cancer Res. Sep. 1. 2007;13(17):4974-4983. EXC4. [pmid: 17785547].
552 Hosokawa S, Toyooka S, Fujiwara Y, et al. Comprehensive analysis of EGFR signaling pathways in Japanese patients with non-small cell lung cancer. Lung Cancer. Oct. 2009;66(1):107-113. EXC6. [pmid: 19185949].
553 Hotta K, Kiura K, Toyooka S, et al. Clinical significance of epidermal growth factor receptor gene mutations on treatment outcome after first-line cytotoxic chemotherapy in Japanese patients with non-small cell lung cancer. J Thorac Oncol. Jul. 2007;2(7):632-637. EXC6. [pmid: 17607119].
554 Hou MM, Huang SF, Kuo HP, et al. Erlotinib treatment in patients with advanced lung adenocarcinoma with CISH-positive and CISH-negative EGFR gene alterations. Anticancer Res. Mar. 2012;32(3):1107-1112. EXC4. [pmid: 22399641].
555 Houskova L, Zemanova Z, Babjuk M, et al. Molecular cytogenetic characterization and diagnostics of bladder cancer. Neoplasma. 2007;54(6):511-516. EXC6. [pmid: 17949235].
556 Howlader N, Noone AM, Krapcho M, et al., editors. SEER Cancer Statistics Review, 1975–2009 (Vintage 2009 Populations). Bethesda, MD. National Cancer Institute. 2012. EXC2.
557 Hsieh RK, Lim KH, Kuo HT, et al. Female sex and bronchioloalveolar pathologic subtype predict EGFR mutations in non-small cell lung cancer. Chest. Jul. 2005;128(1):317-321. EXC6. [pmid: 16002952].
558 Hu C, Liu X, Chen Y, et al. Direct serum and tissue assay for EGFR mutation in non-small cell lung cancer by high-resolution melting analysis. Oncol Rep. 2012;28(5):1815-1821. EXC4. [pmid: 22923193].
559 Hu P, Lee CW, Xu JP, et al. Microsatellite instability in saliva from patients with hereditary non-polyposis colon cancer and siblings carrying germline mismatch repair gene mutations. Ann Clin Lab Sci. Fall. 2011;41(4):321-330. EXC6. [pmid: 22166501].
560 Huang CT, Yen RF, Cheng MF, et al. Correlation of F-18 fluorodeoxyglucose-positron emission tomography maximal standardized uptake value and EGFR mutations in advanced lung adenocarcinoma. Med Oncol. Mar. 2010;27(1):9-15. EXC6. [pmid: 19130320].
561 Huang J, Morehouse C, Streicher K, et al. Altered expression of Insulin receptor isoforms in breast cancer. PLoS One. 2011;6(10). EXC4.
562 Huang SF, Liu HP, Li LH, et al. High frequency of epidermal growth factor receptor mutations with complex patterns in non-small cell lung cancers related to gefitinib responsiveness in Taiwan. Clin Cancer Res. Dec. 15. 2004;10(24):8195-8203. EXC6. [pmid: 15623594].
563 Huang Z, Wang Z, Bai H, et al. The detection of EGFR mutation status in plasma is reproducible and can dynamically predict the efficacy of EGFR-TKI. Thoracic Cancer. November. 2012;3(4):334-340. FULL TEXT LINK http://dx.doi.org/10.1111/j.1759-7714.2012.00133.x. EXC6.
564 Hubner RA, Lubbe S, Chandler I, et al. MTHFR C677T has differential influence on risk of MSI and MSS colorectal cancer. Hum Mol Genet. 2007;16(9):1072-1077. EXC4. [pmid: 17350979].
565 Huh JW, Park YS, Lee JH, et al. CD133 mRNA expression and microsatellite instability in colorectal carcinoma. J Surg Oncol. Dec. 1. 2010;102(7):765-770. EXC4. [pmid: 20872808].
566 Hu-Lieskovan S, Vallbohmer D, Zhang W, et al. EGF61 polymorphism predicts complete pathologic response to cetuximab-based chemoradiation independent of KRAS status in locally advanced rectal cancer patients. Clin Cancer Res. Aug. 1. 2011;17(15):5161-5169. EXC4. [pmid: 21673069].
567 Hunt JD, Strimas A, Martin JE, et al. Differences in KRAS mutation spectrum in lung cancer cases between African Americans and Caucasians after occupational or environmental exposure to known carcinogens. Cancer Epidemiol Biomarkers Prev. Nov. 2002;11(11):1405-1412. EXC6. [pmid: 12433719].
568 Hutchins G, Southward K, Handley K, et al. Value of mismatch repair, KRAS, and BRAF mutations in predicting recurrence and benefits from chemotherapy in colorectal cancer. J Clin Oncol. 2011;(10):1261-1270. EXC6. [pmid: 21383284].
569 Huysentruyt CJ, Baldewijns MM, Ruland AM, et al. Modified UroVysion scoring criteria increase the urothelial carcinoma detection rate in cases of equivocal urinary cytology. Histopathology. Jun. 2011;58(7):1048-1053. EXC6. [pmid: 21707706].
570 Hyde A, Fontaine D, Stuckless S, et al. A histology-based model for predicting microsatellite instability in colorectal cancers. Am J Surg Pathol. Dec. 2010;34(12):1820-1829. EXC6. [pmid: 21107088].
571 Ichihara S, Toyooka S, Fujiwara Y, et al. The impact of epidermal growth factor receptor gene status on gefitinib-treated Japanese patients with non-small-cell lung cancer. Int J Cancer. Mar. 15. 2007;120(6):1239-1247. EXC6. [pmid: 17192902].
572 Ide T, Kitajima Y, Ohtaka K, et al. Expression of the hMLH1 gene is a possible predictor for the clinical response to 5-fluorouracil after a surgical resection in colorectal cancer. Oncol Rep. Jun. 2008;19(6):1571-1576. EXC4. [pmid: 18497967].
573 Iglesias D, Fernandez-Peralta AM, Nejda N, et al. RIS1, a gene with trinucleotide repeats, is a target in the mutator pathway of colorectal carcinogenesis. Cancer Genet Cytogenet. Jun. 2006;167(2):138-144. EXC4. [pmid: 16737913].
574 Iida S, Kato S, Ishiguro M, et al. PIK3CA mutation and methylation influences the outcome of colorectal cancer. Oncology Letters. 2012;3(3):565-570. EXC4. [pmid: 22740953].
575 Ikeda K, Nomori H, Ohba Y, et al. Epidermal growth factor receptor mutations in multicentric lung adenocarcinomas and atypical adenomatous hyperplasias. J Thorac Oncol. May. 2008;3(5):467-471. EXC6. [pmid: 18448997].
576 Ikeda S, Takabe K, Inagaki M, et al. Detection of gene point mutation in paraffin sections using in situ loop-mediated isothermal amplification. Pathol Int. Sep. 2007;57(9):594-599. EXC4. [pmid: 17685931].
577 Ilie M, Long E, Hofman V, et al. Diagnostic value of immunohistochemistry for the detection of the BRAFV600E mutation in primary lung adenocarcinoma Caucasian patients. Ann Oncol. Mar. 2013;24(3):742-748. EXC4. [pmid: 23131393].
578 Ilie MI, Hofman V, Bonnetaud C, et al. Usefulness of tissue microarrays for assessment of protein expression, gene copy number and mutational status of EGFR in lung adenocarcinoma. Virchows Arch. Oct. 2010;457(4):483-495. EXC4. [pmid: 20803030].
579 Imielinski M, Berger AH, Hammerman PS, et al. Mapping the hallmarks of lung adenocarcinoma with massively parallel sequencing. Cell. Sep. 14. 2012;150(6):1107-1120. EXC6. [pmid: 22980975].
580 Inamura K, Togashi Y, Nomura K, et al. Up-regulation of PTEN at the transcriptional level is an adverse prognostic factor in female lung adenocarcinomas. Lung Cancer. 2007;57(2):201-206. EXC6. [pmid: 17452061].
581 Iniesta P, de Juan C, Caldes T, et al. Genetic abnormalities and microsatellite instability in colorectal cancer. Cancer Detect Prev. 1998;22(5):383-395. EXC5. [pmid: 9727619].
582 Inno A, Di Salvatore M, Cenci T, et al. Is there a role for IGF1R and c-MET pathways in resistance to cetuximab in metastatic colorectal cancer?. Clinical Colorectal Cancer. 2011;10(4):325-332. EXC3. [pmid: 21729677].
583 Inoue A, Suzuki T, Fukuhara T, et al. Prospective phase II study of gefitinib for chemotherapy-naive patients with advanced non-small-cell lung cancer with epidermal growth factor receptor gene mutations. J Clin Oncol. Jul. 20. 2006;24(21):3340-3346. EXC6. [pmid: 16785471].
584 Inoue Y, Saigusa S, Iwata T, et al. The prognostic value of KRAS mutations in patients with colorectal cancer. Oncol Rep. 2012;28(5):1579-1584. EXC5. [pmid: 22922794].
585 Iranzo V, Sirera R, Carrato A, et al. Phase II clinical trial with gemcitabine and paclitaxel sequential monotherapy as first-line treatment for advanced non-small-cell lung cancer (SLCG 01-04). Clin Transl Oncol. Jun. 2011;13(6):411-418. EXC4. [pmid: 21680302].
586 Irisa K, Masago K, Togashi Y, et al. Significance of pretreatment comorbidities in elderly patients with advanced non-small-cell lung cancer treated with chemotherapy or epidermal growth factor receptor-tyrosine kinase inhibitor. Med Oncol. Mar. 2012;29(1):185-192. EXC4. [pmid: 21136210].
587 Ishii T, Notohara K, Umapathy A, et al. Tubular adenomas with minor villous changes show molecular features characteristic of tubulovillous adenomas. Am J Surg Pathol. Feb. 2011;35(2):212-220. EXC4. [pmid: 21263241].
588 Ishitobi M, Goranova TE, Komoike Y, et al. Clinical utility of the 70-gene MammaPrint profile in a Japanese population. Jpn J Clin Oncol. Jun. 2010;40(6):508-512. EXC7. [pmid: 20110242].
589 Italiano A, Cortot AB, Ilie M, et al. EGFR and KRAS status of primary sarcomatoid carcinomas of the lung: Implications for anti-EGFR treatment of a rare lung malignancy. Int J Cancer. 2009;125(10):2479-2482. EXC6. [pmid: 19681124].
590 Italiano A, Vandenbos FB, Otto J, et al. Comparison of the epidermal growth factor receptor gene and protein in primary non-small-cell-lung cancer and metastatic sites: implications for treatment with EGFR-inhibitors. Ann Oncol. Jun. 2006;17(6):981-985. EXC4. [pmid: 16524970].
591 Iwata T, Sugio K, Uramoto H, et al. Detection of EGFR and K-ras mutations for diagnosis of multiple lung adenocarcinomas. Front Biosci. 2011;16:2961-2969. EXC5. [pmid: 21622214].
592 Jackman DM, Miller VA, Cioffredi LA, et al. Impact of epidermal growth factor receptor and KRAS mutations on clinical outcomes in previously untreated non-small cell lung cancer patients: results of an online tumor registry of clinical trials. Clin Cancer Res. Aug. 15. 2009;15(16):5267-5273. EXC6. [pmid: 19671843].
593 Jackman DM, Yeap BY, Sequist LV, et al. Exon 19 deletion mutations of epidermal growth factor receptor are associated with prolonged survival in non-small cell lung cancer patients treated with gefitinib or erlotinib. Clin Cancer Res. Jul. 1. 2006;12(13):3908-3914. EXC6. [pmid: 16818686].
594 Jacot W, Pujol JL, Boher JM, et al. Serum EGF-receptor and HER-2 extracellular domains and prognosis of non-small-cell lung cancer. Br J Cancer. Aug. 2. 2004;91(3):430-433. EXC4. [pmid: 15226769].
595 Janjigian YY, Park BJ, Zakowski MF, et al. Impact on disease-free survival of adjuvant erlotinib or gefitinib in patients with resected lung adenocarcinomas that harbor EGFR mutations. J Thorac Oncol. Mar. 2011;6(3):569-575. EXC6. [pmid: 21150674].
596 Janku F, Wheler JJ, Naing A, et al. PIK3CA mutations in advanced cancers: Characteristics and outcomes. Oncotarget. December. 2012;3(12):1566-1575. MEDLINE PMID 23248156 (http://www.ncbi.nlm.nih.gov/pubmed/23248156). EXC3. [pmid: 23248156].
597 Janne PA, Gurubhagavatula S, Yeap BY, et al. Outcomes of patients with advanced non-small cell lung cancer treated with gefitinib (ZD1839,"Iressa") on an expanded access study. Lung Cancer. May. 2004;44(2):221-230. EXC6. [pmid: 15084387].
598 Janne PA, Wang X, Socinski MA, et al. Randomized phase II trial of erlotinib alone or with carboplatin and paclitaxel in patients who were never or light former smokers with advanced lung adenocarcinoma: CALGB 30406 trial. J Clin Oncol. Jun. 10. 2012;30(17):2063-2069. EXC6. [pmid: 22547605].
599 Jantus-Lewintre E, Sirera R, Cabrera A, et al. Analysis of the prognostic value of soluble epidermal growth factor receptor plasma concentration in advanced non-small-cell lung cancer patients. Clin Lung Cancer. Sep. 2011;12(5):320-327. EXC4. [pmid: 21729651].
600 Jass JR, Pokos V, Arnold JL, et al. Colorectal neoplasms detected colonoscopically in at-risk members of colorectal cancer families stratified by the demonstration of DNA microsatellite instability. J Mol Med (Berl). Sep. 1996;74(9):547-551. EXC4. [pmid: 8892060].
601 Jemal A, Center MM, DeSantis C, et al. Global patterns of cancer incidence and mortality rates and trends. Cancer Epidemiol Biomarkers Prev. Aug. 2010;19(8):1893-1907. EXC4. [pmid: 20647400].
602 Jenkins MA, Hayashi S, O'Shea AM, et al. Pathology features in Bethesda guidelines predict colorectal cancer microsatellite instability: a population-based study. Gastroenterology. Jul. 2007;133(1):48-56. EXC4. [pmid: 17631130].
603 Jensen AD, Munter MW, Bischoff H, et al. Treatment of non-small cell lung cancer with intensity-modulated radiation therapy in combination with cetuximab: the NEAR protocol (NCT00115518). BMC Cancer. 2006;6:122. EXC6. [pmid: 16681848].
604 Jensen LH, Dysager L, Lindebjerg J, et al. Molecular biology from bench-to-bedside - which colorectal cancer patients should be referred for genetic counselling and risk assessment. Eur J Cancer. Jul. 2010;46(10):1823-1828. EXC6. [pmid: 20417091].
605 Jensen LH, Kuramochi H, Cruger DG, et al. Gene expression of the mismatch repair gene MSH2 in primary colorectal cancer. Tumour Biol. Oct. 2011;32(5):977-983. EXC6. [pmid: 21732224].
606 Jensen LH, Lindebjerg J, Byriel L, et al. Strategy in clinical practice for classification of unselected colorectal tumours based on mismatch repair deficiency. Colorectal Dis. Jun. 2008;10(5):490-497. EXC6. [pmid: 17868408].
607 Jeon CH, Lee HI, Shin IH, et al. Genetic alterations of APC, K-ras, p53, MSI, and MAGE in Korean colorectal cancer patients. Int J Colorectal Dis. Jan. 2008;23(1):29-35. EXC5. [pmid: 17704924].
608 Jeong SY, Shin KH, Shin JH, et al. Microsatellite instability and mutations in DNA mismatch repair genes in sporadic colorectal cancers. Dis Colon Rectum. Aug. 2003;46(8):1069-1077. EXC4. [pmid: 12907901].
609 Jia XL, Chen G. EGFR and KRAS mutations in Chinese patients with adenosquamous carcinoma of the lung. Lung Cancer. 2011;74(3):396-400. EXC6. [pmid: 21592614].
610 Jian G, Songwen Z, Ling Z, et al. Prediction of epidermal growth factor receptor mutations in the plasma/pleural effusion to efficacy of gefitinib treatment in advanced non-small cell lung cancer. J Cancer Res Clin Oncol. Sep. 2010;136(9):1341-1347. EXC4. [pmid: 20155428].
611 Jiang X, Liu Y, Chen C, et al. The value of biomarkers in patients with sarcomatoid carcinoma of the lung: molecular analysis of 33 cases. Clin Lung Cancer. Jul. 2012;13(4):288-296. EXC6. [pmid: 22169481].
612 Jin P, Meng XM, Sheng JQ, et al. Clinicopathological features of non-familial colorectal cancer with high-frequency microsatellite instability. Chin Med Sci J. 2010;25(4):228-232. EXC6. [pmid: 21232183].
613 Jin Y, Li JP, Tang LY, et al. Protein expression and significance of VEGF, EGFR and MMP-9 in non-small cell lung carcinomas. Asian Pac J Cancer Prev. 2011;12(6):1473-1476. EXC4. [pmid: 22126484].
614 Joerger M, deJong D, Burylo A, et al. Tubulin, BRCA1, ERCC1, Abraxas, RAP80 mRNA expression, p53/p21 immunohistochemistry and clinical outcome in patients with advanced non small-cell lung cancer receiving first-line platinum-gemcitabine chemotherapy. Lung Cancer. Nov. 2011;74(2):310-317. EXC4. [pmid: 21529986].
615 John T, Kohler D, Pintilie M, et al. The ability to form primary tumor xenografts is predictive of increased risk of disease recurrence in early-stage non-small cell lung cancer. Clin Cancer Res. Jan. 1. 2011;17(1):134-141. EXC6. [pmid: 21081655].
616 Johnson FM, Bekele BN, Feng L, et al. Phase II study of dasatinib in patients with advanced non-small-cell lung cancer. J Clin Oncol. Oct. 20. 2010;28(30):4609-4615. EXC6. [pmid: 20855820].
617 Johnson ML, Riely GJ, Rizvi NA, et al. Phase II trial of dasatinib for patients with acquired resistance to treatment with the epidermal growth factor receptor tyrosine kinase inhibitors erlotinib or gefitinib. J Thorac Oncol. Jun. 2011;6(6):1128-1131. EXC6. [pmid: 21623279].
618 Johnson ML, Sima CS, Chaft J, et al. Association of KRAS and EGFR mutations with survival in patients with advanced lung adenocarcinomas. Cancer. Jan. 15. 2013;119(2):356-362. EXC3. [pmid: 22810899].
619 Johnson V, Lipton LR, Cummings C, et al. Analysis of somatic molecular changes, clinicopathological features, family history, and germline mutations in colorectal cancer families: evidence for efficient diagnosis of HNPCC and for the existence of distinct groups of non-HNPCC families. J Med Genet. Oct. 2005;42(10):756-762. EXC6. [pmid: 15788729].
620 Jones JS. DNA-based molecular cytology for bladder cancer surveillance. Urology. Mar. 2006;67(3 Suppl 1):35-45. discussion-7. EXC6. [pmid: 16530074].
621 Jones TD, Zhang S, Lopez-Beltran A, et al. Urothelial carcinoma with an inverted growth pattern can be distinguished from inverted papilloma by fluorescence in situ hybridization, immunohistochemistry, and morphologic analysis. Am J Surg Pathol. Dec. 2007;31(12):1861-1867. EXC5. [pmid: 18043040].
622 Jonsson M, Ekstrand A, Edekling T, et al. Experiences from treatment-predictive KRAS testing: High mutation frequency in rectal cancers from females and concurrent mutations in the same tumor. BMC Clinical Pathology. 2009;9(1). EXC6.
623 Jou YS, Lo YL, Hsiao CF, et al. Association of an EGFR intron 1 SNP with never-smoking female lung adenocarcinoma patients. Lung Cancer. Jun. 2009;64(3):251-256. EXC6. [pmid: 19026460].
624 Jover R, Paya A, Alenda C, et al. Defective mismatch-repair colorectal cancer: clinicopathologic characteristics and usefulness of immunohistochemical analysis for diagnosis. Am J Clin Pathol. Sep. 2004;122(3):389-394. EXC4. [pmid: 15362369].
625 Jover R, Zapater P, Castells A, et al. The efficacy of adjuvant chemotherapy with 5-fluorouracil in colorectal cancer depends on the mismatch repair status. Eur J Cancer. Feb. 2009;45(3):365-373. EXC4. [pmid: 18722765].
626 Jover R, Zapater P, Castells A, et al. Mismatch repair status in the prediction of benefit from adjuvant fluorouracil chemotherapy in colorectal cancer. Gut. 2006;55(6):848-855. EXC6. [pmid: 16299036].
627 Jung M, Kim SH, Hong S, et al. Prognostic and predictive value of carcinoembryonic antigen and cytokeratin-19 fragments levels in advanced non-small cell lung cancer patients treated with gefitinib or erlotinib. Yonsei Med J. 2012;53(5):931-939. EXC2. [pmid: 22869475].
628 Jung M, Kim SH, Lee YJ, et al. Prognostic and predictive value of CEA and CYFRA 21-1 levels in advanced non-small cell lung cancer patients treated with geftinib or erlotinib. Experimental and Therapeutic Medicine. 2011;2(4):685-693. EXC4. [pmid: 22977560].
629 Jung SB, Lee HI, Oh HK, et al. Clinico-pathologic parameters for prediction of microsatellite instability in colorectal cancer. Cancer Research and Treatment. 2012. 2012;44(3):179-186. FULL TEXT LINK http://dx.doi.org/10.4143/crt.2012.44.3.179. EXC6.
630 Junker K, Fritsch T, Hartmann A, et al. Multicolor fluorescence in situ hybridization (M-FISH) on cells from urine for the detection of bladder cancer. Cytogenet Genome Res. 2006;114(3-4):279-283. EXC6. [pmid: 16954667].
631 Just PA, Cazes A, Audebourg A, et al. Histologic subtypes, immunohistochemistry, FISH or molecular screening for the accurate diagnosis of ALK-rearrangement in lung cancer: a comprehensive study of Caucasian non-smokers. Lung Cancer. Jun. 2012;76(3):309-315. EXC6. [pmid: 22153831].
632 Kadiyska TK, Konstantinova DV, Atanasov VR, et al. Frequency and application of the hot spot BRAF gene mutation (p.V600E) in the diagnostic strategy for Hereditary Nonpolyposis Colorectal Cancer. Cancer Detect Prev. 2007;31(3):254-256. EXC5. [pmid: 17566669].
633 Kaira K, Horie Y, Ayabe E, et al. Pulmonary pleomorphic carcinoma: a clinicopathological study including EGFR mutation analysis. J Thorac Oncol. Apr. 2010;5(4):460-465. EXC6. [pmid: 20107421].
634 Kaira K, Nakagawa K, Ohde Y, et al. Depolarized MUC1 expression is closely associated with hypoxic markers and poor outcome in resected non-small cell lung cancer. Int J Surg Pathol. Jun. 2012;20(3):223-232. EXC4. [pmid: 22108499].
635 Kaira K, Oriuchi N, Takahashi T, et al. L-type amino acid transporter 1 (LAT1) expression in malignant pleural mesothelioma. Anticancer Res. Dec. 2011;31(12):4075-4082. EXC6. [pmid: 22199264].
636 Kaji E, Kato J, Suzuki H, et al. Analysis of K-ras, BRAF, and PIK3CA mutations in laterally-spreading tumors of the colorectum. J Gastroenterol Hepatol. Mar. 2011;26(3):599-607. EXC6. [pmid: 21332555].
637 Kakar S, Aksoy S, Burgart LJ, et al. Mucinous carcinoma of the colon: correlation of loss of mismatch repair enzymes with clinicopathologic features and survival. Mod Pathol. Jun. 2004;17(6):696-700. EXC4. [pmid: 15017435].
638 Kakar S, Deng G, Smyrk TC, et al. Loss of heterozygosity, aberrant methylation, BRAF mutation and KRAS mutation in colorectal signet ring cell carcinoma. Mod Pathol. Jul. 2012;25(7):1040-1047. EXC6. [pmid: 22522845].
639 Kakar S, Smyrk TC. Signet ring cell carcinoma of the colorectum: correlations between microsatellite instability, clinicopathologic features and survival. Mod Pathol. Feb. 2005;18(2):244-249. EXC6. [pmid: 15492759].
640 Kakegawa S, Shimizu K, Sugano M, et al. Clinicopathological features of lung adenocarcinoma with KRAS mutations. Cancer. 2011;117(18):4257-4266. EXC6. [pmid: 21387273].
641 Kalady MF, Sanchez JA, Manilich E, et al. Divergent oncogenic changes influence survival differences between colon and rectal adenocarcinomas. Dis Colon Rectum. Jun. 2009;52(6):1039-1045. EXC4. [pmid: 19581844].
642 Kalikaki A, Koutsopoulos A, Hatzidaki D, et al. Clinical outcome of patients with non-small cell lung cancer receiving front-line chemotherapy according to EGFR and K-RAS mutation status. Lung Cancer. Jul. 2010;69(1):110-115. EXC6. [pmid: 19854533].
643 Kamat AM, Dickstein RJ, Messetti F, et al. Use of fluorescence in situ hybridization to predict response to bacillus Calmette-Guerin therapy for bladder cancer: results of a prospective trial. J Urol. Mar. 2012;187(3):862-867. Inc. [pmid: 22245325].
644 Kamat AM, Hegarty PK, Gee JR, et al. ICUD-EAU International Consultation on Bladder Cancer 2012: Screening, diagnosis, and molecular markers. Eur Urol. Jan. 2013;63(1):4-15. EXC6. [pmid: 23083902].
645 Kamat AM, Karam JA, Grossman HB, et al. Prospective trial to identify optimal bladder cancer surveillance protocol: reducing costs while maximizing sensitivity. BJU Int. Oct. 2011;108(7):1119-1123. EXC5. [pmid: 21426474].
646 Kanaji N, Bandoh S, Ishii T, et al. Detection of EML4-ALK fusion genes in a few cancer cells from transbronchial cytological specimens utilizing immediate cytology during bronchoscopy. Lung Cancer. 2012;77(2):293-298. EXC4. [pmid: 22494566].
647 Kanaji N, Bandoh S, Nagamura N, et al. Significance of an epidermal growth factor receptor mutation in cerebrospinal fluid for carcinomatous meningitis. Intern Med. 2007;46(19):1651-1655. EXC2. [pmid: 17917328].
648 Kaneda H, Okamoto I, Sakai K, et al. Marked response to both S-1 and pemetrexed in a patient with echinoderm microtubule-associated protein-like 4-anaplastic lymphoma kinase-positive lung adenocarcinoma. Acta Oncol. 2012;51(7):942-944. EXC2. [pmid: 22283471].
649 Kaneda H, Uemura Y, Nakano T, et al. Lesions in patients with multifocal adenocarcinoma are more frequently in the right upper lobes. Interact Cardiovasc Thorac Surg. Oct. 2012;15(4):627-632. EXC6. [pmid: 22733594].
650 Kanematsu T, Yano S, Uehara H, et al. Phosphorylation, but not overexpression, of epidermal growth factor receptor is associated with poor prognosis of non-small cell lung cancer patients. Oncol Res. 2003;13(5):289-298. EXC4. [pmid: 12688680].
651 Kang BW, Kim JG, Lee SJ, et al. Clinical significance of microsatellite instability for stage II or III colorectal cancer following adjuvant therapy with doxifluridine. Med Oncol. Dec. Suppl 1. 2011;28:S214-S218. EXC4. [pmid: 20953739].
652 Kang JU, Koo SH, Kwon KC, et al. Gain of the EGFR gene located on 7p12 is a frequent and early event in squamous cell carcinoma of the lung. Cancer Genet Cytogenet. Jul. 2008;184(1):31-37. EXC6. [pmid: 18558286].
653 Kappers I, Vollebergh MA, Van Tinteren H, et al. Soluble epidermal growth factor receptor (sEGFR) and carcinoembryonic antigen (CEA) concentration in patients with nonsmall cell lung cancer: Correlation with survival after erlotinib and gefitinib treatment. ecancermedicalscience. 2010;4(1). EXC4.
654 Karim B, Florence C, Kamel R, et al. KRAS mutation detection in Tunisian sporadic coloractal cancer patients with direct sequencing, high resolution melting and denaturating high performance liquid chromatography. Cancer Biomark. 2010;8(6):331-340. EXC5. [pmid: 22072121].
655 Karnwal A, Venegas R, Shuch B, et al. The role of fluorescence in situ hybridization assay for surveillance of non-muscle invasive bladder cancer. Can J Urol. Apr. 2010;17(2):5077-5081. EXC5. [pmid: 20398445].
656 Karpinski P, Szmida E, Misiak B, et al. Assessment of three epigenotypes in colorectal cancer by combined bisulfite restriction analysis. Mol Carcinog. Dec. 2012;51(12):1003-1008. EXC6. [pmid: 22006538].
657 Kasahara K, Arao T, Sakai K, et al. Impact of serum hepatocyte growth factor on treatment response to epidermal growth factor receptor tyrosine kinase inhibitors in patients with non-small cell lung adenocarcinoma. Clin Cancer Res. Sep. 15. 2010;16(18):4616-4624. EXC6. [pmid: 20679350].
658 Kashihara M, Azuma K, Kawahara A, et al. Nuclear Y-box binding protein-1, a predictive marker of prognosis, is correlated with expression of HER2/ErbB2 and HER3/ErbB3 in non-small cell lung cancer. J Thorac Oncol. Sep. 2009;4(9):1066-1074. EXC4. [pmid: 19648825].
659 Katballe N, Christensen M, Wikman FP, et al. Frequency of hereditary non-polyposis colorectal cancer in Danish colorectal cancer patients. Gut. Jan. 2002;50(1):43-51. EXC3. [pmid: 11772966].
660 Katkoori VR, Shanmugam C, Jia X, et al. Prognostic significance and gene expression profiles of p53 mutations in microsatellite-stable stage III colorectal adenocarcinomas. PLoS One. 2012;7(1):e30020. EXC4. [pmid: 22276141].
661 Kawada K, Nakamoto Y, Kawada M, et al. Relationship between 18F-fluorodeoxyglucose accumulation and KRAS/BRAF mutations in colorectal cancer. Clin Cancer Res. Mar. 15. 2012;18(6):1696-1703. EXC6. [pmid: 22282467].
662 Kawahara A, Taira T, Azuma K, et al. A diagnostic algorithm using EGFR mutation-specific antibodies for rapid response EGFR-TKI treatment in patients with non-small cell lung cancer. Lung Cancer. 2012;78(1):39-44. EXC4. [pmid: 22858448].
663 Kawai H, Ishii A, Washiya K, et al. Combined overexpression of EGFR and estrogen receptor alpha correlates with a poor outcome in lung cancer. Anticancer Res. Nov-Dec. 2005;25(6C):4693-4698. EXC4. [pmid: 16334162].
664 Kawano Y, Ohyanagi F, Yanagitani N, et al. Pemetrexed and cisplatin for advanced non-squamous non-small cell lung cancer in Japanese patients: phase II study. Anticancer Res. Aug. 2013;33(8):3327-3333. EXC3. [pmid: 23898099].
665 Kayton ML, He M, Zakowski MF, et al. Primary lung adenocarcinomas in children and adolescents treated for pediatric malignancies. J Thorac Oncol. 2010;5(11):1764-1771. EXC3. [pmid: 20975376].
666 Kazama Y, Watanabe T, Kanazawa T, et al. Mucinous colorectal cancers with chromosomal instability: A biologically distinct and aggressive subtype. Diagn Mol Pathol. 2006;15(1):30-34. EXC5. [pmid: 16531766].
667 Kazama Y, Watanabe T, Kanazawa T, et al. Microsatellite instability in poorly differentiated adenocarcinomas of the colon and rectum: relationship to clinicopathological features. J Clin Pathol. Jun. 2007;60(6):701-704. EXC6. [pmid: 17557871].
668 Ke HG, Zhou XY, Shen Y, et al. The relationship between EGFR gene mutation status and ERCC1 in lung adenocarcinoma of Chinese patients receiving platinum-based neoadjuvant chemotherapy. Oncol Res. 2012;20(5-6):221-229. EXC7. [pmid: 23581229].
669 Kehinde EO, Al-Mulla F, Kapila K, et al. Comparison of the sensitivity and specificity of urine cytology, urinary nuclear matrix protein-22 and multitarget fluorescence in situ hybridization assay in the detection of bladder cancer. Scand J Urol Nephrol. Mar. 2011;45(2):113-121. EXC6. [pmid: 21091091].
670 Impact of the recurrence score (RS) result and mismatch repair status (MMR) on agreement between oncologists (MDs) for stage II colon cancer (CC) recurrence risk (RR) assessment: A novel clinical utility endpoint for prognostic markers. ASCO. 2013. EXC6.
671 Kelly CM, Krishnamurthy S, Bianchini G, et al. Utility of oncotype DX risk estimates in clinically intermediate risk hormone receptor-positive, HER2-normal, grade II, lymph node-negative breast cancers. Cancer. Nov. 15. 2010;116(22):5161-5167. EXC6. [pmid: 20665886].
672 Kelly RJ, Rajan A, Force J, et al. Evaluation of KRAS mutations, angiogenic biomarkers, and DCE-MRI in patients with advanced non-small-cell lung cancer receiving sorafenib. Clin Cancer Res. Mar. 1. 2011;17(5):1190-1199. EXC6. [pmid: 21224376].
673 Kennecke HF, Speers CH, Ennis CA, et al. Impact of routine pathology review on treatment for node-negative breast cancer. J Clin Oncol. Jun. 20. 2012;30(18):2227-2231. EXC4. [pmid: 22564990].
674 Kets CM, Hoogerbrugge N, Bodmer D, et al. Unfavorable pathological characteristics in familial colorectal cancer with low-level microsatellite instability. Mod Pathol. Dec. 2006;19(12):1624-1630. EXC3. [pmid: 16980941].
675 Kets CM, Van Krieken JHJM, Van Erp PEJ, et al. Is early-onset microsatellite and chromosomally stable colorectal cancer a hallmark of a genetic susceptibility syndrome?. Int J Cancer. 2008;122(4):796-801. EXC6. [pmid: 17957798].
676 Khambata-Ford S, Harbison CT, Hart LL, et al. Analysis of potential predictive markers of cetuximab benefit in BMS099, a phase III study of cetuximab and first-line taxane/carboplatin in advanced non-small-cell lung cancer. J Clin Oncol. Feb. 20. 2010;28(6):918-927. EXC6. [pmid: 20100958].
677 Khan SA, Morris M, Idrees K, et al. The biology of early-onset colorectal cancer: An examination of tumor markers, pathology, and survival in a large cohort of patients. J Clin Oncol. 2011;29(15). EXC6.
678 Khode R, Larsen DA, Culbreath BC, et al. Comparative study of epidermal growth factor receptor mutation analysis on cytology smears and surgical pathology specimens from primary and metastatic lung carcinomas. Cancer Cytopathol. Jul. 2013;121(7):361-369. EXC4. [pmid: 23364874].
679 Kidwell KM, Yothers G, Ganz PA, et al. Long-term neurotoxicity effects of oxaliplatin added to fluorouracil and leucovorin as adjuvant therapy for colon cancer: results from National Surgical Adjuvant Breast and Bowel Project trials C-07 and LTS-01. Cancer. Nov. 15. 2012;118(22):5614-5622. EXC6. [pmid: 22569841].
680 Kim DW, Lee SH, Lee JS, et al. A multicenter phase II study to evaluate the efficacy and safety of gefitinib as first-line treatment for Korean patients with advanced pulmonary adenocarcinoma harboring EGFR mutations. Lung Cancer. Jan. 2011;71(1):65-69. EXC6. [pmid: 20430469].
681 Kim DW, Min HS, Lee KH, et al. High tumour islet macrophage infiltration correlates with improved patient survival but not with EGFR mutations, gene copy number or protein expression in resected non-small cell lung cancer. Br J Cancer. Mar. 25. 2008;98(6):1118-1124. EXC6. [pmid: 18283317].
682 Kim H, Piao Z, Kim JW, et al. Expression of hMSH2 and hMLH1 in colorectal carcinomas with microsatellite instability. Pathol Res Pract. 1998;194(1):3-9. EXC4. [pmid: 9542742].
683 Kim H, Xu X, Yoo SB, et al. Discordance between anaplastic lymphoma kinase status in primary non-small-cell lung cancers and their corresponding metastases. Histopathology. Jan. 2013;62(2):305-314. EXC6. [pmid: 23020707].
684 Kim H, Yoo SB, Choe JY, et al. Detection of ALK gene rearrangement in non-small cell lung cancer: a comparison of fluorescence in situ hybridization and chromogenic in situ hybridization with correlation of ALK protein expression. J Thorac Oncol. Aug. 2011;6(8):1359-1366. EXC5. [pmid: 21587085].
685 Kim HJ, Lee KY, Kim YC, et al. Detection and comparison of peptide nucleic acid-mediated real-time polymerase chain reaction clamping and direct gene sequencing for epidermal growth factor receptor mutations in patients with non-small cell lung cancer. Lung Cancer. Mar. 2012;75(3):321-325. EXC6. [pmid: 21930325].
686 Kim HJ, Oh SY, Kim WS, et al. Clinical investigation of EGFR mutation detection by pyrosequencing in lung cancer patients. Oncology Letters. 2012. 2012;5(1):271-276. FULL TEXT LINK http://dx.doi.org/10.3892/ol.2012.950. EXC6.
687 Kim HR, Shim HS, Chung JH, et al. Distinct clinical features and outcomes in never-smokers with nonsmall cell lung cancer who harbor EGFR or KRAS mutations or ALK rearrangement. Cancer. Feb. 1. 2012;118(3):729-739. EXC6. [pmid: 21720997].
688 Kim HS, Park YH, Lee J, et al. Clinical impact of phosphorylated signal transducer and activator of transcription 3, epidermal growth factor receptor, p53, and vascular endothelial growth factor receptor 1 expression in resected adenocarcinoma of lung by using tissue microarray. Cancer. Feb. 1. 2010;116(3):676-685. EXC4. [pmid: 20052735].
689 Kim JC, Roh SA, Cho DH, et al. Chemoresponsiveness associated with canonical molecular changes in colorectal adenocarcinomas. Anticancer Res. Aug. 2009;29(8):3115-3123. EXC5. [pmid: 19661324].
690 Kim JE, Hong YS, Ryu MH, et al. Association between deficient mismatch repair system and efficacy to irinotecan-containing chemotherapy in metastatic colon cancer. Cancer Sci. Sep. 2011;102(9):1706-1711. EXC5. [pmid: 21679278].
691 Kim JH, Shin SH, Kwon HJ, et al. Prognostic implications of CpG island hypermethylator phenotype in colorectal cancers. Virchows Arch. Dec. 2009;455(6):485-494. EXC5. [pmid: 19911194].
692 Kim KS, Jeong JY, Kim YC, et al. Predictors of the response to gefitinib in refractory non-small cell lung cancer. Clin Cancer Res. Mar. 15. 2005;11(6):2244-2251. EXC6. [pmid: 15788673].
693 Kim SJ, Rabbani ZN, Dong F, et al. Phosphorylated epidermal growth factor receptor and cyclooxygenase-2 expression in localized non-small cell lung cancer. Med Oncol_. 2010;27(1):91-97. EXC5. [pmid: 19235531].
694 Kim ST, Choi YJ, Park KH, et al. Epidermal growth factor receptor mutations as a prognostic factor in korean patients with advanced lung adenocarcinoma who had not been treated with received epidermal growth factor receptor tyrosine kinase inhibitors. Chemotherapy. 2011;57(2):108-114. EXC3. [pmid: 21411993].
695 Kim ST, Jung HY, Sung JS, et al. Can serum be used for analyzing the EGFR mutation status in patients with advanced non-small cell lung cancer?. Am J Clin Oncol. Feb. 2013;36(1):57-63. EXC3. [pmid: 22237146].
696 Kim ST, Lee J, Kim JH, et al. Comparison of gefitinib versus erlotinib in patients with nonsmall cell lung cancer who failed previous chemotherapy. Cancer. Jun. 15. 2010;116(12):3025-3033. EXC6. [pmid: 20564408].
697 Kim ST, Sung JS, Jo UH, et al. Can mutations of EGFR and KRAS in serum be predictive and prognostic markers in patients with advanced non-small cell lung cancer (NSCLC)?. Med Oncol. Mar. 2013;30(1):328. EXC7. [pmid: 23307237].
698 Kim SY, Shim EK, Yeo HY, et al. KRAS mutation status and clinical outcome of preoperative chemoradiation with cetuximab in locally advanced rectal cancer: a pooled analysis of 2 phase II trials. Int J Radiat Oncol Biol Phys. Jan. 1. 2013;85(1):201-207. EXC4. [pmid: 22672749].
699 Kim YH, Min BH, Kim SJ, et al. Difference between proximal and distal microsatellite-unstable sporadic colorectal cancers: analysis of clinicopathological and molecular features and prognoses. Ann Surg Oncol. May. 2010;17(5):1435-1441. EXC4. [pmid: 20049642].
700 Kim YH, Song SY, Kwon YD, et al. Microsatellite instable double primary cancers of the colorectum and stomach exhibit less favorable outcome. World J Gastroenterol. Jul. 14. 2005;11(26):3998-4002. EXC3. [pmid: 15996022].
701 Kimura H, Fujiwara Y, Sone T, et al. High sensitivity detection of epidermal growth factor receptor mutations in the pleural effusion of non-small cell lung cancer patients. Cancer Sci. Jul. 2006;97(7):642-648. EXC6. [pmid: 16827805].
702 Kimura H, Kasahara K, Kawaishi M, et al. Detection of epidermal growth factor receptor mutations in serum as a predictor of the response to gefitinib in patients with non-small-cell lung cancer. Clin Cancer Res. Jul. 1. 2006;12(13):3915-3921. EXC6. [pmid: 16818687].
703 Kimura H, Nakajima T, Takeuchi K, et al. ALK fusion gene positive lung cancer and 3 cases treated with an inhibitor for ALK kinase activity. Lung Cancer. Jan. 2012;75(1):66-72. EXC6. [pmid: 21757253].
704 Kimura H, Suminoe M, Kasahara K, et al. Evaluation of epidermal growth factor receptor mutation status in serum DNA as a predictor of response to gefitinib (IRESSA). Br J Cancer. Sep. 17. 2007;97(6):778-784. EXC6. [pmid: 17848912].
705 Kimura T, Okamoto K, Miyamoto H, et al. Clinical benefit of high-sensitivity KRAS mutation testing in metastatic colorectal cancer treated with anti-EGFR antibody therapy. Oncology. 2012;82(5):298-304. EXC3. [pmid: 22555244].
706 Kipp BR, Karnes RJ, Brankley SM, et al. Monitoring intravesical therapy for superficial bladder cancer using fluorescence in situ hybridization. J Urol. Feb. 2005;173(2):401-404. EXC7. [pmid: 15643180].
707 Kirk R. Risk factors. Oncotype DX assay predicts local recurrence in breast cancer. Nat Rev Clin Oncol. Jun. 2010;7(6):300. EXC2. [pmid: 20527688].
708 Kitano S, Nakayama M, Yamane A, et al. Detection of DNA mutations by fluorescence resonance energy transfer-based preferential homoduplex formation assay. Anal Biochem. Jan. 15. 2011;408(2):197-205. EXC4. [pmid: 20850410].
709 Klarskov L, Holck S, Bernstein I, et al. Challenges in the identification of MSH6-associated colorectal cancer: rectal location, less typical histology, and a subset with retained mismatch repair function. Am J Surg Pathol. Sep. 2011;35(9):1391-1399. EXC5. [pmid: 21836479].
710 Klump B, Nehls O, Okech T, et al. Molecular lesions in colorectal cancer: Impact on prognosis? Original data and review of the literature. Int J Colorectal Dis. 2004;19(1):23-42. EXC1. [pmid: 12827409].
711 Knauer M, Mook S, Rutgers EJ, et al. The predictive value of the 70-gene signature for adjuvant chemotherapy in early breast cancer. Breast Cancer Res Treat. Apr. 2010;120(3):655-661. EXC6. [pmid: 20204499].
712 Knijn N, Mekenkamp LJ, Klomp M, et al. KRAS mutation analysis: a comparison between primary tumours and matched liver metastases in 305 colorectal cancer patients. Br J Cancer. Mar. 15. 2011;104(6):1020-1026. EXC6. [pmid: 21364579].
713 Kobayashi M, Sonobe M, Takahashi T, et al. Detection of ALK fusion in lung cancer using fluorescence in situ hybridization. Asian Cardiovasc Thorac Ann. Aug. 2012;20(4):426-431. EXC6. [pmid: 22879549].
714 Kobayashi S, Boggon TJ, Dayaram T, et al. EGFR mutation and resistance of non-small-cell lung cancer to gefitinib. N Engl J Med. Feb. 24. 2005;352(8):786-792. EXC2. [pmid: 15728811].
715 Koelzer VH, Karamitopoulou E, Dawson H, et al. Geographic analysis of RKIP expression and its clinical relevance in colorectal cancer. Br J Cancer. May. 28. 2013;108(10):2088-2096. EXC4. [pmid: 23632477].
716 Koga T, Takeshita M, Ijichi K, et al. CHFR aberrant methylation involves a subset of human lung adenocarcinoma associated with poor clinical outcomes. Hum Pathol. Jul. 2013;44(7):1382-1390. EXC7. [pmid: 23415374].
717 Koh Y, Kim DW, Kim TM, et al. Clinicopathologic characteristics and outcomes of patients with anaplastic lymphoma kinase-positive advanced pulmonary adenocarcinoma: suggestion for an effective screening strategy for these tumors. J Thorac Oncol. May. 2011;6(5):905-912. EXC6. [pmid: 21358343].
718 Kohonen-Corish MR, Daniel JJ, Chan C, et al. Low microsatellite instability is associated with poor prognosis in stage C colon cancer. J Clin Oncol. Apr. 1. 2005;23(10):2318-2324. EXC3. [pmid: 15800322].
719 Koinuma K, Kaneda R, Toyota M, et al. Screening for genomic fragments that are methylated specifically in colorectal carcinoma with a methylated MLH1 promoter. Carcinogenesis. Dec. 2005;26(12):2078-2085. EXC3. [pmid: 16033773].
720 Kok M, Koornstra RH, Mook S, et al. Additional value of the 70-gene signature and levels of ER and PR for the prediction of outcome in tamoxifen-treated ER-positive breast cancer. Breast. Dec. 2012;21(6):769-778. EXC3. [pmid: 22738860].
721 Kondo M, Hoshi SL, Ishiguro H, et al. Economic evaluation of the 70-gene prognosis-signature (MammaPrint(registered trademark)) in hormone receptor-positive, lymph node-negative, human epidermal growth factor receptor type 2-negative early stage breast cancer in Japan. Breast Cancer Res Treat. 2012;133(2):759-768. EXC2. [pmid: 22315134].
722 Kondo M, Hoshi SL, Ishiguro H, et al. Economic evaluation of 21-gene reverse transcriptase-polymerase chain reaction assay in lymph-node-negative, estrogen-receptor-positive, early-stage breast cancer in Japan (Structured abstract). Breast Cancer Res Treat. 2008;(1):175-187. EXC2. [pmid: 18075786].
723 Kondo M, Hoshi SL, Yamanaka T, et al. Economic evaluation of the 21-gene signature (Oncotype DX) in lymph node-negative/positive, hormone receptor-positive early-stage breast cancer based on Japanese validation study (JBCRG-TR03) (Structured abstract). Breast Cancer Res Treat. 2011;(3):739-749. EXC2. [pmid: 21082239].
724 Konigsberg R, Hulla W, Klimpfinger M, et al. Clinical and economic aspects of KRAS mutational status as predictor for epidermal growth factor receptor inhibitor therapy in metastatic colorectal cancer patients. Oncology. 2011;81(5-6):359-364. EXC4. [pmid: 22248908].
725 Konishi J, Yamazaki K, Kinoshita I, et al. Analysis of the response and toxicity to gefitinib of non-small cell lung cancer. Anticancer Res. Jan-Feb. 2005;25(1B):435-441. EXC4. [pmid: 15816608].
726 Koopman M, Kortman GA, Mekenkamp L, et al. Deficient mismatch repair system in patients with sporadic advanced colorectal cancer. Br J Cancer. Jan. 27. 2009;100(2):266-273. EXC4. [pmid: 19165197].
727 Genomic Classifiers (ColoPrint/MSI-Print) to Predict Outcome and Chemotherapy Benefit in Stage II and III Colon Cancer Patients. ASCO Gastrointestinal Symposium. 2013. San Francisco, CA. EXC4.
728 Kordiak J, Szemraj J, Hamara K, et al. Complete surgical resection of lung tumor decreases exhalation of mutated KRAS oncogene. Respir Med. 2012;106(9):1293-1300. EXC4. [pmid: 22795503].
729 Korpanty G, Mulligan N, Carney DN. Complete radiological response of metastatic anaplastic lymphoma kinase-positive signet ring lung adenocarcinoma to systemic chemotherapy. J Thorac Oncol. May. 2011;6(5):963-965. EXC2. [pmid: 21623269].
730 Kosaka T, Yatabe Y, Endoh H, et al. Mutations of the epidermal growth factor receptor gene in lung cancer: biological and clinical implications. Cancer Res. Dec. 15. 2004;64(24):8919-8923. EXC4. [pmid: 15604253].
731 Kosaka T, Yatabe Y, Onozato R, et al. Prognostic implication of EGFR, KRAS, and TP53 gene mutations in a large cohort of Japanese patients with surgically treated lung adenocarcinoma. J Thorac Oncol. Jan. 2009;4(1):22-29. EXC4. [pmid: 19096302].
732 Koukourakis MI, Giatromanolaki A, O'Byrne KJ, et al. Potential role of bcl-2 as a suppressor of tumour angiogenesis in non-small-cell lung cancer. Int J Cancer. Dec. 19. 1997;74(6):565-570. EXC4. [pmid: 9421349].
733 Koyama N, Jinn Y, Takabe K, et al. The characterization of gefitinib sensitivity and adverse events in patients with non-small cell lung cancer. Anticancer Res. Nov-Dec. 2006;26(6B):4519-4525. EXC6. [pmid: 17201173].
734 Kozu Y, Tsuta K, Kohno T, et al. The usefulness of mutation-specific antibodies in detecting epidermal growth factor receptor mutations and in predicting response to tyrosine kinase inhibitor therapy in lung adenocarcinoma. Lung Cancer. Jul. 2011;73(1):45-50. EXC6. [pmid: 21129809].
735 Krajewska M, Kim H, Kim C, et al. Analysis of apoptosis protein expression in early-stage colorectal cancer suggests opportunities for new prognostic biomarkers. Clin Cancer Res. 2005;11(15):5451-5461. EXC4. [pmid: 16061861].
736 Krawczyk P, Kowalski DM, Wojas-Krawczyk K, et al. The qualification of docetaxel or erlotinib for second-line therapy should be based on clinical and molecular predictive factors. Chemotherapy. 2012;58(1):60-69. EXC6. [pmid: 22338650].
737 Krawczyk P, Wojas-Krawczyk K, Mlak R, et al. Predictive value of ERCC1 single-nucleotide polymorphism in patients receiving platinum-based chemotherapy for locally-advanced and advanced non-small cell lung cancer - a pilot study. Folia Histochem Cytobiol. 2012;50(1):80-86. EXC4. [pmid: 22532140].
738 Kriegl L, Jung A, Horst D, et al. Microsatellite instability, KRAS mutations and cellular distribution of TRAIL-receptors in early stage colorectal cancer. PLoS One. 2012;7(12):e51654. EXC4. [pmid: 23284732].
739 Kris MG, Natale RB, Herbst RS, et al. Efficacy of gefitinib, an inhibitor of the epidermal growth factor receptor tyrosine kinase, in symptomatic patients with non-small cell lung cancer: a randomized trial. JAMA. Oct. 22. 2003;290(16):2149-2158. EXC6. [pmid: 14570950].
740 Krishnaswamy S, Kanteti R, Duke-Cohan JS, et al. Ethnic differences and functional analysis of MET mutations in lung cancer. Clin Cancer Res. Sep. 15. 2009;15(18):5714-5723. EXC6. [pmid: 19723643].
741 Krivokapic Z, Markovic S, Antic J, et al. Clinical and pathological tools for identifying microsatellite instability in colorectal cancer. Croat Med J. Aug. 2012;53(4):328-335. EXC4. [pmid: 22911525].
742 Krol LC, t Hart NA, Methorst N, et al. Concordance in KRAS and BRAF mutations in endoscopic biopsy samples and resection specimens of colorectal adenocarcinoma. Eur J Cancer. May. 2012;48(7):1108-1115. EXC6. [pmid: 22446020].
743 Kruger S, Mess F, Bohle A, et al. Numerical aberrations of chromosome 17 and the 9p21 locus are independent predictors of tumor recurrence in non-invasive transitional cell carcinoma of the urinary bladder. Int J Oncol. Jul. 2003;23(1):41-48. EXC6. [pmid: 12792774].
744 Kruhoffer M, Jensen JL, Laiho P, et al. Gene expression signatures for colorectal cancer microsatellite status and HNPCC. Br J Cancer. Jun. 20. 2005;92(12):2240-2248. EXC5. [pmid: 15956967].
745 Kruschewski M, Noske A, Haier J, et al. Is reduced expression of mismatch repair genes MLH1 and MSH2 in patients with sporadic colorectal cancer related to their prognosis?. Clin Exp Metastasis. 2002;19(1):71-77. EXC5. [pmid: 11918085].
746 Kuebler JP, Colangelo L, O'Connell MJ, et al. Severe enteropathy among patients with stage II/III colon cancer treated on a randomized trial of bolus 5-fluorouracil/leucovorin plus or minus oxaliplatin: a prospective analysis. Cancer. Nov. 1. 2007;110(9):1945-1950. EXC6. [pmid: 17853393].
747 Kumar K, Brim H, Giardiello F, et al. Distinct BRAF (V600E) and KRAS mutations in high microsatellite instability sporadic colorectal cancer in African Americans. Clin Cancer Res. Feb. 15. 2009;15(4):1155-1161. EXC6. [pmid: 19190129].
748 Kumar S, Chang EY, Frankhouse J, et al. Combination of microsatellite instability and lymphocytic infiltrate as a prognostic indicator for adjuvant therapy in colon cancer. Arch Surg. Sep. 2009;144(9):835-840. EXC5. [pmid: 19797108].
749 Kunz G. Use of a genomic test (MammaPrint) in daily clinical practice to assist in risk stratification of young breast cancer patients. Arch Gynecol Obstet. Mar. 2011;283(3):597-602. EXC5. [pmid: 20383789].
750 Kuo CH, Lin SM, Lee KY, et al. Subsequent chemotherapy improves survival outcome in advanced non-small-cell lung cancer with acquired tyrosine kinase inhibitor resistance. Clin Lung Cancer. Jan. 2010;11(1):51-56. EXC6. [pmid: 20085868].
751 Kuo YW, Wu SG, Ho CC, et al. Good response to gefitinib in lung adenocarcinoma harboring coexisting EML4-ALK fusion gene and EGFR mutation. J Thorac Oncol. 2010;5(12):2039-2040. EXC2. [pmid: 21102267].
752 Kuramochi H, Nakajima G, Kaneko Y, et al. Amphiregulin and Epiregulin mRNA expression in primary colorectal cancer and corresponding liver metastases. BMC Cancer. 2012;12:88. EXC6. [pmid: 22409860].
753 Kwak EL, Bang YJ, Camidge DR, et al. Anaplastic lymphoma kinase inhibition in non-small-cell lung cancer. N Engl J Med. Oct. 28. 2010;363(18):1693-1703. EXC6. [pmid: 20979469].
754 Kwon MJ, Lee SE, Kang SY, et al. Frequency of KRAS, BRAF, and PIK3CA mutations in advanced colorectal cancers: Comparison of peptide nucleic acid-mediated PCR clamping and direct sequencing in formalin-fixed, paraffin-embedded tissue. Pathol Res Pract. Dec. 15. 2011;207(12):762-768. EXC3. [pmid: 22070922].
755 Cost-utility of the 21-gene breast cancer assay (Oncotype DX®) in the Irish healthcare setting. San Antonio Breast Cancer Symposium. 2011. December. San Antonio, TX. EXC6.
756 Lacouture ME, Basti S, Patel J, et al. The SERIES clinic: An interdisciplinary approach to the management of toxicities of EGFR inhibitors. Journal of Supportive Oncology. 2006;4(5):236-238. EXC2. [pmid: 16724647].
757 Laghi L, Bianchi P, Delconte G, et al. MSH3 protein expression and nodal status in MLH1-deficient colorectal cancers. Clin Cancer Res. Jun. 1. 2012;18(11):3142-3153. EXC4. [pmid: 22496206].
758 Laghi L, Bianchi P, Miranda E, et al. CD3+ cells at the invasive margin of deeply invading (pT3-T4) colorectal cancer and risk of post-surgical metastasis: a longitudinal study. Lancet Oncol. Sep. 2009;10(9):877-884. EXC5. [pmid: 19656725].
759 Laiho P, Launonen V, Lahermo P, et al. Low-level microsatellite instability in most colorectal carcinomas. Cancer Res. Feb. 15. 2002;62(4):1166-1170. EXC4. [pmid: 11861399].
760 Lamberti C, Kruse R, Ruelfs C, et al. Microsatellite instability-a useful diagnostic tool to select patients at high risk for hereditary non-polyposis colorectal cancer: a study in different groups of patients with colorectal cancer. Gut. Jun. 1999;44(6):839-843. EXC4. [pmid: 10323887].
761 Lamberti C, Lundin S, Bogdanow M, et al. Microsatellite instability did not predict individual survival of unselected patients with colorectal cancer. Int J Colorectal Dis. Feb. 2007;22(2):145-152. EXC4. [pmid: 16724208].
762 Lancashire LJ, Powe DG, Reis-Filho JS, et al. A validated gene expression profile for detecting clinical outcome in breast cancer using artificial neural networks. Breast Cancer Res Treat. Feb. 2010;120(1):83-93. EXC4. [pmid: 19347577].
763 Lanza G, Gafa R, Maestri I, et al. Immunohistochemical pattern of MLH1/MSH2 expression is related to clinical and pathological features in colorectal adenocarcinomas with microsatellite instability. Mod Pathol. Jul. 2002;15(7):741-749. EXC6. [pmid: 12118112].
764 Lanza G, Gafa R, Santini A, et al. Immunohistochemical test for MLH1 and MSH2 expression predicts clinical outcome in stage II and III colorectal cancer patients. J Clin Oncol. May. 20. 2006;24(15):2359-2367. EXC4. [pmid: 16710035].
765 Larsen FO, Pfeiffer P, Nielsen D, et al. Bevacizumab in combination with cetuximab and irinotecan after failure of cetuximab and irinotecan in patients with metastatic colorectal cancer. Acta Oncol. May. 2011;50(4):574-577. EXC5. [pmid: 21529301].
766 Lastella P, Patruno M, Forte G, et al. Identification and surveillance of 19 Lynch syndrome families in southern Italy: report of six novel germline mutations and a common founder mutation. Fam Cancer. Jun. 2011;10(2):285-295. EXC3. [pmid: 21286823].
767 Laszlo L. Predictive and prognostic factors in the complex treatment of patients with colorectal cancer. Magy Onkol. Dec. 2010;54(4):383-394. EXC5. [pmid: 21163770].
768 Laudadio J, Keane TE, Reeves HM, et al. Fluorescence in situ hybridization for detecting transitional cell carcinoma: implications for clinical practice. BJU Int. Dec. 2005;96(9):1280-1285. EXC5. [pmid: 16287445].
769 Lawes DA, Pearson T, Sengupta S, et al. Is MSI-H of value in predicting the development of metachronous colorectal cancer?. Eur J Cancer. Mar. 2006;42(4):473-476. EXC4. [pmid: 16427780].
770 LeCaer H, Greillier L, Corre R, et al. A multicenter phase II randomized trial of gemcitabine followed by erlotinib at progression, versus the reverse sequence, in vulnerable elderly patients with advanced non small-cell lung cancer selected with a comprehensive geriatric assessment (the GFPC 0505 study). Lung Cancer. Jul. 2012;77(1):97-103. EXC4. [pmid: 22405570].
771 Lecomte T, Berger A, Zinzindohoue F, et al. Detection of free-circulating tumor-associated DNA in plasma of colorectal cancer patients and its association with prognosis. Int J Cancer. Aug. 10. 2002;100(5):542-548. EXC5. [pmid: 12124803].
772 Lee DH, Lee GK, Kong SY, et al. Epidermal growth factor receptor status in anaplastic thyroid carcinoma. J Clin Pathol. 2007;60(8):881-884. EXC3. [pmid: 17079354].
773 Lee HL, Chung TS, Ting LL, et al. EGFR mutations are associated with favorable intracranial response and progression-free survival following brain irradiation in non-small cell lung cancer patients with brain metastases. Radiation Oncology. 2012;7(1). FULL TEXT LINK http://dx.doi.org/10.1186/1748-717X-7-181. EXC3.
774 Lee HY, Ahn HK, Jeong JY, et al. Favorable clinical outcomes of pemetrexed treatment in anaplastic lymphoma kinase positive non-small-cell lung cancer. Lung Cancer. Jan. 2013;79(1):40-45. EXC6. [pmid: 23103072].
775 Lee JJ, Shen J. Is the Oncotype DX assay necessary in strongly estrogen receptor-positive breast cancers?. Am Surg. Oct. 2011;77(10):1364-1367. EXC5. [pmid: 22127090].
776 Lee JK, Park HS, Kim DW, et al. Comparative analyses of overall survival in patients with anaplastic lymphoma kinase-positive and matched wild-type advanced nonsmall cell lung cancer. Cancer. Jul. 15. 2012;118(14):3579-3586. EXC3. [pmid: 22086654].
777 Lee JS, Hirsh V, Park K, et al. Vandetanib Versus placebo in patients with advanced non-small-cell lung cancer after prior therapy with an epidermal growth factor receptor tyrosine kinase inhibitor: a randomized, double-blind phase III trial (ZEPHYR). J Clin Oncol. Apr. 1. 2012;30(10):1114-1121. EXC5. [pmid: 22370318].
778 Lee JW, Soung YH, Kim SY, et al. ERBB2 kinase domain mutation in the lung squamous cell carcinoma. Cancer Lett. Jun. 8. 2006;237(1):89-94. EXC4. [pmid: 16029927].
779 Lee KH, Lee JS, Nam JH, et al. Promoter methylation status of hMLH1, hMSH2, and MGMT genes in colorectal cancer associated with adenoma-carcinoma sequence. Langenbecks Arch Surg. Oct. 2011;396(7):1017-1026. EXC4. [pmid: 21706233].
780 Lee S, Cho NY, Choi M, et al. Clinicopathological features of CpG island methylator phenotype-positive colorectal cancer and its adverse prognosis in relation to KRAS/BRAF mutation. Pathol Int. Feb. 2008;58(2):104-113. EXC5. [pmid: 18199160].
781 Lee S, Kim Y, Sun JM, et al. Molecular profiles of EGFR, K-ras, c-met, and FGFR in pulmonary pleomorphic carcinoma, a rare lung malignancy. J Cancer Res Clin Oncol. Aug. 2011;137(8):1203-1211. EXC6. [pmid: 21626008].
782 Lee Y, Lee HJ, Kim YT, et al. Imaging characteristics of stage I non-small cell lung cancer on CT and FDG-PET: relationship with epidermal growth factor receptor protein expression status and survival. Korean J Radiol. Mar-Apr. 2013;14(2):375-383. EXC4. [pmid: 23483676].
783 Lee Y, Shim HS, Park MS, et al. High EGFR gene copy number and skin rash as predictive markers for EGFR tyrosine kinase inhibitors in patients with advanced squamous cell lung carcinoma. Clin Cancer Res. Mar. 15. 2012;18(6):1760-1768. EXC4. [pmid: 22271877].
784 Lee YJ, Park IK, Park MS, et al. Activating mutations within the EGFR kinase domain: a molecular predictor of disease-free survival in resected pulmonary adenocarcinoma. J Cancer Res Clin Oncol. Dec. 2009;135(12):1647-1654. EXC6. [pmid: 19517135].
785 Lee YJ, Shim HS, Kang YA, et al. Dose effect of cigarette smoking on frequency and spectrum of epidermal growth factor receptor gene mutations in Korean patients with non-small cell lung cancer. J Cancer Res Clin Oncol. Dec. 2010;136(12):1937-1944. EXC4. [pmid: 20237940].
786 Leidner RS, Fu P, Clifford B, et al. Genetic abnormalities of the EGFR pathway in African American Patients with non-small-cell lung cancer. J Clin Oncol. Nov. 20. 2009;27(33):5620-5626. EXC6. [pmid: 19786660].
787 Leite SM, Gomes KB, Pardini VC, et al. Assessment of microsatellite instability in colorectal cancer patients from Brazil. Mol Biol Rep. Jan. 2010;37(1):375-380. EXC4. [pmid: 19784864].
788 Leung WK, To KF, Man EP, et al. Quantitative detection of promoter hypermethylation in multiple genes in the serum of patients with colorectal cancer. Am J Gastroenterol. Oct. 2005;100(10):2274-2279. EXC6. [pmid: 16181380].
789 Levallet G, Bergot E, Antoine M, et al. High TUBB3 expression, an independent prognostic marker in patients with early non-small cell lung cancer treated by preoperative chemotherapy, is regulated by K-ras signaling pathway. Molecul Cancer Therapeut. 2012;11(5):1203-1213. EXC4.
790 Levine AJ, Win AK, Buchanan DD, et al. Cancer risks for the relatives of colorectal cancer cases with a methylated MLH1 promoter region: data from the Colorectal Cancer Family Registry. Cancer Prev Res (Phila). Feb. 2012;5(2):328-335. EXC6. [pmid: 22144422].
791 Levy M, Benesova L, Lipska L, et al. Utility of cell-free tumour DNA for post-surgical follow-up of colorectal cancer patients. Anticancer Res. May. 2012;32(5):1621-1626. EXC5. [pmid: 22593440].
792 Li AR, Chitale D, Riely GJ, et al. Clinical testing experience and relationship to EGFR gene copy number and immunohistochemical expression. J Molec Diagnost. 2008;10(3):242-248. EXC6.
793 Li BS, Wang XY, Xu AG, et al. High-resolution melting assay (HRMA) is a simple and sensitive stool-based DNA Test for the detection of mutations in colorectal neoplasms. Clin Colorectal Cancer. Dec. 2012;11(4):280-290. EXC4. [pmid: 22609129].
794 Li C, Fang R, Sun Y, et al. Spectrum of oncogenic driver mutations in lung adenocarcinomas from East Asian never smokers. PLoS One. 2011;6(11):e28204. EXC6. [pmid: 22140546].
795 Li C, Sun Y, Fang R, et al. Lung adenocarcinomas with HER2-activating mutations are associated with distinct clinical features and HER2/EGFR copy number gains. J Thorac Oncol. Jan. 2012;7(1):85-89. EXC6. [pmid: 22071781].
796 Li C, Sun Y, Fang Z, et al. Comprehensive analysis of epidermal growth factor receptor gene status in lung adenocarcinoma. J Thorac Oncol. Jun. 2011;6(6):1016-1021. [pmid: 21532505].
797 Li F, Liu Y, Chen H, et al. EGFR and COX-2 protein expression in non-small cell lung cancer and the correlation with clinical features. J Exp Clin Cancer Res. 2011;30(1). EXC4.
798 Li FH, Shen L, Li ZH, et al. Impact of KRAS mutation and PTEN expression on cetuximab-treated colorectal cancer. World J Gastroenterol. Dec. 14. 2010;16(46):5881-5888. EXC3. [pmid: 21155011].
799 Li H, Pan Y, Li Y, et al. Frequency of well-identified oncogenic driver mutations in lung adenocarcinoma of smokers varies with histological subtypes and graduated smoking dose. Lung Cancer. Jan. 2013;79(1):8-13. EXC6. [pmid: 23098378].
800 Li M, Liu L, Liu Z, et al. The status of KRAS mutations in patients with non-small cell lung cancers from mainland China. Oncol Rep. Nov. 2009;22(5):1013-1020. EXC4. [pmid: 19787214].
801 Li M, Zhang Q, Liu L, et al. The different clinical significance of EGFR mutations in exon 19 and 21 in non-small cell lung cancer patients of China. Neoplasma. 2011;58(1):74-81. EXC6. [pmid: 21067269].
802 Li P, Fang YJ, Li F, et al. ERCC1, defective mismatch repair status as predictive biomarkers of survival for stage III colon cancer patients receiving oxaliplatin-based adjuvant chemotherapy. Br J Cancer. Apr. 2. 2013;108(6):1238-1244. EXC3. [pmid: 23481186].
803 Li YH, Wang F, Shen L, et al. EGFR fluorescence in situ hybridization pattern of chromosome 7 disomy predicts resistance to cetuximab in KRAS wild-type metastatic colorectal cancer patients. Clin Cancer Res. Jan. 15. 2011;17(2):382-390. EXC4. [pmid: 20884623].
804 Liang H, Brufsky A, Lembersky B, et al. A retrospective analysis of the impact of oncotype DX low recurrence score results on treatment decisions in a single academic breast cancer center. 30th Annual San Antonio Breast Cancer Symposium. December 13-16, 2007. San Antonio, TX. Breast Cancer Research and Treatment. 2007;106:13-16. EXC2.
805 Liang JT, Huang KC, Lai HS, et al. High-frequency microsatellite instability predicts better chemosensitivity to high-dose 5-fluorouracil plus leucovorin chemotherapy for stage IV sporadic colorectal cancer after palliative bowel resection. Int J Cancer. Oct. 20. 2002;101(6):519-525. EXC5. [pmid: 12237891].
806 Liang Z, Zhang J, Zeng X, et al. Relationship between EGFR expression, copy number and mutation in lung adenocarcinomas. BMC Cancer. 2010;10:376. EXC6. [pmid: 20637128].
807 Liao W, Liao Y, Zhou JX, et al. Gene mutations in epidermal growth factor receptor signaling network and their association with survival in Chinese patients with metastatic colorectal cancers. Anat Rec (Hoboken). Sep. 2010;293(9):1506-1511. EXC5. [pmid: 20652941].
808 Licar A, Cerkovnik P, Ocvirk J, et al. KRAS mutations in Slovene patients with colorectal cancer: frequency, distribution and correlation with the response to treatment. Int J Oncol. May. 2010;36(5):1137-1144. EXC3. [pmid: 20372787].
809 Lievre A, Bachet JB, Boige V, et al. KRAS mutations as an independent prognostic factor in patients with advanced colorectal cancer treated with cetuximab. J Clin Oncol. Jan. 20. 2008;26(3):374-379. EXC5. [pmid: 18202412].
810 Lievre A, Bachet JB, Le Corre D, et al. KRAS mutation status is predictive of response to cetuximab therapy in colorectal cancer. Cancer Res. Apr. 15. 2006;66(8):3992-3995. EXC3. [pmid: 16618717].
811 Lim EH, Zhang SL, Li JL, et al. Using whole genome amplification (WGA) of low-volume biopsies to assess the prognostic role of EGFR, KRAS, p53, and CMET mutations in advanced-stage non-small cell lung cancer (NSCLC). J Thorac Oncol. Jan. 2009;4(1):12-21. EXC3. [pmid: 19096301].
812 Lim KH, Huang MJ, Liu HC, et al. Lack of prognostic value of EGFR mutations in primary resected non-small cell lung cancer. Med Oncol. 2007;24(4):388-393. EXC6. [pmid: 17917087].
813 Lim SB, Jeong SY, Lee MR, et al. Prognostic significance of microsatellite instability in sporadic colorectal cancer. Int J Colorectal Dis. Nov. 2004;19(6):533-537. EXC4. [pmid: 15175889].
814 Lin AY, Buckley NS, Lu AT, et al. Effect of KRAS mutational status in advanced colorectal cancer on the outcomes of anti-epidermal growth factor receptor monoclonal antibody therapy: a systematic review and meta-analysis (Provisional abstract). Clinical Colorectal Cancer. 2011;(1):63-69. EXC2. [pmid: 21609938].
815 Lin CC, Hsu HH, Sun CT, et al. Chemotherapy response in East Asian non-small cell lung cancer patients harboring wild-type or activating mutation of epidermal growth factor receptors. J Thorac Oncol. Sep. 2010;5(9):1424-1429. EXC6. [pmid: 20631634].
816 Lin CH, Lin JK, Chang SC, et al. Molecular profile and copy number analysis of sporadic colorectal cancer in Taiwan. J Biomed Sci. 2011;18:36. EXC6. [pmid: 21645411].
817 Lin G, Zheng XW, Li C, et al. KRAS mutation and NF-(kappa)B activation indicates tolerance of chemotherapy and poor prognosis in colorectal cancer. Dig Dis Sci. 2012;57(9):2325-2333. EXC4. [pmid: 22526587].
818 Lin JK, Lin AJ, Lin CC, et al. The status of EGFR-associated genes could predict the outcome and tumor response of chemo-refractory metastatic colorectal patients using cetuximab and chemotherapy. J Surg Oncol. Nov. 1. 2011;104(6):661-666. EXC3. [pmid: 21671463].
819 Lind JS, Dingemans AM, Groen HJ, et al. A multicenter phase II study of erlotinib and sorafenib in chemotherapy-naive patients with advanced non-small cell lung cancer. Clin Cancer Res. Jun. 1. 2010;16(11):3078-3087. EXC6. [pmid: 20395213].
820 Lipton LR, Johnson V, Cummings C, et al. Refining the Amsterdam Criteria and Bethesda Guidelines: testing algorithms for the prediction of mismatch repair mutation status in the familial cancer clinic. J Clin Oncol. Dec. 15. 2004;22(24):4934-4943. EXC3. [pmid: 15611508].
821 Liu G, Cheng D, Ding K, et al. Pharmacogenetic analysis of BR.21, a placebo-controlled randomized phase III clinical trial of erlotinib in advanced non-small cell lung cancer. J Thorac Oncol. Feb. 2012;7(2):316-322. EXC4. [pmid: 22237259].
822 Liu G, Gurubhagavatula S, Zhou W, et al. Epidermal growth factor receptor polymorphisms and clinical outcomes in non-small-cell lung cancer patients treated with gefitinib. Pharmacogenomics J. Apr. 2008;8(2):129-138. EXC4. [pmid: 17375033].
823 Liu T, Wahlberg S, Burek E, et al. Microsatellite instability as a predictor of a mutation in a DNA mismatch repair gene in familial colorectal cancer. Genes Chromosomes Cancer. Jan. 2000;27(1):17-25. EXC4. [pmid: 10564582].
824 Liu X, Goldblum JR, Zhao Z, et al. Distinct clinicohistologic features of inflammatory bowel disease-associated colorectal adenocarcinoma: in comparison with sporadic microsatellite-stable and Lynch syndrome-related colorectal adenocarcinoma. Am J Surg Pathol. Aug. 2012;36(8):1228-1233. EXC4. [pmid: 22790862].
825 Liu Y, Liu B, Li XY, et al. A comparison of ARMS and direct sequencing for EGFR mutation analysis and Tyrosine Kinase Inhibitors treatment prediction in body fluid samples of Non-Small-Cell Lung Cancer patients. J Exp Clin Cancer Res. 2011;30(1). EXC6.
826 Liu Y, Xia Q, Jia Y, et al. Significance of differential expression of thymidylate synthase in normal and primary tumor tissues from patients with colorectal cancer. J Hematol Oncol. 2011;4:33. EXC5. [pmid: 21824439].
827 Liu Y, Xu ML, Zhong HH, et al. EGFR mutations are more frequent in well-differentiated than in poor-differentiated lung adenocarcinomas. Pathology and Oncology Research. 2008;14(4):373-379. EXC7. [pmid: 18985444].
828 London S. Novel drug active against ALK gene rearrangements. Oncology Report. MARCH-APRIL. 2010:37-38. EXC3.
829 Lopez-Crapez E, Mineur L, Emptas H, et al. KRAS status analysis and anti-EGFR therapies: is comprehensiveness a biologist's fancy or a clinical necessity?. Br J Cancer. Mar. 16. 2010;102(6):1074-1075. author reply 6-7. EXC2. [pmid: 20160721].
830 Lotan Y, Bensalah K, Ruddell T, et al. Prospective evaluation of the clinical usefulness of reflex fluorescence in situ hybridization assay in patients with atypical cytology for the detection of urothelial carcinoma of the bladder. J Urol. Jun. 2008;179(6):2164-2169. EXC5. [pmid: 18423745].
831 Loughrey MB, Waring PM, Tan A, et al. Incorporation of somatic BRAF mutation testing into an algorithm for the investigation of hereditary non-polyposis colorectal cancer. Fam Cancer. 2007;6(3):301-310. EXC3. [pmid: 17453358].
832 Loukola A, de la Chapelle A, Aaltonen LA. Strategies for screening for hereditary non-polyposis colorectal cancer. J Med Genet. Nov. 1999;36(11):819-822. EXC4. [pmid: 10544224].
833 Loukola A, Eklin K, Laiho P, et al. Microsatellite marker analysis in screening for hereditary nonpolyposis colorectal cancer (HNPCC). Cancer Res. Jun. 1. 2001;61(11):4545-4549. EXC5. [pmid: 11389088].
834 Loukola A, Salovaara R, Kristo P, et al. Microsatellite instability in adenomas as a marker for hereditary nonpolyposis colorectal cancer. Am J Pathol. Dec. 1999;155(6):1849-1853. EXC4. [pmid: 10595914].
835 Loupakis F, Pollina L, Stasi I, et al. PTEN expression and KRAS mutations on primary tumors and metastases in the prediction of benefit from cetuximab plus irinotecan for patients with metastatic colorectal cancer. J Clin Oncol. Jun. 1. 2009;27(16):2622-2629. EXC3. [pmid: 19398573].
836 Loupakis F, Ruzzo A, Cremolini C, et al. KRAS codon 61, 146 and BRAF mutations predict resistance to cetuximab plus irinotecan in KRAS codon 12 and 13 wild-type metastatic colorectal cancer. Br J Cancer. Aug. 18. 2009;101(4):715-721. EXC5. [pmid: 19603018].
837 Lovig T, Thorstensen L, Hofstad B, et al. Genetic and protein markers related to in situ growth and multiplicity in small sporadic colorectal adenomas. Scand J Gastroenterol. Mar. 2003;38(3):298-306. EXC6. [pmid: 12737446].
838 Lowery MA, Gallagher DJ, Capanu M, et al. Clinical outcomes in patients age 40 or younger at diagnosis of synchronous metastatic colorectal cancer: A 20-year experience at Memorial Sloan-Kettering Cancer Center. J Clin Oncol. 2011;29(15). EXC6.
839 Lozano MD, Zulueta JJ, Echeveste JI, et al. Assessment of epidermal growth factor receptor and K-ras mutation status in cytological stained smears of non-small cell lung cancer patients: correlation with clinical outcomes. Oncologist. 2011;16(6):877-885. EXC5. [pmid: 21572125].
840 Lu HY, Mao WM, Cheng QY, et al. Mutation status of epidermal growth factor receptor and clinical features of patients with combined small cell lung cancer who received surgical treatment. Oncology Letters. 2012;3(6):1288-1292. EXC7. [pmid: 22783435].
841 Lucci-Cordisco E, Rovella V, Carrara S, et al. Mutations of the 'minor' mismatch repair gene MSH6 in typical and atypical hereditary nonpolyposis colorectal cancer. Fam Cancer. 2001;1(2):93-99. EXC4. [pmid: 14574004].
842 Ludovini V, Bellezza G, Pistola L, et al. High coexpression of both insulin-like growth factor receptor-1 (IGFR-1) and epidermal growth factor receptor (EGFR) is associated with shorter disease-free survival in resected non-small-cell lung cancer patients. Ann Oncol. May. 2009;20(5):842-849. EXC4. [pmid: 19153117].
843 Lund MJ, Mosunjac M, Davis KM, et al. 21-Gene recurrence scores: racial differences in testing, scores, treatment, and outcome. Cancer. Feb. 1. 2012;118(3):788-796. EXC6. [pmid: 21720988].
844 Luo D, Huang M, Zhang X, et al. Salvage treatment with erlotinib after gefitinib failure in advanced non-small-cell lung cancer patients with poor performance status: A matched-pair case-control study. Thoracic Cancer. 2012;3(1):27-33. EXC6.
845 Luo YH, Wu CH, Wu WS, et al. Association between tumor epidermal growth factor receptor mutation and pulmonary tuberculosis in patients with adenocarcinoma of the lungs. J Thorac Oncol. Feb. 2012;7(2):299-305. EXC6. [pmid: 22173705].
846 Lyda MH, Noffsinger A, Belli J, et al. Microsatellite instability and K-ras mutations in patients with ulcerative colitis. Hum Pathol. Jun. 2000;31(6):665-671. EXC4. [pmid: 10872658].
847 Ma ESK, Ng WK, Wong CLP. EGFR gene mutation study in cytology specimens. Acta Cytol. November-December. 2012;56(6):661-668. MEDLINE PMID 23207445 (http://www.ncbi.nlm.nih.gov/pubmed/23207445) FULL TEXT LINK http://dx.doi.org/10.1159/000343606. EXC6. [pmid: 23207445].
848 Ma F, Sun T, Shi Y, et al. Polymorphisms of EGFR predict clinical outcome in advanced non-small-cell lung cancer patients treated with Gefitinib. Lung Cancer. Oct. 2009;66(1):114-119. EXC3. [pmid: 19201048].
849 Macedo MP, Andrade Lde B, Coudry R, et al. Multiple mutations in the Kras gene in colorectal cancer: review of the literature with two case reports. Int J Colorectal Dis. Oct. 2011;26(10):1241-1248. EXC7. [pmid: 21603900].
850 Mack PC, Holland WS, Burich RA, et al. EGFR mutations detected in plasma are associated with patient outcomes in erlotinib plus docetaxel-treated non-small cell lung cancer. J Thorac Oncol. Dec. 2009;4(12):1466-1472. EXC4. [pmid: 19884861].
851 The impact of chemotherapeutic regiments on the cost-utility analysis of Onctype DX® assay. The European Breast Cancer Conference. 2012. March. Vienna, Austria. EXC5.
852 Maemondo M, Inoue A, Kobayashi K, et al. Gefitinib or chemotherapy for non-small-cell lung cancer with mutated EGFR. N Engl J Med. Jun. 24. 2010;362(25):2380-2388. EXC4. [pmid: 20573926].
853 Maffezzini M, Campodonico F, Capponi G, et al. Prognostic significance of fluorescent in situ hybridisation in the follow-up of non-muscle-invasive bladder cancer. Anticancer Res. Nov. 2010;30(11):4761-4765. EXC7. [pmid: 21115937].
854 Maffezzini M, Capponi G, Casazza S, et al. The UroVysion F.I.S.H. test compared to standard cytology for surveillance of non-muscle invasive bladder cancer. Arch Ital Urol Androl. Dec. 2008;80(4):127-131. EXC7. [pmid: 19235427].
855 Magnin S, Viel E, Baraquin A, et al. A multiplex SNaPshot assay as a rapid method for detecting KRAS and BRAF mutations in advanced colorectal cancers. J Molec Diagnost. 2011;13(5):485-492. EXC4.
856 Mak RH, Digumarthy SR, Muzikansky A, et al. Role of 18F-fluorodeoxyglucose positron emission tomography in predicting epidermal growth factor receptor mutations in non-small cell lung cancer. Oncologist. 2011;16(3):319-326. EXC8. [pmid: 21339258].
857 Malapelle U, Bellevicine C, Salatiello M, et al. Sanger sequencing in routine KRAS testing: A review of 1720 cases from a pathologist's perspective. J Clin Pathol. 2012;65(10):940-944. EXC6. [pmid: 22872705].
858 Malapelle U, Carlomagno C, Salatiello M, et al. KRAS mutation detection by high-resolution melting analysis significantly predicts clinical benefit of cetuximab in metastatic colorectal cancer. Br J Cancer. Aug. 7. 2012;107(4):626-631. EXC6. [pmid: 22805329].
859 Malesci A, Laghi L, Bianchi P, et al. Reduced likelihood of metastases in patients with microsatellite-unstable colorectal cancer. Clin Cancer Res. Jul. 1. 2007;13(13):3831-3839. EXC4. [pmid: 17606714].
860 Malo TL, Lipkus I, Wilson T, et al. Treatment Choices Based on OncotypeDx in the Breast Oncology Care Setting. J Cancer Epidemiol. 2012;2012:941495. Exc-6. [pmid: 22927848].
861 Mamounas E, Budd GT, Miller K. Incorporating the Oncotype DX breast cancer assay into community practice: An expert Q & A and case study sampling. Clin Adv Hematol Oncol. Feb. 2008;6(2):s1-s8. EXC2. [pmid: 18516819].
862 Manders P, Spruijt L, Kets CM, et al. Young age and a positive family history of colorectal cancer are complementary selection criteria for the identification of Lynch syndrome. Eur J Cancer. Jun. 2011;47(9):1407-1413. EXC3. [pmid: 21273057].
863 Manne SL, Chung DC, Weinberg DS, et al. Knowledge and attitudes about microsatellite instability testing among high-risk individuals diagnosed with colorectal cancer. Cancer Epidemiol Biomarkers Prev. Oct. 2007;16(10):2110-2117. EXC6. [pmid: 17932359].
864 Mao C, Zhou J, Yang Z, et al. KRAS, BRAF and PIK3CA mutations and the loss of PTEN expression in Chinese patients with colorectal cancer. PLoS One. 2012;7(5):e36653. EXC6. [pmid: 22586484].
865 Marchetti A, Felicioni L, Malatesta S, et al. Clinical features and outcome of patients with non-small-cell lung cancer harboring BRAF mutations. J Clin Oncol. 2011;29(26):3574-3579. EXC4. [pmid: 21825258].
866 Marchetti A, Martella C, Felicioni L, et al. EGFR mutations in non-small-cell lung cancer: analysis of a large series of cases and development of a rapid and sensitive method for diagnostic screening with potential implications on pharmacologic treatment. J Clin Oncol. Feb. 1. 2005;23(4):857-865. EXC6. [pmid: 15681531].
867 Marchetti A, Milella M, Felicioni L, et al. Clinical implications of KRAS mutations in lung cancer patients treated with tyrosine kinase inhibitors: an important role for mutations in minor clones. Neoplasia. Oct. 2009;11(10):1084-1092. EXC3. [pmid: 19794967].
868 Marchionni L, Wilson RF, Marinopoulos SS, et al. Impact of gene expression profiling tests on breast cancer outcomes (Structured abstract). Health Technology Assessment Database. 2008;(3):230. EXC1.
869 Marcus VA, Madlensky L, Gryfe R, et al. Immunohistochemistry for hMLHl and hMSH2: a practical test for DNA mismatch repair-deficient tumors. Am J Surg Pathol. Oct. 1999;23(10):1248-1255. EXC4. [pmid: 10524526].
870 Mariani P, Lae M, Degeorges A, et al. Concordant analysis of KRAS status in primary colon carcinoma and matched metastasis. Anticancer Res. Oct. 2010;30(10):4229-4235. EXC6. [pmid: 21036746].
871 Marisa L, de Reynies A, Duval A, et al. Gene expression classification of colon cancer into molecular subtypes: characterization, validation, and prognostic value. PLoS Med. 2013;10(5):e1001453. EXC4. [pmid: 23700391].
872 Markopoulos C, Xepapadakis G, Venizelos V, et al. Clinical experience of using Oncotype DX as an additional treatment decision tool in early breast cancer - a retrospective analysis from 5 Greek institutions. Eur J Surg Oncol. May. 2012;38(5):413-419. EXC6. [pmid: 22425282].
873 Markovic S, Antic J, Dragicevic N, et al. High-frequency microsatellite instability and BRAF mutation (V600E) in unselected Serbian patients with colorectal cancer. J Mol Histol. Apr. 2012;43(2):137-143. EXC7. [pmid: 22210186].
874 Marks JL, Broderick S, Zhou Q, et al. Prognostic and therapeutic implications of EGFR and KRAS mutations in resected lung adenocarcinoma. J Thorac Oncol. Feb. 2008;3(2):111-116. EXC6. [pmid: 18303429].
875 Martin V, Landi L, Molinari F, et al. HER2 gene copy number status may influence clinical efficacy to anti-EGFR monoclonal antibodies in metastatic colorectal cancer patients. Br J Cancer. Feb. 19. 2013;108(3):668-675. EXC3. [pmid: 23348520].
876 Martinez-Lopez E, Abad A, Font A, et al. Allelic loss on chromosome 18q as a prognostic marker in stage II colorectal cancer. Gastroenterology. Jun. 1. 1998;14(6):1180-1187. EXC4. [pmid: 9609754].
877 Martinez-Navarro EM, Rebollo J, Gonzalez-Manzano R, et al. Epidermal growth factor receptor (EGFR) mutations in a series of non-small-cell lung cancer (NSCLC) patients and response rate to EGFR-specific tyrosine kinase inhibitors (TKIs). Clin Transl Oncol. Nov. 2011;13(11):812-818. EXC3. [pmid: 22082647].
878 Masago K, Fujita S, Mio T, et al. Accuracy of epidermal growth factor receptor gene mutation analysis by direct sequencing method based on small biopsy specimens from patients with non-small cell lung cancer: analysis of results in 19 patients. Int J Clin Oncol. Oct. 2008;13(5):442-446. EXC5. [pmid: 18946755].
879 Masago K, Fujita S, Togashi Y, et al. Clinical significance of epidermal growth factor receptor mutations and insulin-like growth factor 1 and its binding protein 3 in advanced non-squamous non-small cell lung cancer. Oncol Rep. Oct. 2011;26(4):795-803. EXC6. [pmid: 21805046].
880 Masago K, Fujita S, Togashi Y, et al. Clinicopathologic factors affecting the progression-free survival of patients with advanced non-small-cell lung cancer after gefitinib therapy. Clin Lung Cancer. Jan. 2011;12(1):56-61. EXC6. [pmid: 21273181].
881 Mascaux C, Wynes MW, Kato Y, et al. EGFR protein expression in non-small cell lung cancer predicts response to an EGFR tyrosine kinase inhibitor--a novel antibody for immunohistochemistry or AQUA technology. Clin Cancer Res. Dec. 15. 2011;17(24):7796-7807. EXC4. [pmid: 21994417].
882 Massa MJ, Iniesta P, Gonzalez-Quevedo R, et al. Differential prognosis of replication error phenotype and loss of heterozygosity in sporadic colorectal cancer. Eur J Cancer. Nov. 1999;35(12):1676-1682. EXC4. [pmid: 10674012].
883 Masubuchi S, Konishi F, Togashi K, et al. The significance of microsatellite instability in predicting the development of metachronous multiple colorectal carcinomas in patients with nonfamilial colorectal carcinoma. Cancer. May. 1. 1999;85(9):1917-1924. EXC4. [pmid: 10223230].
884 Masuda H, Abe Y, Takayama T. Microsatellite instability in poorly differentiated colorectal adenocarcinoma, particularly in relation to two subtypes. Hepatogastroenterology. Jan-Feb. 2005;52(61):82-85. EXC4. [pmid: 15783000].
885 Matsumoto S, Iwakawa R, Kohno T, et al. Frequent EGFR mutations in noninvasive bronchioloalveolar carcinoma. Int J Cancer. May. 15. 2006;118(10):2498-2504. Inc. [pmid: 16353158].
886 Matsuo K, Hiraki A, Ito H, et al. Soy consumption reduces the risk of non-small-cell lung cancers with epidermal growth factor receptor mutations among Japanese. Cancer Sci. Jun. 2008;99(6):1202-1208. EXC8. [pmid: 18429954].
887 Matsuo K, Ito H, Yatabe Y, et al. Risk factors differ for non-small-cell lung cancers with and without EGFR mutation: assessment of smoking and sex by a case-control study in Japanese. Cancer Sci. Jan. 2007;98(1):96-101. EXC8. [pmid: 17054433].
888 Matsuoka H, Kurata T, Okamoto I, et al. Clinical response to crizotinib retreatment after acquisition of drug resistance. J Clin Oncol. Jul. 1. 2013;31(19):e322-e323. EXC7. [pmid: 23715571].
889 Maughan TS, Adams RA, Smith CG, et al. Addition of cetuximab to oxaliplatin-based first-line combination chemotherapy for treatment of advanced colorectal cancer: results of the randomised phase 3 MRC COIN trial. Lancet. Jun. 18. 2011;377(9783):2103-2114. EXC6. [pmid: 21641636].
890 Maus MKH, Stephens C, Zeger G, et al. Identification of novel variant of EML4-ALK fusion gene in NSCLC: Potential benefits of the RT-PCR method. International Journal of Biomedical Science. 2012;8(1):1-6. EXC6.
891 Mazieres J, Peters S, Lepage B, et al. Lung cancer that harbors an HER2 mutation: epidemiologic characteristics and therapeutic perspectives. J Clin Oncol. Jun. 1. 2013;31(16):1997-2003. EXC4. [pmid: 23610105].
892 Mazzoni F, Rotella V, Pratesi N, et al. From clinical trials to clinical practice: predictors of response to erlotinib in advanced non-small cell lung cancer patients pretreated with chemotherapy. Tumori. Mar-Apr. 2011;97(2):160-165. EXC3. [pmid: 21617709].
893 McGregor DK, Wu TT, Rashid A, et al. Reduced expression of cytokeratin 20 in colorectal carcinomas with high levels of microsatellite instability. Am J Surg Pathol. Jun. 2004;28(6):712-718. EXC6. [pmid: 15166663].
894 McLeer-Florin A, Moro-Sibilot D, Melis A, et al. Dual IHC and FISH testing for ALK gene rearrangement in lung adenocarcinomas in a routine practice: a French study. J Thorac Oncol. Feb. 2012;7(2):348-354. EXC6. [pmid: 22071784].
895 McMillen E, Ye F, Li G, et al. Epidermal growth factor receptor (EGFR) mutation and p-EGFR expression in resected non-small cell lung cancer. Exp Lung Res. Nov. 2010;36(9):531-537. EXC6. [pmid: 20939760].
896 McPhillips M, Meldrum CJ, Creegan R, et al. Deletion mutations in an Australian series of HNPCC patients. Hereditary Cancer in Clinical Practice. 2005;3(1):43-47. EXC4. [pmid: 20223028].
897 McShane LM, Cavenagh MM, Lively TG, et al. Criteria for the use of omics-based predictors in clinical trials. Nature. Oct. 17. 2013;502(7471):317-320. EXC7. [pmid: 24132288].
898 Mead LJ, Jenkins MA, Young J, et al. Microsatellite instability markers for identifying early-onset colorectal cancers caused by germ-line mutations in DNA mismatch repair genes. Clin Cancer Res. May. 15. 2007;13(10):2865-2869. EXC4. [pmid: 17504984].
899 Mekenkamp LJ, Heesterbeek KJ, Koopman M, et al. Mucinous adenocarcinomas: poor prognosis in metastatic colorectal cancer. Eur J Cancer. Mar. 2012;48(4):501-509. EXC4. [pmid: 22226571].
900 Melcher R, Hartmann E, Zopf W, et al. LOH and copy neutral LOH (cnLOH) act as alternative mechanism in sporadic colorectal cancers with chromosomal and microsatellite instability. Carcinogenesis. Apr. 2011;32(4):636-642. EXC4. [pmid: 21297112].
901 Melloni G, Doglioni C, Bandiera A, et al. Prognostic factors and analysis of microsatellite instability in resected pulmonary metastases from colorectal carcinoma. Ann Thorac Surg. Jun. 2006;81(6):2008-2013. EXC5. [pmid: 16731121].
902 Mencoboni M, Bergaglio M, Serra M, et al. Maintenance therapy with gefitinib after first-line chemotherapy in patients affected by advanced non-small cell lung cancer. Anticancer Res. Nov-Dec. 2007;27(6C):4425-4429. EXC4. [pmid: 18214055].
903 Meng WJ, Sun XF, Tian C, et al. Microsatellite instability did not predict individual survival in sporadic stage II and III rectal cancer patients. Oncology. 2007;72(1-2):82-88. EXC5. [pmid: 18004081].
904 Meng WJ, Wang L, Tian C, et al. Novel mutations and sequence variants in exons 3-9 of human T cell factor-4 gene in sporadic rectal cancer patients stratified by microsatellite instability. World J Gastroenterol. Jul. 21. 2007;13(27):3747-3751. EXC6. [pmid: 17659738].
905 Meng X, Loo BW Jr, Ma L, et al. Molecular imaging with 11C-PD153035 PET/CT predicts survival in non-small cell lung cancer treated with EGFR-TKI: a pilot study. J Nucl Med. Oct. 2011;52(10):1573-1579. EXC4. [pmid: 21903741].
906 Mengual L, Marin-Aguilera M, Ribal MJ, et al. Clinical utility of fluorescent in situ hybridization for the surveillance of bladder cancer patients treated with bacillus Calmette-Guerin therapy. Eur Urol. Sep. 2007;52(3):752-759. EXC3. [pmid: 17379395].
907 Menon AG, Morreau H, Tollenaar RA, et al. Down-regulation of HLA-A expression correlates with a better prognosis in colorectal cancer patients. Lab Invest. Dec. 2002;82(12):1725-1733. EXC5. [pmid: 12480922].
908 Merrick DT, Kittelson J, Winterhalder R, et al. Analysis of c-ErbB 1/epidermal growth factor receptor and c-ErbB2/HER-2 expression in bronchial dysplasia: evaluation of potential targets for chemoprevention of lung cancer. Clin Cancer Res. Apr. 1. 2006;12(7 Pt 1):2281-2288. EXC3. [pmid: 16609045].
909 Messerini L, Ciantelli M, Baglioni S, et al. Prognostic significance of microsatellite instability in sporadic mucinous colorectal cancers. HumPathol. Jun. 1999;30(6):629-634. EXC4. [pmid: 10374769].
910 Messerini L, Vitelli F, De Vitis LR, et al. Microsatellite instability in sporadic mucinous colorectal carcinomas: relationship to clinico-pathological variables. J Pathol. Aug. 1997;182(4):380-384. EXC6. [pmid: 9306957].
911 Messick CA, Sanchez J, Dejulius KL, et al. Genetic and molecular diversity of colon cancer hepatic metastases. Surgery. Aug. 2009;146(2):227-231. EXC3. [pmid: 19628078].
912 Metro G, Chiari R, Duranti S, et al. Impact of specific mutant KRAS on clinical outcome of EGFR-TKI-treated advanced non-small cell lung cancer patients with an EGFR wild type genotype. Lung Cancer. 2012;78(1):81-86. EXC3. [pmid: 22770374].
913 Metro G, Crino L. The LUX-Lung clinical trial program of afatinib for non-small-cell lung cancer. Expert Rev Anticancer Ther. May. 2011;11(5):673-682. EXC6. [pmid: 21554040].
914 Michael-Robinson JM, Biemer-Huttmann A, Purdie DM, et al. Tumour infiltrating lymphocytes and apoptosis are independent features in colorectal cancer stratified according to microsatellite instability status. Gut. Mar. 2001;48(3):360-366. EXC4. [pmid: 11171826].
915 Michael-Robinson JM, Pandeya N, Walsh MD, et al. Characterization of tumour-infiltrating lymphocytes and apoptosis in colitis-associated neoplasia: comparison with sporadic colorectal cancer. J Pathol. Feb. 2006;208(3):381-387. EXC4. [pmid: 16315333].
916 Michael-Robinson JM, Reid LE, Purdie DM, et al. Proliferation, apoptosis, and survival in high-level microsatellite instability sporadic colorectal cancer. Clin Cancer Res. Aug. 2001;7(8):2347-2356. EXC4. [pmid: 11489812].
917 Michalopoulos NV, Saetta AA, Lazaris AC, et al. Microsatellite instability in sporadic and inherited colon adenocarcinomas from Greek patients: correlation with several clinicopathological characteristics. Acta Gastroenterol Belg. Jul-Sep. 2005;68(3):294-301. EXC4. [pmid: 16268414].
918 Midgley RS, Church D, Kerr DJ. The emergence of 'omics for the management of colorectal cancer. Curr Opin Oncol. Jul. 2011;23(4):410-414. EXC2. [pmid: 21577111].
919 Miglio U, Mezzapelle R, Paganotti A, et al. Mutation analysis of KRAS in primary colorectal cancer and matched metastases by means of highly sensitivity molecular assay. Pathol Res Pract. Apr. 2013;209(4):233-236. EXC3. [pmid: 23538047].
920 Mihaylova Z, Ludovini V, Gregorg V, et al. Serum level changes of matrix metalloproteinases 2 and 9, vascular endothelial growth factor and epidermal growth factor receptor during platinum-based chemotherapy in advanced non-small cell lung cancer patients. J BUON. Jan-Mar. 2007;12(1):105-111. EXC6. [pmid: 17436410].
921 Miladi-Abdennadher I, Abdelmaksoud-Damak R, Ayadi L, et al. Expression of pl6INK4a, alone or combined with p53, is predictive of better prognosis in colorectal adenocarcinoma in Tunisian patients. Appl Immunohistochem Mol Morphol. Dec. 2011;19(6):562-568. EXC4. [pmid: 22095233].
922 Miller VA, Hirsh V, Cadranel J, et al. Afatinib versus placebo for patients with advanced, metastatic non-small-cell lung cancer after failure of erlotinib, gefitinib, or both, and one or two lines of chemotherapy (LUX-Lung 1): a phase 2b/3 randomised trial. Lancet Oncol. May. 2012;13(5):528-538. EXC3. [pmid: 22452896].
923 Miller VA, Riely GJ, Zakowski MF, et al. Molecular characteristics of bronchioloalveolar carcinoma and adenocarcinoma, bronchioloalveolar carcinoma subtype, predict response to erlotinib. J Clin Oncol. Mar. 20. 2008;26(9):1472-1478. EXC3. [pmid: 18349398].
924 Milne RL, Antoniou AC. Genetic modifiers of cancer risk for BRCA1 and BRCA2 mutation carriers. Ann Oncol. Jan. Suppl 1. 2011;22:i11-i17. EXC7. [pmid: 21285145].
925 Milton DT, Azzoli CG, HeelanRT, et al. A phase I/II study of weekly high-dose erlotinib in previously treated patients with nonsmall cell lung cancer. Cancer. Sep. 1. 2006;107(5):1034-1041. EXC3. [pmid: 16878326].
926 Mimae T, Tsuta K, Maeshima AM, et al. Cathepsin D as a potential prognostic marker for lung adenocarcinoma. Pathology Research and Practice. 2012;208(9):534-540. EXC4.
927 Mina L, Soule SE, Badve S, et al. Predicting response to primary chemotherapy: gene expression profiling of paraffin-embedded core biopsy tissue. Breast Cancer Res Treat. Jun. 2007;103(2):197-208. EXC6. [pmid: 17039265].
928 Mino-Kenudson M, Mark EJ. Reflex testing for epidermal growth factor receptor mutation and anaplastic lymphoma kinase fluorescence in situ hybridization in non-small cell lung cancer. Arch Pathol Lab Med. May. 2011;135(5):655-664. EXC1. [pmid: 21526964].
929 Miquel C, Jacob S, Grandjouan S, et al. Frequent alteration of DNA damage signalling and repair pathways in human colorectal cancers with microsatellite instability. Oncogene. Aug. 30. 2007;26(40):5919-5926. EXC5. [pmid: 17384679].
930 Mirchev MB, Kahl P, Friedrichs N, et al. DNA methylation in patients with colorectal cancer-correlation with some clinical and morphological features and with local tumour invasion. Folia Med (Plovdiv). Apr-Jun. 2010;52(2):22-30. EXC6. [pmid: 20836393].
931 Mitchell EP, Piperdi B, Lacouture ME, et al. The efficacy and safety of panitumumab administered concomitantly with FOLFIRI or Irinotecan in second-line therapy for metastatic colorectal cancer: the secondary analysis from STEPP (Skin Toxicity Evaluation Protocol With Panitumumab) by KRAS status. Clin Colorectal Cancer. Dec. 2011;10(4):333-339. EXC4. [pmid: 22000810].
932 Mitiushkina NV, Iyevleva AG, Poltoratskiy AN, et al. Detection of EGFR mutations and EML4-ALK rearrangements in lung adenocarcinomas using archived cytological slides. Cancer Cytopathol. Jul. 2013;121(7):370-376. EXC4. [pmid: 23408463].
933 Mitsudomi T, Morita S, Yatabe Y, et al. Gefitinib versus cisplatin plus docetaxel in patients with non-small-cell lung cancer harbouring mutations of the epidermal growth factor receptor (WJTOG3405): an open label, randomised phase 3 trial. Lancet Oncol. Feb. 2010;11(2):121-128. EXC6. [pmid: 20022809].
934 Mittmann N, Au HJ, Tu D, et al. Prospective cost-effectiveness analysis of cetuximab in metastatic colorectal cancer: Evaluation of national cancer institute of Canada clinical trials group CO.17 Trial. J Natl Cancer Inst. 2009;101(17):1182-1192. EXC6. [pmid: 19666851].
935 Miura N, Nakamura H, Sato R, et al. Clinical usefulness of serum telomerase reverse transcriptase (hTERT) mRNA and epidermal growth factor receptor (EGFR) mRNA as a novel tumor marker for lung cancer. Cancer Sci. Dec. 2006;97(12):1366-1373. EXC4. [pmid: 17052260].
936 Miyazawa H, Tanaka T, Nagai Y, et al. Peptide nucleic acid-locked nucleic acid polymerase chain reaction clamp-based detection test for gefitinib-refractory T790M epidermal growth factor receptor mutation. Cancer Sci. Mar. 2008;99(3):595-600. EXC3. [pmid: 18271876].
937 Mizota A, Shitara K, Kondo C, et al. Retrospective analysis of cetuximab monotherapy for patients with irinotecan-intolerant metastatic colorectal cancer. Int J Clin Oncol. Aug. 2011;16(4):416-420. EXC5. [pmid: 21437572].
938 Moatamed NA, Apple SK, Bennett CJ, et al. Exclusion of the uniform tetraploid cells significantly improves specificity of the urine FISH assay. Diagn Cytopathol. Mar. 2013;41(3):218-225. EXC5. [pmid: 21987521].
939 Modest DP, Jung A, Moosmann N, et al. The influence of KRAS and BRAF mutations on the efficacy of cetuximab-based first-line therapy of metastatic colorectal cancer: an analysis of the AIO KRK-0104-trial. Int J Cancer. Aug. 15. 2012;131(4):980-986. EXC3. [pmid: 21960311].
940 Moghbeli M, Moaven O, Dadkhah E, et al. High frequency of microsatellite instability in sporadic colorectal cancer patients in Iran. Genet Mol Res. 2011;10(4):3520-3529. EXC6. [pmid: 22194204].
941 Mok TS, Wu YL, Thongprasert S, et al. Gefitinib or carboplatin-paclitaxel in pulmonary adenocarcinoma. N Engl J Med. Sep. 3. 2009;361(10):947-957. EXC3. [pmid: 19692680].
942 Molinari F, Felicioni L, Buscarino M, et al. Increased detection sensitivity for KRAS mutations enhances the prediction of anti-EGFR monoclonal antibody resistance in metastatic colorectal cancer. Clin Cancer Res. Jul. 15. 2011;17(14):4901-4914. EXC6. [pmid: 21632860].
943 Monaco SE, Nikiforova MN, Cieply K, et al. A comparison of EGFR and KRAS status in primary lung carcinoma and matched metastases. HumPathol. Jan. 2010;41(1):94-102. EXC6. [pmid: 19740513].
944 Montagut C, Iglesias M, Arumi M, et al. Mitogen-activated protein kinase phosphatase-1 (MKP-1) impairs the response to anti-epidermal growth factor receptor (EGFR) antibody cetuximab in metastatic colorectal cancer patients. Br J Cancer. 2010;102(7):1137-1144. EXC6. [pmid: 20234366].
945 Montomoli J, Jacques S, Hamilton D, et al. Retrospective analysis of KRAS status in metastatic colorectal cancer patients: A single-center feasibility study. Clinical and Experimental Gastroenterology. 2012;5(1):167-171. EXC3. [pmid: 23028236].
946 Mook S, Bonnefoi H, Pruneri G, et al. Daily clinical practice of fresh tumour tissue freezing and gene expression profiling; logistics pilot study preceding the MIND ACT trial. Eur J Cancer. May. 2009;45(7):1201-1208. EXC6. [pmid: 19232484].
947 Mook S, Van't Veer LJ, Rutgers EJ, et al. Individualization of therapy using Mammaprint: from development to the MIND ACT Trial. Cancer Genomics Proteomics. May-Jun. 2007;4(3):147-155. EXC3. [pmid: 17878518].
948 Moonen PM, Merkx GF, Peelen P, et al. UroVysion compared with cytology and quantitative cytology in the surveillance of non-muscle-invasive bladder cancer. Eur Urol. May. 2007;51(5):1275-1280. discussion 80. EXC6. [pmid: 17084511].
949 Moore AM, Einhorn LH, Estes D, et al. Gefitinib in patients with chemo-sensitive and chemo-refractory relapsed small cell cancers: a Hoosier Oncology Group phase II trial. Lung Cancer. Apr. 2006;52(1):93-97. EXC4. [pmid: 16488055].
950 Moosmann N, von Weikersthal LF, Vehling-Kaiser U, et al. Cetuximab plus capecitabine and irinotecan compared with cetuximab plus capecitabine and oxaliplatin as first-line treatment for patients with metastatic colorectal cancer: AIO KRK-0104-a randomized trial of the German AIO CRC study group. J Clin Oncol. Mar. 10. 2011;29(8):1050-1058. EXC5. [pmid: 21300933].
951 Moran T, Sequist LV. Timing of epidermal growth factor receptor tyrosine kinase inhibitor therapy in patients with lung cancer with EGFR mutations. J Clin Oncol. 2012;30(27):3330-3336. EXC6. [pmid: 22753908].
952 Morandi L, De Biase D, Visard M, et al. T[20] repeat in the 3'-untranslated region of the MT1X gene: A marker with high sensitivity and specificity to detect microsatellite instability in colorectal cancer. Int J Colorectal Dis. 2012;27(5):647-656. EXC4. [pmid: 22108904].
953 Mori Y, Selaru FM, Sato F, et al. The impact of microsatellite instability on the molecular phenotype of colorectal tumors. Cancer Res. Aug. 1. 2003;63(15):4577-4582. EXC4. [pmid: 12907634].
954 Morifuji M, Hiyama E, Murakami Y, et al. Fluorescent-based BAT-26 analysis for distinct screening of microsatellite instability in colorectal cancers. Int J Oncol. Apr. 2003;22(4):807-813. EXC4. [pmid: 12632072].
955 Morikawa T, Kuchiba A, Qian ZR, et al. Prognostic significance and molecular associations of tumor growth pattern in colorectal cancer. Ann Surg Oncol. Jun. 2012;19(6):1944-1953. EXC4. [pmid: 22189472].
956 Morikawa T, Kuchiba A, Yamauchi M, et al. Association of CTNNB1 (beta-catenin) alterations, body mass index, and physical activity with survival in patients with colorectal cancer. JAMA. Apr. 27. 2011;305(16):1685-1694. EXC4. [pmid: 21521850].
957 Morinaga R, Okamoto I, Fujita Y, et al. Association of epidermal growth factor receptor (EGFR) gene mutations with EGFR amplification in advanced non-small cell lung cancer. Cancer Sci. Dec. 2008;99(12):2455-2460. EXC6. [pmid: 18957054].
958 Moroni M, Veronese S, Benvenuti S, et al. Gene copy number for epidermal growth factor receptor (EGFR) and clinical response to antiEGFR treatment in colorectal cancer: a cohort study. Lancet Oncol. May. 2005;6(5):279-286. EXC6. [pmid: 15863375].
959 Morris PG, Reiner AS, Szenberg OR, et al. Leptomeningeal metastasis from non-small cell lung cancer: survival and the impact of whole brain radiotherapy. J Thorac Oncol. Feb. 2012;7(2):382-385. EXC5. [pmid: 22089116].
960 Mostert B, Jiang Y, Sieuwerts AM, et al. KRAS and BRAF mutation status in circulating colorectal tumor cells and their correlation with primary and metastatic tumor tissue. Int J Cancer. Jul. 2013;133(1):130-141. EXC6. [pmid: 23233388].
961 Motoi N, Szoke J, Riely GJ, et al. Lung adenocarcinoma: modification of the 2004 WHO mixed subtype to include the major histologic subtype suggests correlations between papillary and micropapillary adenocarcinoma subtypes, EGFR mutations and gene expression analysis. Am J Surg Pathol. Jun. 2008;32(6):810-827. EXC6. [pmid: 18391747].
962 Mrkonjic M, Roslin NM, Greenwood CM, et al. Specific variants in the MLH1 gene region may drive DNA methylation, loss of protein expression, and MSI-H colorectal cancer. PLoS One. 2010;5(10):el3314. EXC4. [pmid: 20967208].
963 Mu XL, Li LY, Zhang XT, et al. Gefitinib-sensitive mutations of the epidermal growth factor receptor tyrosine kinase domain in Chinese patients with non-small cell lung cancer. Clin Cancer Res. Jun. 15. 2005;11(12):4289-4294. EXC6. [pmid: 15958609].
964 Mueller J, Gazzoli I, Bandipalliam P, et al. Comprehensive molecular analysis of mismatch repair gene defects in suspected Lynch syndrome (hereditary nonpolyposis colorectal cancer) cases. Cancer Res. Sep. 1. 2009;69(17):7053-7061. EXC5. [pmid: 19690142].
965 Mukohara T, Engelman JA, Hanna NH, et al. Differential effects of gefitinib and cetuximab on non-small-cell lung cancers bearing epidermal growth factor receptor mutations. J Natl Cancer Inst. 2005;97(16):1185-1194. EXC4. [pmid: 16106023].
966 Mukohara T, Kudoh S, Yamauchi S, et al. Expression of epidermal growth factor receptor (EGFR) and downstream-activated peptides in surgically excised non-small-cell lung cancer (NSCLC). Lung Cancer. Aug. 2003;41(2):123-130. EXC4. [pmid: 12871775].
967 Miiller CI, Schulmann K, Reinacher-Schick A, et al. Predictive and prognostic value of microsatellite instability in patients with advanced colorectal cancer treated with a fluoropyrimidine and oxaliplatin containing first-line chemotherapy. A report of the AIO Colorectal Study Group. Int J Colorectal Dis. 2008;(11):1033-1039. EXC3. [pmid: 18594845].
968 Mumby PB, Lo SS, Norton J, et al. Prospective multi-center study of the impact of the 21-gene recurrence score assay on patient satisfaction, anxiety arid decisional conflict for adjuvant breast cancer treatment selection. Breast Cancer Res Treat. Dec. 2007;106(1 suppl):S73-S74. EXC6.
969 Munfus-McCray D, Cui M, Zhang Z, et al. Comparison of EGFR and KRAS mutations in primary and unpaired metastatic lung adenocarcinoma with potential chemotherapy effect. HumPathol. Jul. 2013;44(7):1286-1292. EXC6. [pmid: 23337026].
970 Munfus-Mccray D, Harada S, Adams C, et al. EGFR and KRAS mutations in metastatic lung adenocarcinomas. Hum Pathol. 2011;42(10):1447-1453. EXC5. [pmid: 21497370].
971 Murakami H, Tamura T, Takahashi T, et al. Phase I study of continuous afatinib (BIB W 2992) in patients with advanced non-small cell lung cancer after prior chemotherapy/erlotinib/gefitinib (LUX-Lung 4). Cancer Chemother Pharmacol. Apr. 2012;69(4):891-899. EXC6. [pmid: 22071596].
972 Murata S, Iseki M, Kinjo M, et al. Molecular and immunohistologic analyses cannot reliably solve diagnostic variation of flat intraepithelial lesions of the urinary bladder. Am J ClinPathol. Dec. 2010;134(6):862-872. EXC5. [pmid: 21088148].
973 Murphy KM, Zhang S, Geiger T, et al. Comparison of the microsatellite instability analysis system and the Bethesda panel for the determination of microsatellite instability in colorectal cancers. J Mol Diagn. Jul. 2006;8(3):305-311. EXC5. [pmid: 16825502].
974 Murray S, Karavasilis V, Bobos M, et al. Molecular predictors of response to tyrosine kinase inhibitors in patients with Non-Small-Cell Lung Cancer. J Exp Clin Cancer Res. 2012;31:77. EXC3. [pmid: 22992338].
975 Murray S, Timotheadou E, Linardou H, et al. Mutations of the epidermal growth factor receptor tyrosine kinase domain and associations with clinicopathological features in non-small cell lung cancer patients. Lung Cancer. May. 2006;52(2):225-233. EXC6. [pmid: 16567021].
976 Mvundura M, Grosse SD, Hampel H, et al. The cost-effectiveness of genetic testing strategies for Lynch syndrome among newly diagnosed patients with colorectal cancer (Structured abstract). Genetics in Medicine. 2010;(2):93-104. EXC6. [pmid: 20084010].
977 Na II, Rho JK, Choi YJ, et al. Clinical features reflect exon sites of EGFR mutations in patients with resected non-small-cell lung cancer. J Korean Med Sci. Jun. 2007;22(3):393-399. EXC6. [pmid: 17596643].
978 Na II, Rho JK, Choi YJ, et al. The survival outcomes of patients with resected non-small cell lung cancer differ according to EGFR mutations and the P21 expression. Lung Cancer. Jul. 2007;57(1):96-102. EXC5. [pmid: 17337084].
979 Na KY, Kim KS, Lee JE, et al. The 70-gene prognostic signature for korean breast cancer patients. Journal of Breast Cancer. 2011;14(1):33-38. EXC5. [pmid: 21847392].
980 Nagai Y, Miyazawa H, Huqun, et al. Genetic heterogeneity of the epidermal growth factor receptor in non-small cell lung cancer cell lines revealed by a rapid and sensitive detection system, the peptide nucleic acid-locked nucleic acid PCR clamp. Cancer Res. Aug. 15. 2005;65(16):7276-7282. EXC6. [pmid: 16105816].
981 Nagasaka T, Koi M, Kloor M, et al. Mutations in both KRAS and BRAF may contribute to the methylator phenotype in colon cancer. Gastroenterology. Jun. 2008;134(7):1950-1960. 60 e1. EXC4. [pmid: 18435933].
982 Nagasaka T, Sasamoto H, Notohara K, et al. Colorectal cancer with mutation in BRAF, KRAS, and wild-type with respect to both oncogenes showing different patterns of DNA methylation. J Clin Oncol. Nov. 15. 2004;22(22):4584-4594. EXC4. [pmid: 15542810].
983 Naghibalhossaini F, Mokarram P, Khalili I, et al. MTHFR C677T and A1298C variant genotypes and the risk of microsatellite instability among Iranian colorectal cancer patients. Cancer Genet Cytogenet. Mar. 2010;197(2):142-151. EXC6. [pmid: 20193847].
984 Naguib A, Mitrou PN, Gay LJ, et al. Dietary, lifestyle and clinicopathological factors associated with BRAF and K-ras mutations arising in distinct subsets of colorectal cancers in the EPIC Norfolk study. BMC Cancer. 2010;10:99. EXC4. [pmid: 20233436].
985 Naidoo R, Tarin M, Chetty R. A comparative microsatellite analysis of colorectal cancer in patients <35 years and >50 years of age. Am J Gastroenterol. Nov. 2000;95(11):3266-3275. EXC4. [pmid: 11095352].
986 Nakagawa H, Nagasaka T, Cullings HM, et al. Efficient molecular screening of Lynch syndrome by specific 3' promoter methylation of the MLH1 or BRAF mutation in colorectal cancer with high-frequency microsatellite instability. Oncol Rep. 2009;21(6):1577-1583. EXC4. [pmid: 19424639].
987 Nakagawa H, Nuovo GJ, Zervos EE, et al. Age-related hypermethylation of the 5' region of MLH1 in normal colonic mucosa is associated with microsatellite-unstable colorectal cancer development. Cancer Res. Oct. 1. 2001;61(19):6991-6995. EXC6. [pmid: 11585722].
988 Nakagawa M, Uramoto H, Shimokawa H, et al. Insulin-like growth factor receptor-1 expression predicts postoperative recurrence in adenocarcinoma of the lung. Experimental and Therapeutic Medicine. 2011;2(4):585-590. EXC4. [pmid: 22977544].
989 Nakajima T, Kimura H, Takeuchi K, et al. Treatment of lung cancer with an ALK inhibitor after EML4-ALK fusion gene detection using endobronchial ultrasound-guided transbronchial needle aspiration. J Thorac Oncol. 2010;5(12):2041-2042. EXC2. [pmid: 21102268].
990 Nakajima T, Yasufuku K, Nakagawara A, et al. Multigene mutation analysis of metastatic lymph nodes in non-small cell lung cancer diagnosed by endobronchial ultrasound-guided transbronchial needle aspiration. Chest. Nov. 2011;140(5):1319-1324. EXC4. [pmid: 21527506].
991 Nakamura T, Sueoka-Aragane N, Iwanaga K, et al. Application of a highly sensitive detection system for epidermal growth factor receptor mutations in plasma DNA. J Thorac Oncol. Sep. 2012;7(9):1369-1381. EXC4. [pmid: 22858585].
992 Nash GM, Gimbel M, Cohen AM, et al. KRAS mutation and microsatellite instability: two genetic markers of early tumor development that influence the prognosis of colorectal cancer. Ann Surg Oncol. Feb. 2010;17(2):416-424. EXC7. [pmid: 19813061].
993 Nash GM, Gimbel M, Shia J, et al. Automated, multiplex assay for high-frequency microsatellite instability in colorectal cancer. J Clin Oncol. Aug. 15. 2003;21(16):3105-3112. EXC4. [pmid: 12915601].
994 Nash GM, Gimbel M, Shia J, et al. KRAS mutation correlates with accelerated metastatic progression in patients with colorectal liver metastases. Ann Surg Oncol. Feb. 2010;17(2):572-578. EXC7. [pmid: 19727962].
995 Natale RB, Bodkin D, Govindan R, et al. Vandetanib versus gefitinib in patients with advanced non-small-cell lung cancer: results from a two-part, double-blind, randomized phase ii study. J Clin Oncol. May. 20. 2009;27(15):2523-2529. EXC4. [pmid: 19332730].
996 National Cancer Institute at the National Institutes of Health. Cancer Staging. Bethesda, MD. National Cancer Institute. www.cancer.gov/cancertopics/factsheet/detection/staging. EXC8.
997 National Institute for Health and Care Excellence. Gene expression profiling and expanded immunohistochemistry tests for guiding adjuvant chemotherapy decisions in early breast cancer management: MammaPrint, Oncotype DX, IHC4 and Mammostrat. NICE diagnostics guidance 10. London. NICE. 2013. www.nice.org.uk/dg10. Accessed on January 8, 2014. EXC1.
998 Negri FV, Campanini N, Camisa R, et al. Biological predictive factors in rectal cancer treated with preoperative radiotherapy or radiochemotherapy. Br J Cancer. Jan. 15. 2008;98(1):143-147. EXC7. [pmid: 18087284].
999 Nehls O, Hass HG, Okech T, et al. Prognostic implications of BAX protein expression and microsatellite instability in all non-metastatic stages of primary colon cancer treated by surgery alone. Int J Colorectal Dis. Jun. 2009;24(6):655-663. EXC5. [pmid: 19221769].
1000 Nehls O, Okech T, Hsieh CJ, et al. Studies on p53, BAX and Bcl-2 protein expression and microsatellite instability in stage III (UICC) colon cancer treated by adjuvant chemotherapy: major prognostic impact of proapoptotic BAX. Br J Cancer. May. 7. 2007;96(9):1409-1418. EXC4. [pmid: 17426704].
1001 Nemunaitis J, Klemow S, Tong A, et al. Prognostic value of K-ras mutations, ras oncoprotein, and c-erb B-2-oncoprotein expression in adenocarcinoma of the lung. American Journal of Clinical Oncology: Cancer Clinical Trials. 1998;21(2):155-160. EXC6.
1002 Neninger E, Verdecia BG, Crombet T, et al. Combining an EGF-based cancer vaccine with chemotherapy in advanced nonsmall cell lung cancer. J Immunother. Jan. 2009;32(1):92-99. EXC4. [pmid: 19307998].
1003 Neumann J, Horst D, Kriegl L, et al. A simple immunohistochemical algorithm predicts the risk of distant metastases in right-sided colon cancer. Histopathology. Feb. 2012;60(3):416-426. EXC4. [pmid: 22276605].
1004 Neumann J, Zeindl-Eberhart E, Kirchner T, et al. Frequency and type of KRAS mutations in routine diagnostic analysis of metastatic colorectal cancer. Pathol Res Pract. 2009;205(12):858-862. EXC6. [pmid: 19679400].
1005 Newman TB, Kohn MA. Evidence-Based Diagnosis. New York. Cambridge University Press. 2009. EXC2.
1006 Newnham GM, Conron M, McLachlan S, et al. Integrated mutation, copy number and expression profiling in resectable non-small cell lung cancer. BMC Cancer. 2011;11:93. EXC6. [pmid: 21385341].
1007 Ng K, Ogino S, Meyerhardt JA, et al. Relationship between statin use and colon cancer recurrence and survival: results from CALGB 89803. J Natl Cancer Inst. Oct. 19. 2011;103(20):1540-1551. EXC4. [pmid: 21849660].
1008 Nguyen B, Cusumano PG, Deck K, et al. Comparison of molecular subtyping with BluePrint, MammaPrint, and TargetPrint to local clinical subtyping in breast cancer patients. Ann Surg Oncol. Oct. 2012;19(10):3257-3263. EXC 6. [pmid: 22965266].
1009 Nguyen CT, Litt DB, Dolar SE, et al. Prognostic significance of nondiagnostic molecular changes in urine detected by UroVysion fluorescence in situ hybridization during surveillance for bladder cancer. Urology. Feb. 2009;73(2):347-350. EXC6. [pmid: 19022486].
1010 Nie Q, Yang XN, An SJ, et al. CYP1A1*2A polymorphism as a predictor of clinical outcome in advanced lung cancer patients treated with EGFR-TKI and its combined effects with EGFR intron 1 (CA)n polymorphism. Eur J Cancer. Sep. 2011;47(13):1962-1970. EXC4. [pmid: 21616658].
1011 Niemiec J, Kolodziejski L, Dyczek S. EGFR LI and Ki-67 LI are independent prognostic parameters influencing survivals of surgically treated squamous cell lung cancer patients. Neoplasma. 2005;52(3):231-237. EXC4. [pmid: 15875085].
1012 Niemiec J, Kolodziejski L, Dyczek S, et al. Prognostic significance of epidermal growth factor receptor in surgically treated squamous cell lung cancer patients. Folia Histochem Cytobiol. 2004;42(2):111-118. EXC4. [pmid: 15253134].
1013 Nilbert M, Planck M, Fernebro E, et al. Microsatellite instability is rare in rectal carcinomas and signifies hereditary cancer. Eur J Cancer. Jun. 1999;35(6):942-945. EXC4. [pmid: 10533476].
1014 Ninomiya H, Hiramatsu M, Inamura K, et al. Correlation between morphology and EGFR mutations in lung adenocarcinomas Significance of the micropapillary pattern and the hobnail cell type. Lung Cancer. Feb. 2009;63(2):235-240. EXC6. [pmid: 18571764].
1015 Nishino M, Cardarella S, Jackman DM, et al. RECIST 1.1 in NSCLC patients with EGFR mutations treated with EGFR tyrosine kinase inhibitors: comparison with RECIST 1.0. AJR Am J Roentgenol. Jul. 2013;201(1):W64-W71. EXC3. [pmid: 23789698].
1016 Nishino M, Klepeis VE, Yeap BY, et al. Histologic and cytomorphologic features of ALK-rearranged lung adenocarcinomas. Mod Pathol. Nov. 2012;25(11):1462-1472. EXC6. [pmid: 22743652].
1017 Nishio M, Yamanaka T, Matsumoto K, et al. Serum heparan sulfate concentration is correlated with the failure of epidermal growth factor receptor tyrosine kinase inhibitor treatment in patients with lung adenocarcinoma. J Thorac Oncol. Nov. 2011;6(11):1889-1894. EXC4. [pmid: 21964526].
1018 Nitsche U, Rosenberg R, Balmert A, et al. Integrative marker analysis allows risk assessment for metastasis in stage II colon cancer. Ann Surg. Nov. 2012;256(5):763-771. discussion 71. EXC6. [pmid: 23095620].
1019 Niwinska A, Olszewski W, Murawska M, et al. Triple-negative breast cancer with brain metastases: A comparison between basal-like and non-basal-like biological subtypes. J Neurooncol. 2011;105(3):547-553. EXC4. [pmid: 21656328].
1020 Noda H, Kato Y, Yoshikawa H, et al. Frequent involvement of ras-signalling pathways in both polypoid-type and flat-type early-stage colorectal cancers. J Exp Clin Cancer Res. Jun. 2006;25(2):235-242. EXC6. [pmid: 16918136].
1021 Noguchi M, Suzuki T, Kabayama K, et al. GM3 synthase gene is a novel biomarker for histological classification and drug sensitivity against epidermal growth factor receptor tyrosine kinase inhibitors in non-small cell lung cancer. Cancer Sci. Oct. 2007;98(10):1625-1632. EXC4. [pmid: 17711504].
1022 Norrie MW, Hawkins NJ, Todd AV, et al. The role of hMLH1 methylation in the development of synchronous sporadic colorectal carcinomas. Dis Colon Rectum. May. 2002;45(5):674-680. EXC6. [pmid: 12004219].
1023 Norris S, Atkins D, Bruening W, et al. Selecting Observational Studies for Comparing Medical Interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2010. EXC2.
1024 Nose N, Sugio K, Oyama T, et al. Association between estrogen receptor-beta expression and epidermal growth factor receptor mutation in the postoperative prognosis of adenocarcinoma of the lung. J Clin Oncol. Jan. 20. 2009;27(3):411-417. EXC6. [pmid: 19064969].
1025 Nose N, Uramoto H, Iwata T, et al. Expression of estrogen receptor beta predicts a clinical response and longer progression-free survival after treatment with EGFR-TKI for adenocarcinoma of the lung. Lung Cancer. Mar. 2011;71(3):350-355. EXC4. [pmid: 20615575].
1026 Nosho K, Baba Y, Tanaka N, et al. Tumour-infiltrating T-cell subsets, molecular changes in colorectal cancer, and prognosis: cohort study and literature review. J Pathol. Dec. 2010;222(4):350-366. EXC5. [pmid: 20927778].
1027 Nosho K, Kure S, Irahara N, et al. A Prospective Cohort Study Shows Unique Epigenetic, Genetic, and Prognostic Features of Synchronous Colorectal Cancers. Gastroenterology. 2009;137(5):1609-1620.e3. EXC4. [pmid: 19686742].
1028 Nosho K, Shima K, Irahara N, et al. DNMT3B expression might contribute to CpG island methylator phenotype in colorectal cancer. Clin Cancer Res. Jun. 1. 2009;15(11):3663-3671. EXC4. [pmid: 19470733].
1029 Nosho K, Yamamoto H, Hamamoto Y, et al. A case of multiple protruding and flat colorectal tumors analyzed by a cDNA array. Int J Colorectal Dis. Jun. 2007;22(6):723-724. EXC2. [pmid: 16075236].
1030 Nosho K, Yamamoto H, Takahashi T, et al. Correlation of laterally spreading type and JC virus with methylator phenotype status in colorectal adenoma. Hum Pathol. May. 2008;39(5):767-775. EXC4. [pmid: 18284934].
1031 Notarnicola M, Gristina R, Messa C, et al. Oestrogen receptors and microsatellite instability in colorectal carcinoma patients. Cancer Lett. Jul. 10. 2001;168(1):65-70. EXC4. [pmid: 11368879].
1032 Nygaard AD, Garm Spindler KL, Pallisgaard N, et al. The prognostic value of KRAS mutated plasma DNA in advanced non-small cell lung cancer. Lung Cancer. Mar. 2013;79(3):312-317. EXC6. [pmid: 23238036].
1033 Obermair A, Youlden DR, Young JP, et al. Risk of endometrial cancer for women diagnosed with HNPCC-related colorectal carcinoma. Int J Cancer. 2010;127(11):2678-2684. EXC3. [pmid: 20533284].
1034 O'Brien MJ, Yang S, Mack C, et al. Comparison of microsatellite instability, CpG island methylation phenotype, BRAF and KRAS status in serrated polyps and traditional adenomas indicates separate pathways to distinct colorectal carcinoma end points. Am J Surg Pathol. Dec. 2006;30(12):1491-1501. EXC5. [pmid: 17122504].
1035 O'Byrne KJ, Cox G, Swinson D, et al. Towards a biological staging model for operable non-small cell lung cancer. Lung Cancer. Dec. Suppl 2. 2001;34:S83-S89. EXC4. [pmid: 11720747].
1036 O'Byrne KJ, Gatzemeier U, Bondarenko I, et al. Molecular biomarkers in non-small-cell lung cancer: a retrospective analysis of data from the phase 3 FLEX study. Lancet Oncol. Aug. 2011;12(8):795-805. EXC3. [pmid: 21782507].
1037 Ocvirk J, Brodowicz T, Wrba F, et al. Cetuximab plus FOLFOX6 or FOLFIRI in metastatic colorectal cancer: CECOG trial. World J Gastroenterol. Jul. 7. 2010;16(25):3133-3143. EXC3. [pmid: 20593498].
1038 Ogino S, Brahmandam M, Kawasaki T, et al. Epigenetic profiling of synchronous colorectal neoplasias by quantitative DNA methylation analysis. Mod Pathol. Aug. 2006;19(8):1083-1090. EXC6. [pmid: 16699497].
1039 Ogino S, Nosho K, Irahara N, et al. Lymphocytic reaction to colorectal cancer is associated with longer survival, independent of lymph node count, microsatellite instability, and CpG island methylator phenotype. Clin Cancer Res. Oct. 15. 2009;15(20):6412-6420. EXC6. [pmid: 19825961].
1040 Ogino S, Nosho K, Irahara N, et al. Prognostic significance and molecular associations of 18q loss of heterozygosity: a cohort study of microsatellite stable colorectal cancers. J Clin Oncol. Sep. 20. 2009;27(27):4591-4598. EXC4. [pmid: 19704056].
1041 Ogino S, Nosho K, Irahara N, et al. Negative lymph node count is associated with survival of colorectal cancer patients, independent of tumoral molecular alterations and lymphocytic reaction. Am J Gastroenterol. Feb. 2010;105(2):420-433. EXC4. [pmid: 19809407].
1042 Ogino S, Nosho K, Kirkner GJ, et al. CpG island methylator phenotype, microsatellite instability, BRAF mutation and clinical outcome in colon cancer. Gut. 2009;58(1):90-96. EXC4. [pmid: 18832519].
1043 Oh IJ, Ban HJ, Kim KS, et al. Retreatment of gefitinib in patients with non-small-cell lung cancer who previously controlled to gefitinib: a single-arm, open-label, phase II study. Lung Cancer. Jul. 2012;77(1):121-127. EXC6. [pmid: 22333554].
1044 Oh JE, An CH, Yoo NJ, et al. Detection of low-level EGFR T790M mutation in lung cancer tissues. APMIS. Jul. 2011;119(7):403-411. EXC6. [pmid: 21635547].
1045 Ohsaki Y, Tanno S, Fujita Y, et al. Epidermal growth factor receptor expression correlates with poor prognosis in non-small cell lung cancer patients with p53 overexpression. Oncol Rep. May-Jun. 2000;7(3):603-607. EXC4. [pmid: 10767376].
1046 Ohta M, Seto M, Ijichi H, et al. Decreased expression of the RAS-GTPase activating protein RASAL1 is associated with colorectal tumor progression. Gastroenterology. Jan. 2009;136(1):206-216. EXC7. [pmid: 18992247].
1047 Ohtsuka K, Ohnishi H, Furuyashiki G, et al. Clinico-pathological and biological significance of tyrosine kinase domain gene mutations and overexpression of epidermal growth factor receptor for lung adenocarcinoma. J Thorac Oncol. Oct. 2006;1(8):787-795. EXC6. [pmid: 17409961].
1048 Ohtsuka K, Ohnishi H, Kurai D, et al. Familial lung adenocarcinoma caused by the EGFR V843I germ-line mutation. J Clin Oncol. Mar. 10. 2011;29(8):e191-e192. EXC2. [pmid: 21172876].
1049 Okami J, Taniguchi K, Higashiyama M, et al. Prognostic factors for gefitinib-treated postoperative recurrence in non-small cell lung cancer. Oncology. 2007;72(3-4):234-242. EXC6. [pmid: 18176089].
1050 Okayama H, Kohno T, Ishii Y, et al. Identification of genes upregulated in ALK-positive and EGFR/KRAS/ALK-negative lung adenocarcinomas. Cancer Res. 2012;72(1):100-111. EXC5. [pmid: 22080568].
1051 Okon K, Demczuk S, Klimkowska A, et al. Correlation of microsatellite status, proliferation, apoptotic and selected immunohistochemical markers in colorectal carcinoma studied with tissue microarray. Pol J Pathol. 2006;57(2):105-111. EXC6. [pmid: 17019973].
1052 Okon K, Klimkowska A, Wojcik P, et al. High thymidylate synthase expression is typical for sporadic MSI-H colorectal carcinoma. Pol J Pathol. 2006;57(1):29-33. EXC6. [pmid: 16739880].
1053 Okon K, Sinczak-Kuta A, Klimkowska A, et al. Tissue microarray FISH applied to colorectal carcinomas with various microsatellite status. Pol J Pathol. 2006;57(2):99-103. EXC4. [pmid: 17019972].
1054 Okon K, Zazula M, Rudzki Z, et al. CDX-2 expression is reduced in colorectal carcinomas with solid growth pattern and proximal location, but is largely independent of MSI status. Pol J Pathol. 2004;55(3):9-14. EXC4. [pmid: 15619975].
1055 Okuda K, Sasaki H, Dumontet C, et al. Expression of excision repair cross-complementation group 1 and class III beta-tubulin predict survival after chemotherapy for completely resected non-small cell lung cancer. Lung Cancer. Oct. 2008;62(1):105-112. EXC6. [pmid: 18395930].
1056 Okuda T, Kawakami K, Ishiguro K, et al. The profile of hMLH1 methylation and microsatellite instability in colorectal and non-small cell lung cancer. Int J Mol Med. Jan. 2005;15(1):85-90. EXC6. [pmid: 15583832].
1057 Okudela K, Woo T, Yazawa T, et al. Significant association between EGFR-mutated lung adenocarcinoma and past illness from gastric cancer or uterine myoma: Its implication in carcinogenesis. Lung Cancer. 2009;66(3):287-291. EXC6. [pmid: 19362747].
1058 Olaru AV, Cheng Y, Agarwal R, et al. Unique patterns of CpG island methylation in inflammatory bowel disease-associated colorectal cancers. Inflamm Bowel Dis. Apr. 2012;18(4):641-648. EXC6. [pmid: 21830278].
1059 Cost-effectiveness of the Oncotype DX assay in Australia: an exploratory analysis. International Society for Pharmoeconomics and Outcomes Research. 2010. May. Atlanta, GA. EXC6.
1060 Oliart S, Martinez-Santos C, Moreno-Azcoita M, et al. Do MSI-L sporadic colorectal tumors develop through"mild mutator pathway"?. Am J Clin Oncol. Aug. 2006;29(4):364-370. EXC6. [pmid: 16891863].
1061 Oliner K, Juan T, Suggs S, et al. A comparability study of 5 commercial KRAS tests. Diagn Pathol. 2010;5:23. EXC4. [pmid: 20398393].
1062 Oltedal S, Aasprong OG, Moller JH, et al. Heterogeneous distribution of K-ras mutations in primary colon carcinomas: implications for EGFR-directed therapy. Int J Colorectal Dis. Oct. 2011;26(10):1271-1277. EXC6. [pmid: 21573767].
1063 Onitsuka T, Uramoto H, Ono K, et al. Comprehensive molecular analyses of lung adenocarcinoma with regard to the epidermal growth factor receptor, K-ras, MET, and hepatocyte growth factor status. J Thorac Oncol. May. 2010;5(5):591-596. EXC6. [pmid: 20150826].
1064 Onn A, Choe DH, Herbst RS, et al. Tumor cavitation in stage I non-small cell lung cancer: epidermal growth factor receptor expression and prediction of poor outcome. Radiology. Oct. 2005;237(1):342-347. EXC4. [pmid: 16183941].
1065 Onn A, Correa AM, Gilcrease M, et al. Synchronous overexpression of epidermal growth factor receptor and HER2-neu protein is a predictor of poor outcome in patients with stage I non-small cell lung cancer. Clin Cancer Res. Jan. 1. 2004;10(1 Pt 1):136-143. EXC4. [pmid: 14734462].
1066 Oratz R, Kim B, Chao C, et al. Physician survey of the effect of the 21-gene recurrence score assay results on treatment recommendations for patients with lymph node-positive, estrogen receptor-positive breast cancer. J Oncol Pract. Mar. 2011;7(2):94-99. Exc7. [pmid: 21731516].
1067 Oratz R, Paul D, Cohn A, et al. Impact of Oncotype DX (TM) on decision making in breast cancer clinical practice. Breast Cancer Res Treat. suppl 1. 2005;94:S100-S. EXC2.
1068 Oratz R, Paul D, Cohn AL, et al. Impact of a commercial reference laboratory test recurrence score on decision making in early-stage breast cancer. Journal of Oncology Practice. 2007;3(4):182-186. EXC5. [pmid: 20859407].
1069 Orta L, Klimstra DS, Qin J, et al. Towards identification of hereditary DNA mismatch repair deficiency: sebaceous neoplasm warrants routine immunohistochemical screening regardless of patient's age or other clinical characteristics. Am J Surg Pathol. Jun. 2009;33(6):934-944. EXC3. [pmid: 19342947].
1070 Ortiz TM, Cohen DW, Kent MS, et al. KRAS mutation analysis helps to differentiate between pulmonary metastasis from colon adenocarcinoma in situ and primary lung adenocarcinoma. J Thorac Oncol. Jan. 2011;6(1):220-222. EXC3. [pmid: 21178719].
1071 Oshita F, Matsukuma S, Yoshihara M, et al. Novel heteroduplex method using small cytology specimens with a remarkably high success rate for analysing EGFR gene mutations with a significant correlation to gefitinib efficacy in non-small-cell lung cancer. Br J Cancer. Oct. 23. 2006;95(8):1070-1075. EXC3. [pmid: 17047654].
1072 Oster B, Thorsen K, Lamy P, et al. Identification and validation of highly frequent CpG island hypermethylation in colorectal adenomas and carcinomas. Int J Cancer. Dec. 15. 2011;129(12):2855-2866. EXC4. [pmid: 21400501].
1073 Ostwald C, Linnebacher M, Weirich V, et al. Chromosomally and microsatellite stable colorectal carcinomas without the CpG island methylator phenotype in a molecular classification. Int J Oncol. Aug. 2009;35(2):321-327. EXC6. [pmid: 19578746].
1074 Otani H, Toyooka S, Soh J, et al. Detection of EGFR gene mutations using the wash fluid of CT-guided biopsy needle in NSCLC patients. J Thorac Oncol. May. 2008;3(5):472-476. EXC4. [pmid: 18448998].
1075 Ottini L, Palli D, Falchetti M, et al. Microsatellite instability in gastric cancer is associated with tumor location and family history in a high-risk population from Tuscany. Cancer Res. Oct. 15. 1997;57(20):4523-4529. EXC3. [pmid: 9377564].
1076 Overbeek LI, Kets CM, Hebeda KM, et al. Patients with an unexplained microsatellite instable tumour have a low risk of familial cancer. Br J Cancer. May. 21. 2007;96(10):1605-1612. EXC3. [pmid: 17453009].
1077 Owens SR, Chiosea SI, Kuan SF. Selective expression of gastric mucin MUC6 in colonic sessile serrated adenoma but not in hyperplastic polyp aids in morphological diagnosis of serrated polyps. Mod Pathol. Jun. 2008;21(6):660-669. EXC6. [pmid: 18360351].
1078 Oxnard GR, Janjigian YY, Arcila ME, et al. Maintained sensitivity to EGFR tyrosine kinase inhibitors in EGFR-mutant lung cancer recurring after adjuvant erlotinib or gefitinib. Clin Cancer Res. Oct. 1. 2011;17(19):6322-6328. EXC5. [pmid: 21831955].
1079 Oxnard GR, Miller VA, Robson ME, et al. Screening for germline EGFR T790M mutations through lung cancer genotyping. J Thorac Oncol. Jun. 2012;7(6):1049-1052. EXC4. [pmid: 22588155].
1080 Oyama K, Kawakami K, Maeda K, et al. The association between methylenetetrahydrofolate reductase polymorphism and promoter methylation in proximal colon cancer. Anticancer Res. Mar-Apr. 2004;24(2B):649-654. EXC4. [pmid: 15161007].
1081 Ozer E, Yuksel E, Kizildag S, et al. Microsatellite instability in early-onset breast cancer. Pathology Research and Practice. 2002;198(8):525-530. EXC7.
1082 Paez D, Pare L, Espinosa I, et al. Immunoglobulin G fragment C receptor polymorphisms and KRAS mutations: are they useful biomarkers of clinical outcome in advanced colorectal cancer treated with anti-EGFR-based therapy?. Cancer Sci. Sep. 2010;101(9):2048-2053. EXC7. [pmid: 20550522].
1083 Paez JG, Janne PA, Lee JC, et al. EGFR mutations in lung cancer: correlation with clinical response to gefitinib therapy. Science. Jun. 4. 2004;304(5676):1497-1500. EXC6. [pmid: 15118125].
1084 Paik JH, Choe G, Kim H, et al. Screening of anaplastic lymphoma kinase rearrangement by immunohistochemistry in non-small cell lung cancer: correlation with fluorescence in situ hybridization. J Thorac Oncol. Mar. 2011;6(3):466-472. EXC4. [pmid: 21258247].
1085 Paik JH, Choi CM, Kim H, et al. Clinicopathologic implication of ALK rearrangement in surgically resected lung cancer: a proposal of diagnostic algorithm for ALK-rearranged adenocarcinoma. Lung Cancer. Jun. 2012;76(3):403-409. EXC6. [pmid: 22129856].
1086 Paik PK, Johnson ML, D'Angelo SP, et al. Driver mutations determine survival in smokers and never-smokers with stage IIIB/IV lung adenocarcinomas. Cancer. Dec. 1. 2012;118(23):5840-5847. EXC6. [pmid: 22605530].
1087 Paik S, Shak S, Tang G, et al. Multi-gene RT-PCR assay for predicting recurrence in node negative breast cancer patients - NSABP studies B-20 and B-14. Breast Cancer Res Treat. Suppl 1. 2003;82:S10-S1. EXC2.
1088 Paik S, Shak S, Tang G, et al. Expression of the 21 genes in the Recurrence Score assay and tamoxifen clinical benefit in the NSABP study B-14 of node negative, estrogen receptor positive breast cancer. J Clin Oncol. Jun. 1. 2005;23(16):6S-S. EXC2.
1089 Paik S, Shak S, Tang G, et al. Expression of the 21 genes in the Recurrence Score assay and prediction of clinical benefit from tamoxifen in NSABP study B-14 and chemotherapy in NSABP study B-20. Breast Cancer Res Treat. suppl 1. 2004;88:S15-S. EXC2.
1090 Paik S, Shak S, Tang G, et al. Risk classification of breast cancer patients by the Recurrence Score assay: comparison to guidelines based on patient age, tumor size, and tumor grade. Breast Cancer Res Treat. Suppl 1. 2004;88:S21-S. EXC2.
1091 Paik S, Tang G, Shak S, et al. Gene expression and benefit of chemotherapy in women with node-negative, estrogen receptor-positive breast cancer. J Clin Oncol. Aug. 10. 2006;24(23):3726-3734. EXC5. [pmid: 16720680].
1092 Pallis AG, Voutsina A, Kalikaki A, et al. 'Classical' but not 'other' mutations of EGFR kinase domain are associated with clinical outcome in gefitinib-treated patients with non-small cell lung cancer. Br J Cancer. Dec. 3. 2007;97(11):1560-1566. EXC6. [pmid: 18000506].
1093 Pallis AG, Voutsina A, Kentepozidis N, et al. A phase II trial of erlotinib as front-line treatment in clinically selected patients with non-small-cell lung cancer. Clin Lung Cancer. Mar. 2012;13(2):129-135. EXC3. [pmid: 22000696].
1094 Palmirotta R, Ludovici G, De Marchis ML, et al. A comprehensive procedural approach to genotyping KRAS and BRAF from paraffin embedded tissues for diagnostic purposes. In Vivo. Jul. 2012;26(4):537-547. EXC6. [pmid: 22773565].
1095 Palmirotta R, Matera S, Curia MC, et al. Correlations between phenotype and microsatellite instability in HNPCC: implications for genetic testing. Fam Cancer. 2004;3(2):117-121. EXC4. [pmid: 15340262].
1096 Palomaki GE, McClain MR, Melillo S, et al. EGAPP supplementary evidence review: DNA testing strategies aimed at reducing morbidity and mortality from Lynch syndrome. Genet Med. Jan. 2009;11(1):42-65. EXC3. [pmid: 19125127].
1097 Pancione M, Forte N, Fucci A, et al. Prognostic role of beta-catenin and p53 expression in the metastatic progression of sporadic colorectal cancer. Hum Pathol. Jun. 2010;41(6):867-876. EXC4. [pmid: 20129645].
1098 Pandey V, Prabhu JS, Payal K, et al. Assessment of microsatellite instability in colorectal carcinoma at an Indian center. Int J Colorectal Dis. Jul. 2007;22(7):777-782. EXC6. [pmid: 17160686].
1099 Pang B, Matthias D, Ong CW, et al. The positive impact of cytological specimens for EGFR mutation testing in non-small cell lung cancer: A single South East Asian laboratory's analysis of 670 cases. Cytopathology. 2012;23(4):229-236. EXC4. [pmid: 22805513].
1100 Paradiso A, Tommasi S, Pinto R, et al. Exhaled breath condensate is not suitable to detect EGFR somatic mutations. Eur Respir J. 2008;32(4):1126-1127. EXC2. [pmid: 18827165].
1101 Paraf F, Gilquin M, Longy M, et al. MLH1 and MSH2 protein immunohistochemistry is useful for detection of hereditary non-polyposis colorectal cancer in young patients. Histopathology. Sep. 2001;39(3):250-258. EXC4. [pmid: 11532035].
1102 Parc Y, Gueroult S, Mourra N, et al. Prognostic significance of microsatellite instability determined by immunohistochemical staining of MSH2 and MLH1 in sporadic T3N0M0 colon cancer. Gut. Mar. 2004;53(3):371-375. EXC4. [pmid: 14960518].
1103 Park HS, Lee JK, Kim DW, et al. Immunohistochemical screening for anaplastic lymphoma kinase (ALK) rearrangement in advanced non-small cell lung cancer patients. Lung Cancer. 2012;77(2):288-292. EXC4. [pmid: 22465695].
1104 Park JH, Han SW, Oh DY, et al. Analysis of KRAS, BRAF, PTEN, IGF1R, EGFR intron 1 CA status in both primary tumors and paired metastases in determining benefit from cetuximab therapy in colon cancer. Cancer Chemother Pharmacol. Oct. 2011;68(4):1045-1055. EXC5. [pmid: 21340604].
1105 Park S, Choi YL, Sung CO, et al. High MET copy number and MET overexpression: poor outcome in non-small cell lung cancer patients. Histol Histopathol. Feb. 2012;27(2):197-207. EXC4. [pmid: 22207554].
1106 Park S, Ha SY, Cho HY, et al. Prognostic implications of hypoxia-inducible factor-1alpha in epidermal growth factor receptor-negative non-small cell lung cancer. Lung Cancer. Apr. 2011;72(1):100-107. EXC4. [pmid: 20822827].
1107 Park S, Holmes-Tisch AJ, Cho EY, et al. Discordance of molecular biomarkers associated with epidermal growth factor receptor pathway between primary tumors and lymph node metastasis in non-small cell lung cancer. J Thorac Oncol. Jul. 2009;4(7):809-815. EXC6. [pmid: 19487967].
1108 Park SH, Ha SY, Lee JI, et al. Epidermal growth factor receptor mutations and the clinical outcome in male smokers with squamous cell carcinoma of lung. J Korean Med Sci. Jun. 2009;24(3):448-452. EXC3. [pmid: 19543508].
1109 Park SJ, Hong YS, Lee JL, et al. Genetic polymorphisms of Fc(gamma)RIIa and Fc(gamma)RIIIa are not predictive of clinical outcomes after cetuximab plus irinotecan chemotherapy in patients with metastatic colorectal cancer. Oncology. 2012;82(2):83-89. EXC5. [pmid: 22327884].
1110 Park SY, Choe G, Lee HS, et al. Tumor budding as an indicator of isolated tumor cells in lymph nodes from patients with node-negative colorectal cancer. Dis Colon Rectum. Feb. 2005;48(2):292-302. EXC4. [pmid: 15616755].
1111 Park SY, Lee HS, Choe G, et al. Clinicopathological characteristics, microsatellite instability, and expression of mucin core proteins and p53 in colorectal mucinous adenocarcinomas in relation to location. Virchows Arch. Jul. 2006;449(1):40-47. EXC6. [pmid: 16645863].
1112 Parra HS, Cavina R, Latteri F, et al. Analysis of epidermal growth factor receptor expression as a predictive factor for response to gefitinib ('Iressa', ZD1839) in non-small-cell lung cancer. Br J Cancer. Jul. 19. 2004;91(2):208-212. EXC4. [pmid: 15187994].
1113 Partanen R, Hemminki K, Koskinen H, et al. The detection of increased amounts of the extracellular domain of the epidermal growth factor receptor in serum during carcinogenesis in asbestosis patients. J Occup Med. 1994;36(12):1324-1328. EXC4. [pmid: 7884573].
1114 Partin JF, Mamounas EP. Impact of the 21-gene recurrence score assay compared with standard clinicopathologic guidelines in adjuvant therapy selection for node-negative, estrogen receptor-positive breast cancer. Ann Surg Oncol. Nov. 2011;18(12):3399-3406. EXC5. [pmid: 21537874].
1115 Paule B, Castagne V, Picard V, et al. MDR1 polymorphism role in patients treated with cetuximab and irinotecan in irinotecan refractory colorectal cancer. Med Oncol. Dec. 2010;27(4):1066-1072. EXC4. [pmid: 19862647].
1116 Pe PA, Azcoita MM, Alonso A, et al. Prognostic significancce of high microsatellite instability in a Spanish series of gastric adenocarcinomas. Anticancer Res. 2000;20(5 C):4009-4014. EXC4. [pmid: 11268493].
1117 Peeters M, Price TJ, Cervantes A, et al. Randomized phase III study of panitumumab with fluorouracil, leucovorin, and irinotecan (FOLFIRI) compared with FOLFIRI alone as second-line treatment in patients with metastatic colorectal cancer. J Clin Oncol. Nov. 1. 2010;28(31):4706-4713. EXC6. [pmid: 20921462].
1118 Peeters M, Siena S, Cutsem E, et al. Association of progression-free survival, overall survival, and patient-reported outcomes by skin toxicity and KRAS status in patients receiving panitumumab monotherapy. Cancer. 2009;(7):1544-1554. EXC7. [pmid: 19189371].
1119 Pelosi G, Gasparini P, Cavazza A, et al. Multiparametric molecular characterization of pulmonary sarcomatoid carcinoma reveals a nonrandom amplification of anaplastic lymphoma kinase (ALK) gene. Lung Cancer. 2012;77(3):507-514. EXC6. [pmid: 22705117].
1120 Peng J, Xiao-ming M, Jian-qiu S, et al. Clinicopathological features of non-familial colorectal cancer with high-frequency microsatellite instability. Chin Med Sci J. Dec. 2010;25(4):228-232. EXC6. [pmid: 21232183].
1121 Penzel R, Schirmacher P, Warth A. A novel EML4-ALK variant: exon 6 of EML4 fused to exon 19 of ALK. J Thorac Oncol. Jul. 2012;7(7):1198-1199. EXC7. [pmid: 22706607].
1122 Perea J, Alvaro E, Rodriguez Y, et al. Approach to early-onset colorectal cancer: Clinicopathological, familial, molecular and immunohistochemical characteristics. World Journal of Gastroenterology. 2010;16(29):3697-3703. EXC6. [pmid: 20677343].
1123 Perez-Ruiz E, Rueda A, Pereda T, et al. Involvement of K-RAS mutations and amino acid substitutions in the survival of metastatic colorectal cancer patients. Tumour Biol. Dec. 2012;33(6):1829-1835. EXC3. [pmid: 22791568].
1124 Perez-Soler R, Chachoua A, Hammond LA, et al. Determinants of tumor response and survival with erlotinib in patients with non--small-cell lung cancer. J Clin Oncol. Aug. 15. 2004;22(16):3238-3247. EXC5. [pmid: 15310767].
1125 Perez-Villamil B, Romera-Lopez A, Hernandez-Prieto S, et al. Colon cancer molecular subtypes identified by expression profiling and associated to stroma, mucinous type and different clinical behavior. BMC Cancer. 2012;12:260. EXC4. [pmid: 22712570].
1126 Perkins G, Lievre A, Ramacci C, et al. Additional value of EGFR downstream signaling phosphoprotein expression to KRAS status for response to anti-EGFR antibodies in colorectal cancer. Int J Cancer. Sep. 1. 2010;127(6):1321-1331. EXC4. [pmid: 20049837].
1127 Perng RP, Yang CH, Chen YM, et al. High efficacy of erlotinib in Taiwanese NSCLC patients in an expanded access program study previously treated with chemotherapy. Lung Cancer. Oct. 2008;62(1):78-84. EXC4. [pmid: 18423781].
1128 Perrin J, Gouvernet J, Parriaux D, et al. MSH2 and MLH1 immunodetection and the prognosis of colon cancer. Int J Oncol. Nov. 2001;19(5):891-895. EXC4. [pmid: 11604984].
1129 Perrone F, Lampis A, Orsenigo M, et al. PI3KCA/PTEN deregulation contributes to impaired responses to cetuximab in metastatic colorectal cancer patients. Ann Oncol. Jan. 2009;20(1):84-90. EXC6. [pmid: 18669866].
1130 Personeni N, Fieuws S, Piessevaux H, et al. Clinical usefulness of EGFR gene copy number as a predictive marker in colorectal cancer patients treated with cetuximab: a fluorescent in situ hybridization study. Clin Cancer Res. Sep. 15. 2008;14(18):5869-5876. EXC4. [pmid: 18794099].
1131 Pesch B, Nasterlack M, Eberle F, et al. The role of haematuria in bladder cancer screening among men with former occupational exposure to aromatic amines. BJU Int. Aug. 2011;108(4):546-552. EXC6. [pmid: 21223477].
1132 Pesek M, Benesova L, Belsanova B, et al. Dominance of EGFR and insignificant KRAS mutations in prediction of tyrosine-kinase therapy for NSCLC patients stratified by tumor subtype and smoking status. Anticancer Res. 2009;29(7):2767-2773. EXC3. [pmid: 19596959].
1133 Pesek M, Kopeckova M, Benesova L, et al. Clinical significance of hypermethylation status in NSCLC: evaluation of a 30-gene panel in patients with advanced disease. Anticancer Res. Dec. 2011;31(12):4647-4652. EXC4. [pmid: 22199344].
1134 Petras ML, Lefferts JA, Ward BP, et al. KRAS detection in colonic tumors by DNA extraction from FTA paper: the molecular touch-prep. Diagn Mol Pathol. Dec. 2011;20(4):189-193. EXC5. [pmid: 22089345].
1135 Pfeiffer P, Clausen PP, Andersen K, et al. Lack of prognostic significance of epidermal growth factor receptor and the oncoprotein p185HER-2 in patients with systemically untreated non-small-cell lung cancer: an immunohistochemical study on cryosections. Br J Cancer. Jul. 1996;74(1):86-91. EXC4. [pmid: 8679464].
1136 Pfeiffer P, Nexo E, Bentzen SM, et al. Enzyme-linked immunosorbent assay of epidermal growth factor receptor in lung cancer: comparisons with immunohistochemistry, clinicopathological features and prognosis. Br J Cancer. Jul. 1998;78(1):96-99. EXC4. [pmid: 9662257].
1137 Phillips SM, Banerjea A, Feakins R, et al. Tumour-infiltrating lymphocytes in colorectal cancer with microsatellite instability are activated and cytotoxic. Br J Surg. Apr. 2004;91(4):469-475. EXC4. [pmid: 15048750].
1138 Phipps AI, Baron J, Newcomb PA. Prediagnostic smoking history, alcohol consumption, and colorectal cancer survival: the Seattle Colon Cancer Family Registry. Cancer. Nov. 1. 2011;117(21):4948-4957. EXC6. [pmid: 21495019].
1139 Pichler M, Balic M, Stadelmeyer E, et al. Evaluation of high-resolution melting analysis as a diagnostic tool to detect the BRAF V600E mutation in colorectal tumors. J Mol Diagn. Mar. 2009;11(2):140-147. EXC6. [pmid: 19213871].
1140 Pichler M, Winter E, Stotz M, et al. Down-regulation of KRAS-interacting miRNA-143 predicts poor prognosis but not response to EGFR-targeted agents in colorectal cancer. Br J Cancer. May. 22. 2012;106(11):1826-1832. EXC4. [pmid: 22549179].
1141 Pino MS, Kikuchi H, Zeng M, et al. Epithelial to mesenchymal transition is impaired in colon cancer cells with microsatellite instability. Gastroenterology. Apr. 2010;138(4):1406-1417. EXC7. [pmid: 20026115].
1142 Pirker R, Pereira JR, Szczesna A, et al. Cetuximab plus chemotherapy in patients with advanced non-small-cell lung cancer (FLEX): an open-label randomised phase III trial. Lancet. May. 2. 2009;373(9674):1525-1531. EXC5. [pmid: 19410716].
1143 Pirker R, Pereira JR, von Pawel J, et al. EGFR expression as a predictor of survival for first-line chemotherapy plus cetuximab in patients with advanced non-small-cell lung cancer: analysis of data from the phase 3 FLEX study. Lancet Oncol. Jan. 2012;13(1):33-42. EXC4. [pmid: 22056021].
1144 Pistorius SR, Kruppa C, Haas S, et al. Clinical consequences of molecular diagnosis in families with mismatch repair gene germline mutations. Int J Colorectal Dis. 2000;15(5-6):255-263. EXC6. [pmid: 11151427].
1145 Plaschke J, Schwanebeck U, Pistorius S, et al. Methylenetetrahydrofolate reductase polymorphisms and risk of sporadic and hereditary colorectal cancer with or without microsatellite instability. Cancer Lett. Mar. 10. 2003;191(2):179-185. EXC4. [pmid: 12618331].
1146 Plummer JM, Chin SN, Aronson M, et al. Lynch syndrome in a predominantly Afrocentric population: a clinicopathological and genetic study. Can J Surg. Oct. 2012;55(5):294-300. EXC3. [pmid: 22854115].
1147 Pluquet E, Cadranel J, Legendre A, et al. Osteoblastic reaction in non-small cell lung carcinoma and its association to epidermal growth factor receptor tyrosine kinase inhibitors response and prolonged survival. J Thorac Oncol. Apr. 2010;5(4):491-496. EXC3. [pmid: 20195171].
1148 Poole EM, Curtin K, Hsu L, et al. Genetic variability in EGFR, Src and HER2 and risk of colorectal adenoma and cancer. International Journal of Molecular Epidemiology and Genetics. 2011;2(4):300-315. EXC6. [pmid: 22199994].
1149 Popat S, Vieira de Araujo A, Min T, et al. Lung adenocarcinoma with concurrent exon 19 EGFR mutation and ALK rearrangement responding to erlotinib. J Thorac Oncol. Nov. 2011;6(11):1962-1963. EXC2. [pmid: 22005476].
1150 Popovici V, Budinska E, Tejpar S, et al. Identification of a poor-prognosis BRAF-mutant-like population of patients with colon cancer. J Clin Oncol. Apr. 20. 2012;30(12):1288-1295. EXC4. [pmid: 22393095].
1151 Porta R, Sanchez-Torres JM, Paz-Ares L, et al. Brain metastases from lung cancer responding to erlotinib: the importance of EGFR mutation. Eur Respir J. Mar. 2011;37(3):624-631. EXC5. [pmid: 20595147].
1152 Poulogiannis G, Ichimura K, Hamoudi RA, et al. Prognostic relevance of DNA copy number changes in colorectal cancer. J Pathol. Feb. 2010;220(3):338-347. EXC4. [pmid: 19911421].
1153 Power DG, Shah MA, Asmis TR, et al. Safety and efficacy of panitumumab following cetuximab: retrospective review of the Memorial Sloan-Kettering experience. Invest New Drugs. Jun. 2010;28(3):353-360. EXC4. [pmid: 19468688].
1154 Poynter JN, Siegmund KD, Weisenberger DJ, et al. Molecular characterization of MSI-H colorectal cancer by MLHI promoter methylation, immunohistochemistry, and mismatch repair germline mutation screening. Cancer Epidemiol Biomarkers Prev. Nov. 2008;17(11):3208-3215. EXC4. [pmid: 18990764].
1155 Prall F, Duhrkop T, Weirich V, et al. Prognostic role of CD8+ tumor-infiltrating lymphocytes in stage III colorectal cancer with and without microsatellite instability. Hum Pathol. Jul. 2004;35(7):808-816. EXC4. [pmid: 15257543].
1156 Prat A, Parker JS, Fan C, et al. Concordance among gene expression-based predictors for ER-positive breast cancer treated with adjuvant tamoxifen. Ann Oncol. Nov. 2012;23(11):2866-2873. EXC5. [pmid: 22532584].
1157 Price KA, Azzoli CG, Krug LM, et al. Phase II trial of gefitinib and everolimus in advanced non-small cell lung cancer. J Thorac Oncol. Oct. 2010;5(10):1623-1629. EXC6. [pmid: 20871262].
1158 Price TJ, Hardingham JE, Lee CK, et al. Impact of KRAS and BRAF Gene Mutation Status on Outcomes From the Phase III AGITG MAX Trial of Capecitabine Alone or in Combination With Bevacizumab and Mitomycin in Advanced Colorectal Cancer. J Clin Oncol. Jul. 1. 2011;29(19):2675-2682. EXC3. [pmid: 21646616].
1159 Psofaki V, Kalogera C, Tzambouras N, et al. Promoter methylation status of hMLH1, MGMT, and CDKN2A/p16 in colorectal adenomas. World J Gastroenterol. Jul. 28. 2010;16(28):3553-3560. EXC6. [pmid: 20653064].
1160 Pucciarelli S, Agostini M, Viel A, et al. Early-age-at-onset colorectal cancer and microsatellite instability as markers of hereditary nonpolyposis colorectal cancer. Dis Colon Rectum. Mar. 2003;46(3):305-312. EXC6. [pmid: 12626904].
1161 Pycha A, Lodde M, Comploj E, et al. Intermediate-risk urothelial carcinoma: an unresolved problem?. Urology. Mar. 2004;63(3):472-475. EXC7. [pmid: 15028440].
1162 Qin L, Zhong W, Zhang L, et al. Comparison of three methods for detecting epidermal growth factor receptor mutations in plasma DNA samples of Chinese patients with advanced non-small cell lung cancer. Chin Med J (Engl). Mar. 2011;124(6):887-891. EXC6. [pmid: 21518597].
1163 Qiu H, Sirivongs P, Rothenberger M, et al. Molecular prognostic factors in rectal cancer treated by radiation and surgery. Dis Colon Rectum. Apr. 2000;43(4):451-459. EXC6. [pmid: 10789738].
1164 Qiu J, Compagnone M, Laibe S, et al. BRAF p.Val600Glu (V600E) somatic mutation is mainly associated with MSS phenotype in metastatic colorectal cancer. Cancer Genomics Proteomics. Jan-Feb. 2011;8(1):15-18. EXC6. [pmid: 21289333].
1165 Quasar Collaborative G, Gray R, Barnwell J, et al. Adjuvant chemotherapy versus observation in patients with colorectal cancer: a randomised study. Lancet. Dec. 15. 2007;370(9604):2020-2029. EXC6. [pmid: 18083404].
1166 Querings S, Altmuller J, Ansen S, et al. Benchmarking of mutation diagnostics in clinical lung cancer specimens. PLoS One. 2011;6(5):e19601. EXC6. [pmid: 21573178].
1167 Quinn E, Hawkins N, Yip YL, et al. CD103+ intraepithelial lymphocytes--a unique population in microsatellite unstable sporadic colorectal cancer. Eur J Cancer. Mar. 2003;39(4):469-475. EXC6. [pmid: 12751377].
1168 Raedle J, Brieger A, Trojan J, et al. Evaluation of rapid microsatellite analysis of paraffin-embedded specimens in screening for hereditary nonpolyposis colorectal cancer. Mod Pathol. May. 1999;12(5):485-491. EXC4. [pmid: 10349986].
1169 Raedle J, Schaffner M, Esser N, et al. Frequency of the Amsterdam criteria in a regional German cohort of patients with colorectal cancer. Z Gastroenterol. Aug. 2002;40(8):561-568. EXC3. [pmid: 12297979].
1170 Raedle J, Trojan J, Brieger A, et al. Bethesda guidelines: relation to microsatellite instability and MLH1 promoter methylation in patients with colorectal cancer. Ann Intern Med. Oct. 16. 2001;135(8 Pt):566-576. EXC6. [pmid: 11601928].
1171 Raevaara TE, Korhonen MK, Lohi H, et al. Functional significance and clinical phenotype of nontruncating mismatch repair variants of MLH1. Gastroenterology. Aug. 2005;129(2):537-549. EXC3. [pmid: 16083711].
1172 Rajkumar T, Soumittra N, Pandey D, et al. Mutation analysis of hMSH2 and hMLH1 in colorectal cancer patients in India. Genet Test. Summer. 2004;8(2):157-162. EXC3. [pmid: 15345113].
1173 Rako I, Jakic-Razumovic J, Katalinic D, et al. Mutation pattern of KRAS and BRAF oncogenes in colorectal cancer patients. Neoplasma. 2012;59(4):376-383. EXC6. [pmid: 22489692].
1174 Ramalingam S, Forster J, Naret C, et al. Dual inhibition of the epidermal growth factor receptor with cetuximab, an IgG1 monoclonal antibody, and gefitinib, a tyrosine kinase inhibitor, in patients with refractory non-small cell lung cancer (NSCLC): a phase I study. J Thorac Oncol. Mar. 2008;3(3):258-264. EXC6. [pmid: 18317068].
1175 Ramalingam SS, Blackhall F, Krzakowski M, et al. Randomized phase II study of dacomitinib (PF-00299804), an irreversible pan-human epidermal growth factor receptor inhibitor, versus erlotinib in patients with advanced non-small-cell lung cancer. J Clin Oncol. 2012;30(27):3337-3344. EXC6. [pmid: 22753918].
1176 Ramalingam SS, Spigel DR, Chen D, et al. Randomized phase II study of erlotinib in combination with placebo or R1507, a monoclonal antibody to insulin-like growth factor-1 receptor, for advanced-stage non-small-cell lung cancer. J Clin Oncol. 2011;(34):4574-4580. EXC6. [pmid: 22025157].
1177 Ramirez N, Bandres E, Navarro A, et al. Epigenetic events in normal colonic mucosa surrounding colorectal cancer lesions. Eur J Cancer. Nov. 2008;44(17):2689-2695. EXC6. [pmid: 18938072].
1178 Ramsey SD, Burke W, Clarke L. An economic viewpoint on alternative strategies for identifying persons with hereditary nonpolyposis colorectal cancer (Structured abstract). Genetics in Medicine. 2003;(5):353-336. EXC4. [pmid: 14501830].
1179 Ramsey SD, Clarke L, Etzioni R, et al. Cost-effectiveness of microsatellite instability screening as a method for detecting hereditary nonpolyposis colorectal cancer (Structured abstract). Ann Intern Med. 2001;(8 Part 1):577-588. EXC6. [pmid: 11601929].
1180 Rao B, Gao Y, Huang J, et al. Mutations of p53 and K-ras correlate TF expression in human colorectal carcinomas: TF downregulation as a marker of poor prognosis. Int J Colorectal Dis. May. 2011;26(5):593-601. EXC5. [pmid: 21404058].
1181 Rao C, Hu Q, Ma J, et al. Comparison of the epidermal growth factor receptor protein expression between primary non-small cell lung cancer and paired lymph node metastases: implications for targeted nuclide radiotherapy. J Exp Clin Cancer Res. 2010;29:7. EXC4. [pmid: 20096104].
1182 Raptis S, Mrkonjic M, Green RC, et al. MLH1-93G>A promoter polymorphism and the risk of microsatellite-unstable colorectal cancer. J Natl Cancer Inst. Mar. 21. 2007;99(6):463-474. EXC6. [pmid: 17374836].
1183 Rasuck CG, Leite SMO, Komatsuzaki F, et al. Association between methylation in mismatch repair genes, V600E BRAF mutation and microsatellite instability in colorectal cancer patients. Mol Biol Rep. 2012;39(3):2553-2560. EXC6. [pmid: 21681432].
1184 Rasul KI, Kerr DJ. QUASAR results: The prognostic validity of a colon cancer recurrence score and the role of multigene profiles in determining risk. Curr Colorectal Cancer Rep. 2010;6:144-147. EXC2.
1185 Rawson JB, Manno M, Mrkonjic M, et al. Promoter methylation of Wnt antagonists DKK1 and SFRP1 is associated with opposing tumor subtypes in two large populations of colorectal cancer patients. Carcinogenesis. 2011;32(5):741-747. EXC4. [pmid: 21304055].
1186 Ready N, Janne PA, Bogart J, et al. Chemoradiotherapy and gefitinib in stage III non-small cell lung cancer with epidermal growth factor receptor and KRAS mutation analysis: cancer and leukemia group B (CALEB) 30106, a CALGB-stratified phase II trial. J Thorac Oncol. Sep. 2010;5(9):1382-1390. EXC6. [pmid: 20686428].
1187 Rebersek M, Boc M, Cerkovnik P, et al. Efficacy of first-line systemic treatment in correlation with BRAF V600E and different KRAS mutations in metastatic colorectal cancer-a single institution retrospective analysis. Radiology and Oncology. 2011;45(4):285-291. EXC3. [pmid: 22933967].
1188 Rector TS, Taylor BC, Wilt TJ. Systematic review of prognostic tests Chapter 12 of Methods Guide for Medical Test Reviews. AHRQ Publication No. 12-EHC017. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm. Also published in a special supplement to the Journal of General Internal Medicine, July 2012. EXC2.
1189 Reed SD, Dinan MA, Schulman KA, et al. Cost-effectiveness of the 21-gene recurrence score assay in the context of multifactorial decision making to guide chemotherapy for early-stage breast cancer. Genet Med. Mar. 2013;15(3):203-211. EXC2. [pmid: 22975761].
1190 Reid JF, Gariboldi M, Sokolova V, et al. Integrative approach for prioritizing cancer genes in sporadic colon cancer. Genes Chromosomes Cancer. Nov. 2009;48(11):953-962. EXC4. [pmid: 19672874].
1191 Reidy DL, Vakiani E, Fakih MG, et al. Randomized, phase II study of the insulin-like growth factor-1 receptor inhibitor IMC-A12, with or without cetuximab, in patients with cetuximab- or panitumumab-refractory metastatic colorectal cancer. J Clin Oncol. Sep. 20. 2010;28(27):4240-4246. EXC4. [pmid: 20713879].
1192 Reissmann PT, Koga H, Figlin RA, et al. Amplification and overexpression of the cyclin D1 and epidermal growth factor receptor genes in non-small-cell lung cancer. Lung Cancer Study Group. J Cancer Res Clin Oncol. 1999;125(2):61-70. EXC4. [pmid: 10190311].
1193 Rekhtman N, Brandt SM, Sigel CS, et al. Suitability of thoracic cytology for new therapeutic paradigms in non-small cell lung carcinoma: high accuracy of tumor subtyping and feasibility of EGFR and KRAS molecular testing. J Thorac Oncol. Mar. 2011;6(3):451-458. EXC6. [pmid: 21266922].
1194 Rekhtman N, Paik PK, Arcila ME, et al. Clarifying the spectrum of driver oncogene mutations in biomarker-verified squamous carcinoma of lung: lack of EGFR/KRAS and presence of PIK3CA/AKT1 mutations. Clin Cancer Res. Feb. 15. 2012;18(4):1167-1176. EXC6. [pmid: 22228640].
1195 Ren S, Chen X, Kuang P, et al. Association of EGFR mutation or ALK rearrangement with expression of DNA repair and synthesis genes in never-smoker women with pulmonary adenocarcinoma. Cancer. Nov. 15. 2012;118(22):5588-5594. EXC6. [pmid: 22569898].
1196 Ren S, Kuang P, Zheng L, et al. Analysis of driver mutations in female non-smoker Asian patients with pulmonary adenocarcinoma. Cell Biochem Biophys. Nov. 2012;64(2):155-160. EXC6. [pmid: 22707299].
1197 Renouf DJ, Wood-Baker R, Ionescu DN, et al. BCL-2 expression is prognostic for improved survival in non-small cell lung cancer. J Thorac Oncol. 2009;4(4):486-491. EXC4. [pmid: 19240654].
1198 Retel VP, Joore MA, Harten WH. Head-to-head comparison of the 70-gene signature versus the 21-gene assay: cost-effectiveness and the effect of compliance (Provisional abstract). Breast Cancer Res Treat. 2012;(2):627-636. EXC5. [pmid: 21947677].
1199 Revuelta I, Moya-Rull D, Garcia-Herrera A, et al. Role of oncogenic pathways and KRAS/BRAF mutations in the behavior of colon adenocarcinoma in renal transplant patients. Transplantation. Mar. 15. 2012;93(5):509-517. EXC3. [pmid: 22245873].
1200 Reyes CM, Allen BA, Terdiman JP, et al. Comparison of selection strategies for genetic testing of patients with hereditary nonpolyposis colorectal carcinoma: effectiveness and cost-effectiveness (Structured abstract). Cancer. 2002;(9):1848-1856. EXC3. [pmid: 12404277].
1201 Impact of the Recurrence Score on adjuvant decision-making in ER-positive early breast cancer - results of a large prospective multicentre decision impact study in node negative and node positive disease. SABCS. 2011. Exc2.
1202 Ribic CM, Sargent DJ, Moore MJ, et al. Tumor microsatellite-instability status as a predictor of benefit from fluorouracil-based adjuvant chemotherapy for colon cancer. The New England journal of medicine. 2003;(3):247-257. EXC3. [pmid: 12867608].
1203 Ricciardiello L, Ceccarelli C, Angiolini G, et al. High thymidylate synthase expression in colorectal cancer with microsatellite instability: implications for chemotherapeutic strategies. Clin Cancer Res. Jun. 1. 2005;11(11):4234-4240. EXC6. [pmid: 15930362].
1204 Richardson CM, Richardson D, Swinson DE, et al. Cyclooxygenase-2 protein levels are independent of epidermal growth factor receptor expression or activation in operable non-small cell lung cancer. Lung Cancer. Apr. 2005;48(1):47-57. EXC4. [pmid: 15777970].
1205 Richman SD, Seymour MT, Chambers P, et al. KRAS and BRAF mutations in advanced colorectal cancer are associated with poor prognosis but do not preclude benefit from oxaliplatin or irinotecan: results from the MRC FOCUS trial. J Clin Oncol. 2009;(35):5931-5937. EXC3. [pmid: 19884549].
1206 Rickman OB, Vohra PK, Sanyal B, et al. Analysis of ErbB receptors in pulmonary carcinoid tumors. Clin Cancer Res. May. 15. 2009;15(10):3315-3324. EXC6. [pmid: 19447869].
1207 Riegert-Johnson DL, Johnson RA, Rabe KG, et al. The value of MUTYH testing in patients with early onset microsatellite stable colorectal cancer referred for hereditary nonpolyposis colon cancer syndrome testing. Genet Test. Winter. 2007;11(4):361-365. EXC4. [pmid: 18294051].
1208 Riely GJ, Kris MG, Rosenbaum D, et al. Frequency and distinctive spectrum of KRAS mutations in never smokers with lung adenocarcinoma. Clin Cancer Res. Sep. 15. 2008;14(18):5731-5734. EXC4. [pmid: 18794081].
1209 Riely GJ, Pao W, Pham D, et al. Clinical course of patients with non-small cell lung cancer and epidermal growth factor receptor exon 19 and exon 21 mutations treated with gefitinib or erlotinib. Clin Cancer Res. Feb. 1. 2006;12(3 Pt 1):839-844. EXC4. [pmid: 16467097].
1210 Rigau V, Sebbagh N, Olschwang S, et al. Microsatellite instability in colorectal carcinoma. The comparison of immunohistochemistry and molecular biology suggests a role for hMSH6 [correction of hMLH6] immunostaining. ArchPathol Lab Med. Jun. 2003;127(6):694-700. EXC6. [pmid: 12741892].
1211 Rijcken FE, van der Sluis T, Hollema H, et al. Hyperplastic polyps in hereditary nonpolyposis colorectal cancer. Am J Gastroenterol. Oct. 2003;98(10):2306-2311. EXC3. [pmid: 14572584].
1212 Risinger JI, Barrett JC, Watson P, et al. Molecular genetic evidence of the occurrence of breast cancer as an integral tumor in patients with the hereditary nonpolyposis colorectal carcinoma syndrome. Cancer. May. 1. 1996;77(9):1836-1843. EXC3. [pmid: 8646682].
1213 Risio M, Malacarne D, Giaretti W. KRAS transitions and villous growth in colorectal adenomas. Cell Oncol. 2005;27(5-6):363-366. EXC3. [pmid: 16373972].
1214 Risques RA, Moreno V, Ribas M, et al. Genetic pathways and genome-wide determinants of clinical outcome in colorectal cancer. Cancer Res. Nov. 1. 2003;63(21):7206-7214. EXC6. [pmid: 14612515].
1215 Rizvi NA, Rusch V, Pao W, et al. Molecular characteristics predict clinical outcomes: prospective trial correlating response to the EGFR tyro sine kinase inhibitor gefitinib with the presence of sensitizing mutations in the tyrosine binding domain of the EGFR gene. Clin Cancer Res. May. 15. 2011;17(10):3500-3506. EXC6. [pmid: 21558399].
1216 Rodig SJ, Mino-Kenudson M, Dacic S, et al. Unique clinicopathologic features characterize ALK-rearranged lung adenocarcinoma in the western population. Clin Cancer Res. Aug. 15. 2009;15(16):5216-5223. EXC6. [pmid: 19671850].
1217 Rodriguez J, Zarate R, Bandres E, et al. Fc gamma receptor polymorphisms as predictive markers of Cetuximab efficacy in epidermal growth factor receptor downstream-mutated metastatic colorectal cancer. Eur J Cancer. Aug. 2012;48(12):1774-1780. EXC3. [pmid: 22305465].
1218 Rohde F, Rimkus C, Friederichs J, et al. Expression of osteopontin, a target gene of de-regulated Wnt signaling, predicts survival in colon cancer. Int J Cancer. Oct. 15. 2007;121(8):1717-1723. EXC4. [pmid: 17565744].
1219 Roman R, Verdu M, Calvo M, et al. Microsatellite instability of the colorectal carcinoma can be predicted in the conventional pathologic examination. A prospective multicentric study and the statistical analysis of 615 cases consolidate our previously proposed logistic regression model. Virchows Arch. May. 2010;456(5):533-541. EXC4. [pmid: 20393748].
1220 Romanowicz-Makowska H, Smolarz B, Langner E, et al. Analysis of microsatellite instability and BRCA1 mutations in patients from hereditary nonpolyposis colorectal cancer (HNPCC) family. Pol J Pathol. 2005;56(1):21-26. EXC3. [pmid: 15921010].
1221 Roncucci L, Mora E, Mariani F, et al. Myeloperoxidase-positive cell infiltration in colorectal carcinogenesis as indicator of colorectal cancer risk. Cancer Epidemiol Biomarkers Prev. Sep. 2008;17(9):2291-2297. EXC4. [pmid: 18768495].
1222 Rose JS, Serna DS, Martin LK, et al. Influence of KRAS mutation status in metachronous and synchronous metastatic colorectal adenocarcinoma. Cancer. Dec. 15. 2012;118(24):6243-6252. EXC3. [pmid: 22674181].
1223 Rosell R, Carcereny E, Gervais R, et al. Erlotinib versus standard chemotherapy as first-line treatment for European patients with advanced EGFR mutation-positive non-small-cell lung cancer (EURTAC): a multicentre, open-label, randomised phase 3 trial. Lancet Oncol. Mar. 2012;13(3):239-246. EXC4. [pmid: 22285168].
1224 Rosell R, Molina MA, Costa C, et al. Pretreatment EGFR T790M mutation and BRCA1 mRNA expression in erlotinib-treated advanced non-small-cell lung cancer patients with EGFR mutations. Clin Cancer Res. Mar. 1. 2011;17(5):1160-1168. EXC6. [pmid: 21233402].
1225 Rosell R, Moran T, Cardenal F, et al. Predictive biomarkers in the management of EGFR mutant lung cancer. Ann N Y Acad Sci. Oct. 2010;1210:45-52. EXC2. [pmid: 20973798].
1226 Rosell R, Moran T, Queralt C, et al. Screening for epidermal growth factor receptor mutations in lung cancer. N Engl J Med. Sep. 3. 2009;361(10):958-967. EXC6. [pmid: 19692684].
1227 Rosell R, Perez-Roca L, Sanchez JJ, et al. Customized treatment in non-small-cell lung cancer based on EGFR mutations and BRCA1 mRNA expression. PLoS One. 2009;4(5):e5133. EXC5. [pmid: 19415121].
1228 Rosell R, Robinet G, Szczesna A, et al. Randomized phase II study of cetuximab plus cisplatin/vinorelbine compared with cisplatin/vinorelbine alone as first-line therapy in EGFR-expressing advanced non-small-cell lung cancer. Ann Oncol. Feb. 2008;19(2):362-369. EXC5. [pmid: 17947225].
1229 Ross HJ, Blumenschein GR Jr, Aisner J, et al. Randomized phase II multicenter trial of two schedules of lapatinib as first- or second-line monotherapy in patients with advanced or metastatic non-small cell lung cancer. Clin Cancer Res. Mar. 15. 2010;16(6):1938-1949. EXC6. [pmid: 20215545].
1230 Rosty C, Buchanan DD, Walsh MD, et al. Phenotype and polyp landscape in serrated polyposis syndrome: a series of 100 patients from genetics clinics. Am J Surg Pathol. Jun. 2012;36(6):876-882. EXC3. [pmid: 22510757].
1231 Rosty C, Chazal M, Etienne MC, et al. Determination of microsatellite instability, p53 and K-ras mutations in hepatic metastases from patients with colorectal cancer: Relationship with response to 5-fluorouracil and survival. Int J Cancer. 2001;95(3):162-167. EXC6. [pmid: 11307149].
1232 Roupret M, Azzouzi AR, Cussenot O. Microsatellite instability and transitional cell carcinoma of the upper urinary tract. BJU Int. Sep. 2005;96(4):489-492. EXC4. [pmid: 16104897].
1233 Rovella V, Carrara S, Crucitti SC, et al. Familial microsatellite-stable non-polyposis colorectal cancer: incidence and characteristics in a clinic-based population. Ann Oncol. Jun. 2001;12(6):813-818. EXC4. [pmid: 11484957].
1234 Rozek LS, Lipkin SM, Fearon ER, et al. CDX2 polymorphisms, RNA expression, and risk of colorectal cancer. Cancer Res. Jul. 1. 2005;65(13):5488-5492. EXC4. [pmid: 15994917].
1235 Rudzki Z, Zazula M, Okon K, et al. Low-level microsatellite instability colorectal carcinomas: do they really belong to a "gray zone" between high-level microsatellite instability and microsatellite-stable cancers?. Int J Colorectal Dis. May. 2003;18(3):216-221. EXC6. [pmid: 12673486].
1236 Ruibal A, Nunez MI, Rodriguez J, et al. Cytosolic levels of neuron-specific enolase in squamous cell carcinomas of the lung. Int J Biol Markers. Jul-Sep. 2003;18(3):188-194. EXC4. [pmid: 14535589].
1237 Ruiz MIG, Floor K, Steinberg SM, et al. Combined assessment of EGFR pathway-related molecular markers and prognosis of NSCLC patients. Br J Cancer. 2009;100(1):145-152. Exc6. [pmid: 19050706].
1238 Ruiz MIG, Van Cruijsen H, Smit EF, et al. Genetic heterogeneity in patients with multiple neoplastic lung lesions: A report of three cases. J Thorac Oncol. 2007;2(1):12-21. EXC7. [pmid: 17410004].
1239 Rumilla K, Schowalter KV, Lindor NM, et al. Frequency of deletions of EPCAM (TACSTD1) in MSH2-associated Lynch syndrome cases. J Mol Diagn. Jan. 2011;13(1):93-99. EXC3. [pmid: 21227399].
1240 Rusch V, Baselga J, Cordon-Cardo C, et al. Differential expression of the epidermal growth factor receptor and its ligands in primary non-small cell lung cancers and adjacent benign lung. Cancer Res. May. 15. 1993;53(10 Suppl):2379-2385. EXC4. [pmid: 7683573].
1241 Russell PA, Barnett SA, Walkiewicz M, et al. Correlation of mutation status and survival with predominant histologic subtype according to the new IASLC/ATS/ERS lung adenocarcinoma classification in stage III (N2) patients. J Thorac Oncol. Apr. 2013;8(4):461-468. EXC7. [pmid: 23486266].
1242 Russo A, Sala P, Alberici P, et al. Prognostic relevance of MLH1 and MSH2 mutations in hereditary non-polyposis colorectal cancer patients. Tumori. Nov-Dec. 2009;95(6):731-738. EXC4. [pmid: 20210238].
1243 Rutgers E, Piccart-Gebhart MJ, Bogaerts J, et al. Baseline results of the EORTC 10041/MINDACT TRIAL (Microarray In Node 0-3 positive Disease may Avoid ChemoTherapy). ASCO Gastrointestinal Symposium. 2013. San Francisco, CA. EXC6.
1244 Rutgers E, Piccart-Gebhart MJ, Bogaerts J, et al. The EORTC 10041/BIG 03-04 MIND ACT trial is feasible: results of the pilot phase. Eur J Cancer. Dec. 2011;47(18):2742-2749. EXC 6. [pmid: 22051734].
1245 Rutten A, Burgdorf W, Hugel H, et al. Cystic sebaceous tumors as marker lesions for the Muir-Torre syndrome: a histopathologic and molecular genetic study. Am J Dermatopathol. Oct. 1999;21(5):405-413. EXC4. [pmid: 10535567].
1246 Ryan BM, Lefort F, McManus R, et al. A prospective study of circulating mutant KRAS2 in the serum of patients with colorectal neoplasia: strong prognostic indicator in postoperative follow up. Gut. Jan. 2003;52(1):101-108. EXC4. [pmid: 12477769].
1247 Ryan P, Mulligan AM, Aronson M, et al. Comparison of clinical schemas and morphologic features in predicting Lynch syndrome in mutation-positive patients with endometrial cancer encountered in the context of familial gastrointestinal cancer registries. Cancer. Feb. 1. 2012;118(3):681-688. EXC3. [pmid: 21721000].
1248 Sahoo R, Harini VV, Babu VC, et al. Screening for EGFR mutations in lung cancer, a report from India. Lung Cancer. Sep. 2011;73(3):316-319. EXC6. [pmid: 21315473].
1249 Saif MW, Kaley K, Penney R, et al. The efficacy of gemcitabine as salvage treatment in patients with refractory advanced colorectal cancer (CRC): a single institution experience. Anticancer Res. Sep. 2011;31(9):2971-2974. EXC4. [pmid: 21868546].
1250 Saisho S, Yasuda K, Maeda A, et al. Post-recurrence survival of patients with non-small-cell lung cancer after curative resection with or without induction/adjuvant chemotherapy. Interact Cardiovasc Thorac Surg. Feb. 2013;16(2):166-172. EXC3. [pmid: 23143203].
1251 Sakuma Y, Matsukuma S, Yoshihara M, et al. Epidermal growth factor receptor gene mutations in atypical adenomatous hyperplasias of the lung. Mod Pathol. Sep. 2007;20(9):967-973. EXC3. [pmid: 17618248].
1252 Sakuma Y, Matsukuma S, Yoshihara M, et al. Distinctive evaluation of nonmucinous and mucinous subtypes of bronchioloalveolar carcinomas in EGFR and K-ras gene-mutation analyses for Japanese lung adenocarcinomas: confirmation of the correlations with histologic subtypes and gene mutations. Am J Clin Pathol. Jul. 2007;128(1):100-108. EXC6. [pmid: 17580276].
1253 Salahshor S, Kressner U, Fischer H, et al. Microsatellite instability in sporadic colorectal cancer is not an independent prognostic factor. Br J Cancer. Sep. 1999;81(2):190-193. EXC4. [pmid: 10496341].
1254 Salam MA, Elnahhas T, Azim HA, et al. The effect of EGFR overexpression in inoperable non-small cell lung cancer (NSCLC) patients receiving cisplatin-vinorelbine combination. Turkish Journal of Cancer. 2006;36(1):11-18. EXC5.
1255 Salazar F, Molina MA, Sanchez-Ronco M, et al. First-line therapy and methylation status of CHFR in serum influence outcome to chemotherapy versus EGFR tyrosine kinase inhibitors as second-line therapy in stage IV non-small-cell lung cancer patients. Lung Cancer. Apr. 2011;72(1):84-91. EXC4. [pmid: 20705357].
1256 Salazar R, Roepman P, Capella G, et al. Gene expression signature to improve prognosis prediction of stage II and III colorectal cancer. J Clin Oncol. Jan. 1. 2011;29(1):17-24. EXC4. [pmid: 21098318].
1257 Salido M, Pijuan L, Martinez-Aviles L, et al. Increased ALK gene copy number and amplification are frequent in non-small cell lung cancer. J Thorac Oncol. Jan. 2011;6(1):21-27. EXC6. [pmid: 21107285].
1258 Salovaara R, Loukola A, Kristo P, et al. Population-based molecular detection of hereditary nonpolyposis colorectal cancer. J Clin Oncol. Jun. 2000;18(11):2193-2200. EXC4. [pmid: 10829038].
1259 Salto-Tellez M, Lee SC, Chiu LL, et al. Microsatellite instability in colorectal cancer: considerations for molecular diagnosis and high-throughput screening of archival tissues. Clin Chem. Jun. 2004;50(6):1082-1086. EXC4. [pmid: 15161730].
1260 Salto-Tellez M, Tan SY, Chiu LL, et al. Dinucleotide microsatellite repeats are essential for the diagnosis of microsatellite instability in colorectal cancer in Asian patients. World J Gastroenterol. May. 14. 2005;11(18):2781-2783. EXC6. [pmid: 15884122].
1261 Saltz L, Badarinath S, Dakhil S, et al. Phase III trial of cetuximab, bevacizumab, and 5-fluorouracil/leucovorin vs. FOLFOX-bevacizumab in colorectal cancer. Clin Colorectal Cancer. Jun. 2012;11(2):101-111. EXC4. [pmid: 22055112].
1262 Salvesen HB, Macdonald N, Ryan A, et al. Methylation of hMLH1 in a population-based series of endometrial carcinomas. Clin Cancer Res. 2000;6(9):3607-3613. EXC6. [pmid: 10999752].
1263 Sameer AS, Chowdri NA, Syeed N, et al. SMAD4--molecular gladiator of the TGF-beta signaling is trampled upon by mutational insufficiency in colorectal carcinoma of Kashmiri population: an analysis with relation to KRAS proto-oncogene. BMC Cancer. 2010;10:300. EXC4. [pmid: 20565773].
1264 Sammoud S, Khiari M, Semeh A, et al. Relationship between expression of ras p21 oncoprotein and mutation status of the K-ras gene in sporadic colorectal cancer patients in Tunisia. Appl Immunohistochem Mol Morphol. Mar. 2012;20(2):146-152. EXC6. [pmid: 21768877].
1265 Samowitz WS, Albertsen H, Herrick J, et al. Evaluation of a large, population-based sample supports a CpG island methylator phenotype in colon cancer. Gastroenterology. Sep. 2005;129(3):837-845. EXC4. [pmid: 16143123].
1266 Samowitz WS, Curtin K, Ma KN, et al. Microsatellite instability in sporadic colon cancer is associated with an improved prognosis at the population level. Cancer Epidemiol Biomarkers Prev. Sep. 2001;10(9):917-923. EXC4. [pmid: 11535541].
1267 Samowitz WS, Curtin K, Wolff RK, et al. The MLH1-93 G>A promoter polymorphism and genetic and epigenetic alterations in colon cancer. Genes Chromosomes Cancer. Oct. 2008;47(10):835-844. EXC4. [pmid: 18615680].
1268 Samowitz WS, Curtin K, Wolff RK, et al. Microsatellite instability and survival in rectal cancer. Cancer Causes Control. Nov. 2009;20(9):1763-1768. EXC4. [pmid: 19669908].
1269 Samowitz WS, Slattery ML. Transforming growth factor-beta receptor type 2 mutations and microsatellite instability in sporadic colorectal adenomas and carcinomas. Am J Pathol. Jul. 1997;151(1):33-35. EXC6. [pmid: 9212728].
1270 Samowitz WS, Slattery ML. Regional reproducibility of microsatellite instability in sporadic colorectal cancer. Genes Chromosomes Cancer. Oct. 1999;26(2):106-114. EXC4. [pmid: 10469448].
1271 Samowitz WS, Slattery ML, Kerber RA. Microsatellite instability in human colonic cancer is not a useful clinical indicator of familial colorectal cancer. Gastroenterology. Dec. 1995;109(6):1765-1771. EXC4. [pmid: 7498640].
1272 Samowitz WS, Slattery ML, Sweeney C, et al. APC mutations and other genetic and epigenetic changes in colon cancer. Mol Cancer Res. Feb. 2007;5(2):165-170. EXC6. [pmid: 17293392].
1273 Samowitz WS, Wolff RK, Ma KN, et al. Polymorphisms in insulin-related genes predispose to specific KRAS2 and TP53 mutations in colon cancer. Mutat Res. Mar. 20. 2006;595(1-2):117-124. EXC6. [pmid: 16448675].
1274 Sanchez JA, Krumroy L, Plummer S, et al. Genetic and epigenetic classifications define clinical phenotypes and determine patient outcomes in colorectal cancer. Br J Surg. Oct. 2009;96(10):1196-1204. EXC4. [pmid: 19787768].
1275 Sanchez JA, Vogel JD, Kalady MF, et al. Identifying Lynch syndrome: we are all responsible. Dis Colon Rectum. Dec. 2008;51(12):1750-1756. EXC4. [pmid: 18682882].
1276 Sanchez-de-Abajo A, de la Hoya M, van Puijenbroek M, et al. Molecular analysis of colorectal cancer tumors from patients with mismatch repair proficient hereditary nonpolyposis colorectal cancer suggests novel carcinogenic pathways. Clin Cancer Res. Oct. 1. 2007;13(19):5729-5735. EXC6. [pmid: 17908962].
1277 Sanchez-Navarro I, Gamez-Pozo A, Pinto A, et al. An 8-gene qRT-PCR-based gene expression score that has prognostic value in early breast cancer. BMC Cancer. 2010;10:336. EXC5. [pmid: 20584321].
1278 Sanders HR, Li HR, Bruey JM, et al. Exon scanning by reverse transcriptase-polymerase chain reaction for detection of known and novel EML4-ALK fusion variants in non-small cell lung cancer. Cancer Genet. Jan. 2011;204(1):45-52. EXC5. [pmid: 21356191].
1279 Sanford M, Scott LJ. Gefitinib: a review of its use in the treatment of locally advanced/metastatic non-small cell lung cancer. Drugs. Nov. 12. 2009;69(16):2303-2328. EXC2. [pmid: 19852530].
1280 Santarpia M, Magri I, Sanchez-Ronco M, et al. mRNA expression levels and genetic status of genes involved in the EGFR and NF-kappaB pathways in metastatic non-small-cell lung cancer patients. J Transl Med. 2011;9:163. EXC6. [pmid: 21951562].
1281 Santini D, Loupakis F, Vincenzi B, et al. High concordance of KRAS status between primary colorectal tumors and related metastatic sites: implications for clinical practice. Oncologist. Dec. 2008;13(12):1270-1275. EXC6. [pmid: 19056857].
1282 Santis G, Angell R, Nickless G, et al. Screening for EGFR and KRAS mutations in endobronchial ultrasound derived transbronchial needle aspirates in non-small cell lung cancer using COLD-PCR. PLoS One. 2011;6(9):e25191. EXC6. [pmid: 21949883].
1283 Santoro A, Cavina R, Latteri F, et al. Activity of a specific inhibitor, gefitinib (Iressa, ZD1839), of epidermal growth factor receptor in refractory non-small-cell lung cancer. Ann Oncol. Jan. 2004;15(1):33-37. EXC4. [pmid: 14679116].
1284 Sargent DJ, Marsoni S, Monges G, et al. Defective mismatch repair as a predictive marker for lack of efficacy of fluorouracil-based adjuvant therapy in colon cancer. J Clin Oncol. Jul. 10. 2010;28(20):3219-3226. EXC4. [pmid: 20498393].
1285 Saridaki Z, Papadatos-Pastos D, Tzardi M, et al. BRAF mutations, microsatellite instability status and cyclin D1 expression predict metastatic colorectal patients outcome. Br J Cancer. 2010;102(12):1762-1768. EXC3. [pmid: 20485284].
1286 Saridaki Z, Tzardi M, Papadaki C, et al. Impact of KRAS, BRAF, PIK3CA mutations, PTEN, AREG, EREG expression and skin rash in >/= 2 line cetuximab-based therapy of colorectal cancer patients. PLoS One. 2011;6(1):e15980. EXC3. [pmid: 21283802].
1287 Sarkaria IS, Zakowski MF, Pham D, et al. Epidermal growth factor receptor signaling in adenocarcinomas with bronchioloalveolar components. Ann Thorac Surg. Jan. 2008;85(1):216-223. EXC4. [pmid: 18154814].
1288 Sarli L, Bottarelli L, Azzoni C, et al. Loss of p27 expression and microsatellite instability in sporadic colorectal cancer. Surg Oncol. Aug. 2006;15(2):97-106. EXC4. [pmid: 17123889].
1289 Sarli L, Bottarelli L, Bader G, et al. Association between recurrence of sporadic colorectal cancer, high level of microsatellite instability, and loss of heterozygosity at chromosome 18q. Dis Colon Rectum. Sep. 2004;47(9):1467-1482. EXC4. [pmid: 15486743].
1290 Sarosdy MF, Kahn PR, Ziffer MD, et al. Use of a multitarget fluorescence in situ hybridization assay to diagnose bladder cancer in patients with hematuria. J Urol. Jul. 2006;176(1):44-47. EXC3. [pmid: 16753364].
1291 Sarosdy MF, Schellhammer P, Bokinsky G, et al. Clinical evaluation of a multi-target fluorescent in situ hybridization assay for detection of bladder cancer. J Urol. Nov. 2002;168(5):1950-1954. EXC6. [pmid: 12394683].
1292 Sartore-Bianchi A, Di Nicolantonio F, Nichelatti M, et al. Multi-determinants analysis of molecular alterations for predicting clinical benefit to EGFR-targeted monoclonal antibodies in colorectal cancer. PLoS One. 2009;4(10):e7287. EXC3. [pmid: 19806185].
1293 Sartore-Bianchi A, Martini M, Molinari F, et al. PIK3CA mutations in colorectal cancer are associated with clinical resistance to EGFR-targeted monoclonal antibodies. Cancer Res. Mar. 1. 2009;69(5):1851-1857. EXC3. [pmid: 19223544].
1294 Sartori G, Bettelli S, Schirosi L, et al. Microsatellite and EGFR, HER2 and K-RAS analyses in sclerosing hemangioma of the lung. Am J Surg Pathol. Oct. 2007;31(10):1512-1520. EXC3. [pmid: 17895751].
1295 Sartori G, Cavazza A, Sgambato A, et al. EGFR and K-ras mutations along the spectrum of pulmonary epithelial tumors of the lung and elaboration of a combined clinicopathologic and molecular scoring system to predict clinical responsiveness to EGFR inhibitors. Am J Clin Pathol. Apr. 2009;131(4):478-489. EXC6. [pmid: 19289583].
1296 Sasaki H, Endo K, Konishi A, et al. EGFR Mutation status in Japanese lung cancer patients: genotyping analysis using LightCycler. Clin Cancer Res. Apr. 15. 2005;11(8):2924-2929. EXC4. [pmid: 15837743].
1297 Sasaki H, Endo K, Okuda K, et al. Epidermal growth factor receptor gene amplification and gefitinib sensitivity in patients with recurrent lung cancer. J Cancer Res Clin Oncol. May. 2008;134(5):569-577. EXC3. [pmid: 17932690].
1298 Sasaki H, Hikosaka Y, Kawano O, et al. Evaluation of Kras gene mutation and copy number gain in non-small cell lung cancer. J Thorac Oncol. Jan. 2011;6(1):15-20. EXC4. [pmid: 21150464].
1299 Sasaki H, Kawano O, Endo K, et al. EGFRvIII mutation in lung cancer correlates with increased EGFR copy number. Oncol Rep. Feb. 2007;17(2):319-323. EXC6. [pmid: 17203167].
1300 Sasaki H, Okuda K, Endo K, et al. CCND1 messenger RNA expression is correlated with EGFR mutation status in lung cancer. Clin Lung Cancer. Sep. 2007;8(8):493-496. EXC4. [pmid: 17922974].
1301 Sasaki H, Okuda K, Kawano O, et al. Fibroblast growth factor receptor 4 mutation and polymorphism in Japanese lung cancer. Oncol Rep. 2008;20(5):1125-1130. EXC4. [pmid: 18949411].
1302 Sasaki H, Okuda K, Takada M, et al. A novel EGFR mutation D1012H and polymorphism at exon 25 in Japanese lung cancer. J Cancer Res Clin Oncol. 2008;134(12):1371-1376. EXC3. [pmid: 18478265].
1303 Sasaki H, Shimizu S, Endo K, et al. EGFR and erbB2 mutation status in Japanese lung cancer patients. Int J Cancer. Jan. 1. 2006;118(1):180-184. EXC7. [pmid: 16003726].
1304 Sasaki H, Shitara M, Yokota K, et al. Overexpression of GLUT1 correlates with Kras mutations in lung carcinomas. Mol Med Report. Mar. 2012;5(3):599-602. EXC4. [pmid: 22200795].
1305 Sasaki H, Yukiue H, Mizuno K, et al. Elevated serum epidermal growth factor receptor level is correlated with lymph node metastasis in lung cancer. Int J Clin Oncol. Apr. 2003;8(2):79-82. EXC4. [pmid: 12720099].
1306 Sastre J, Gravalos C, Rivera F, et al. First-line cetuximab plus capecitabine in elderly patients with advanced colorectal cancer: clinical outcome and subgroup analysis according to KRAS status from a Spanish TTD Group Study. Oncologist. 2012;17(3):339-345. EXC3. [pmid: 22363067].
1307 Sato R, Suzuki T, Katayose Y, et al. Steroid sulfatase and estrogen sulfotransferase in colon carcinoma: regulators of intratumoral estrogen concentrations and potent prognostic factors. Cancer Res. Feb. 1. 2009;69(3):914-922. EXC4. [pmid: 19141651].
1308 Savic S, Zlobec I, Thalmann GN, et al. The prognostic value of cytology and fluorescence in situ hybridization in the follow-up of nonmuscle-invasive bladder cancer after intravesical Bacillus Calmette-Guerin therapy. Int J Cancer. Jun. 15. 2009;124(12):2899-2904. EXC7. [pmid: 19230026].
1309 Sawhney MS, Farrar WD, Gudiseva S, et al. Microsatellite instability in interval colon cancers. Gastroenterology. Dec. 2006;131(6):1700-1705. EXC4. [pmid: 17087932].
1310 Scagliotti GV, Novello S, Schiller JH, et al. Rationale and design of MARQUEE: a phase III, randomized, double-blind study of tivantinib plus erlotinib versus placebo plus erlotinib in previously treated patients with locally advanced or metastatic, nonsquamous, non-small-cell lung cancer. Clinical Lung Cancer. 2012;(5):391-395. EXC3. [pmid: 22440336].
1311 Scartozzi M, Bianchi F, Rosati S, et al. Mutations of hMLH1 and hMSH2 in patients with suspected hereditary nonpolyposis colorectal cancer: correlation with microsatellite instability and abnormalities of mismatch repair protein expression. J Clin Oncol. Mar. 1. 2002;20(5):1203-1208. EXC4. [pmid: 11870161].
1312 Scartozzi M, Giampieri R, Maccaroni E, et al. Analysis of HER-3, insulin growth factor-1, nuclear factor-kB and epidermal growth factor receptor gene copy number in the prediction of clinical outcome for K-RAS wild-type colorectal cancer patients receiving irinotecan-cetuximab. Ann Oncol. Jul. 2012;23(7):1706-1712. EXC3. [pmid: 22112971].
1313 Scartozzi M, Mandolesi A, Giampieri R, et al. Insulin-like growth factor 1 expression correlates with clinical outcome in K-RAS wild type colorectal cancer patients treated with cetuximab and irinotecan. Int J Cancer. Oct. 15. 2010;127(8):1941-1947. EXC3. [pmid: 20099280].
1314 Schafmayer C, Buch S, Volzke H, et al. Investigation of the colorectal cancer susceptibility region on chromosome 8q24.21 in a large German case-control sample. Int J Cancer. Jan. 1. 2009;124(1):75-80. EXC4. [pmid: 18839428].
1315 Scheel SK, Porzner M, Pfeiffer S, et al. Mutations in the WTX-gene are found in some high-grade microsatellite instable (MSI-H) colorectal cancers. BMC Cancer. 2010;10:413. EXC4. [pmid: 20696052].
1316 Schiemann U, Gunther S, Gross M, et al. Preoperative serum levels of the carcinoembryonic antigen in hereditary non-polyposis colorectal cancer compared to levels in sporadic colorectal cancer. Cancer Detect Prev. 2005;29(4):356-360. EXC4. [pmid: 16122885].
1317 Schiller JH, von Pawel J, Schutt P, et al. Pemetrexed with or without matuzumab as second-line treatment for patients with stage IIIB/IV non-small cell lung cancer. J Thorac Oncol. Dec. 2010;5(12):1977-1985. EXC4. [pmid: 20978446].
1318 Schimanski CC, Moehler M, Gockel I, et al. Expression of chemokine receptor CCR5 correlates with the presence of hepatic molecular metastases in K-ras positive human colorectal cancer. J Cancer Res Clin Oncol. Jul. 2011;137(7):1139-1145. EXC4. [pmid: 21468700].
1319 Schimanski CC, Zimmermann T, Schmidtmann I, et al. K-ras mutation status correlates with the expression of VEGFR1, VEGFR2, and PDGFRalpha in colorectal cancer. Int J Colorectal Dis. Feb. 2010;25(2):181-186. EXC6. [pmid: 19936766].
1320 Schirosi L, Lantuejoul S, Cavazza A, et al. Pleuro-pulmonary solitary fibrous tumors: a clinicopathologic, immunohistochemical, and molecular study of 88 cases confirming the prognostic value of de Perrot staging system and p53 expression, and evaluating the role of c-kit, BRAF, PDGFRs (alpha/beta), c-met, and EGFR. Am J Surg Pathol. Nov. 2008;32(11):1627-1642. EXC3. [pmid: 18753943].
1321 Schittenhelm MM, Kollmannsberger C, Oechsle K, et al. Molecular determinants of response to matuzumab in combination with paclitaxel for patients with advanced non-small cell lung cancer. Mol Cancer Ther. Mar. 2009;8(3):481-489. EXC6. [pmid: 19276157].
1322 Schlegel J, Bocker T, Zirngibl H, et al. Detection of microsatellite instability in human colorectal carcinomas using a non-radioactive PCR-based screening technique. Virchows Arch. 1995;426(3):223-227. EXC4. [pmid: 7773500].
1323 Schlomer BJ, Ho R, Sagalowsky A, et al. Prospective validation of the clinical usefulness of reflex fluorescence in situ hybridization assay in patients with atypical cytology for the detection of urothelial carcinoma of the bladder. J Urol. Jan. 2010;183(1):62-67. EXC3. [pmid: 19913822].
1324 Schmid K, Oehl N, Wrba F, et al. EGFR/KRAS/BRAF mutations in primary lung adenocarcinomas and corresponding locoregional lymph node metastases. Clin Cancer Res. Jul. 15. 2009;15(14):4554-4560. EXC6. [pmid: 19584155].
1325 Schnabel PA, Smit E, Carpeno Jde C, et al. Influence of histology and biomarkers on first-line treatment of advanced non-small cell lung cancer in routine care setting: baseline results of an observational study (FRAME). Lung Cancer. Dec. 2012;78(3):263-269. EXC7. [pmid: 23040326].
1326 Schneider R, Schneider C, Kloor M, et al. Lynch syndrome: clinical, pathological, and genetic insights. Langenbecks Arch Surg. Apr. 2012;397(4):513-525. EXC7. [pmid: 22362054].
1327 Schoen RE. Families at risk for colorectal cancer: risk assessment and genetic testing. J Clin Gastroenterol. Sep. 2000;31(2):114-120. EXC7. [pmid: 10993425].
1328 Schofield L, Goldblatt J, Iacopetta B. Challenges in the diagnosis and management of Lynch Syndrome in an Indigenous family living in a remote West Australian community. Rural Remote Health. 2011;11(4):1836. EXC7. [pmid: 22188021].
1329 Schofield L, Watson N, Grieu F, et al. Population-based detection of Lynch syndrome in young colorectal cancer patients using microsatellite instability as the initial test. Int J Cancer. Mar. 1. 2009;124(5):1097-1102. EXC4. [pmid: 19072991].
1330 Scholtka B, Schneider M, Melcher R, et al. A gene marker panel covering the Wnt and the Ras-Raf-MEK-MAPK signalling pathways allows to detect gene mutations in 80% of early (UICC I) colon cancer stages in humans. Cancer Epidemiol. Aug. 2009;33(2):123-129. EXC4. [pmid: 19679059].
1331 Schulmann K, Brasch FE, Kunstmann E, et al. HNPCC-associated small bowel cancer: Clinical and molecular characteristics. Gastroenterology. 2005;128(3):590-599. EXC3. [pmid: 15765394].
1332 Schulmann K, Hahn SA, Brasch F, et al. Microsatellite instability and expression of MLH1 and MSH2 in carcinomas of the small intestine [2] (multiple letters). Cancer. 2003;98(8):1774-1776. EXC3. [pmid: 14534898].
1333 Schulmann K, Mori Y, Croog V, et al. Molecular phenotype of inflammatory bowel disease-associated neoplasms with microsatellite instability. Gastroenterology. Jul. 2005;129(1):74-85. EXC4. [pmid: 16012936].
1334 Scott LD. Ethical issues in genetic testing. Am J Gastroenterol. 2004;99(10):1871-1873. EXC2. [pmid: 15447741].
1335 Sedivy R, Wolf B, Kalipciyan M, et al. Genetic analysis of multiple synchronous lesions of the colon adenoma-carcinoma sequence. Br J Cancer. Apr. 2000;82(7):1276-1282. EXC2. [pmid: 10755401].
1336 Segal G, Liebermann N, Klang S, et al. [Identification of K-RAS mutations in colorectal cancer patients in Israel]. Harefuah. May. 2011;150(5):447-450. 91. EXC2. [pmid: 21678640].
1337 Sehofield L, Watson N, Grieu F, et al. Population-based detection of lynch syndrome in young colorectal cancer patients using microsatellite instability as the initial test. Int J Cancer. 2009;124(5):1097-1102. EXC6. [pmid: 19072991].
1338 Sekine A, Kato T, Hagiwara E, et al. Metastatic brain tumors from non-small cell lung cancer with EGFR mutations: distinguishing influence of exon 19 deletion on radiographic features. Lung Cancer. Jul. 2012;77(1):64-69. EXC6. [pmid: 22335887].
1339 Selamat SA, Chung BS, Girard L, et al. Genome-scale analysis of DNA methylation in lung adenocarcinoma and integration with mRNA expression. Genome Res. Jul. 2012;22(7):1197-1211. EXC4. [pmid: 22613842].
1340 Selvaggi G, Novello S, Torri V, et al. Epidermal growth factor receptor overexpression correlates with a poor prognosis in completely resected non-small-cell lung cancer. Ann Oncol. Jan. 2004;15(1):28-32. EXC4. [pmid: 14679115].
1341 Sengupta SB, Yiu CY, Boulos PB, et al. Genetic instability in patients with metachronous colorectal cancers. Br J Surg. Jul. 1997;84(7):996-1000. EXC4. [pmid: 9240146].
1342 Senkus E, Kyriakides S, Penault-Llorca F, et al. Primary breast cancer: ESMO Clinical Practice Guidelines for diagnosis, treatment and follow-up. Ann Oncol. Oct. Suppl 6. 2013;24:vi7-vi23. EXC7. [pmid: 23970019].
1343 Sequist LV, Gettinger S, Senzer NN, et al. Activity of IPI-504, a novel heat-shock protein 90 inhibitor, in patients with molecularly defined non-small-cell lung cancer. J Clin Oncol. Nov. 20. 2010;28(33):4953-4960. EXC6. [pmid: 20940188].
1344 Sequist LV, Martins RG, Spigel D, et al. First-line gefitinib in patients with advanced non-small-cell lung cancer harboring somatic EGFR mutations. J Clin Oncol. May. 20. 2008;26(15):2442-2449. EXC7. [pmid: 18458038].
1345 Sequist LV, von Pawel J, Garmey EG, et al. Randomized phase II study of erlotinib plus tivantinib versus erlotinib plus placebo in previously treated non-small-cell lung cancer. J Clin Oncol. Aug. 20. 2011;29(24):3307-3315. EXC3. [pmid: 21768463].
1346 Serrano M, Lage P, Belga S, et al. Bethesda criteria for microsatellite instability testing: impact on the detection of new cases of Lynch syndrome. Fam Cancer. Dec. 2012;11(4):571-578. EXC3. [pmid: 22776989].
1347 Seya T, Tanaka N, Shinji S, et al. Squamous cell carcinoma arising from recurrent anal fistula. J Nippon Med Sch. Aug. 2007;74(4):319-324. EXC2. [pmid: 17878704].
1348 Shah L, Walter KL, Borczuk AC, et al. Expression of syndecan-1 and expression of epidermal growth factor receptor are associated with survival in patients with nonsmall cell lung carcinoma. Cancer. Oct. 1. 2004;101(7):1632-1638. EXC4. [pmid: 15378500].
1349 Shannon B, Gnanasampanthan S, Beilby J, et al. A polymorphism in the methylenetetrahydrofolate reductase gene predisposes to colorectal cancers with microsatellite instability. Gut. 2002;50(4):520-524. EXC4. [pmid: 11889073].
1350 Shannon C, Kirk J, Barnetson R, et al. Incidence of microsatellite instability in synchronous tumors of the ovary and endometrium. Clin Cancer Res. 2003;9(4):1387-1392. EXC6. [pmid: 12684409].
1351 Shaozhang Z, Xiaomei L, Aiping Z, et al. Detection of EML4-ALK fusion genes in non-small cell lung cancer patients with clinical features associated with EGFR mutations. Genes Chromosomes Cancer. Oct. 2012;51(10):925-932. EXC6. [pmid: 22736493].
1352 Sharif S, O'Connell MJ. Gene Signatures in Stage II Colon Cancer: A Clinical Review. Curr Colorectal Cancer Rep. Sep. 2012;8(3):225-231. EXC2. [pmid: 23002390].
1353 Shaw AT, Yeap BY, Mino-Kenudson M, et al. Clinical features and outcome of patients with non-small-cell lung cancer who harbor EML4-ALK. J Clin Oncol. Sep. 10. 2009;27(26):4247-4253. EXC7. [pmid: 19667264].
1354 Shaw AT, Yeap BY, Solomon BJ, et al. Effect of crizotinib on overall survival in patients with advanced non-small-cell lung cancer harbouring ALK gene rearrangement: a retrospective analysis. Lancet Oncol. Oct. 2011;12(11):1004-1012. EXC5. [pmid: 21933749].
1355 Shemirani AI, Haghighi MM, Milanizadeh S, et al. The role of kras mutations and MSI status in diagnosis of colorectal cancer. Gastroenterology and Hepatology from Bed to Bench. 2011;4(2):70-75. EXC6. [pmid: 24834160].
1356 Shen H, Yuan Y, Hu HG, et al. Clinical significance of K-ras and BRAF mutations in Chinese colorectal cancer patients. World J Gastroenterol. Feb. 14. 2011;17(6):809-816. EXC6. [pmid: 21390154].
1357 Shen L, Kondo Y, Hamilton SR, et al. P14 methylation in human colon cancer is associated with microsatellite instability and wild-type p53. Gastroenterology. Mar. 2003;124(3):626-633. EXC4. [pmid: 12612901].
1358 Shen L, Toyota M, Kondo Y, et al. Integrated genetic and epigenetic analysis identifies three different subclasses of colon cancer. Proc Natl Acad Sci U S A. Nov. 20. 2007;104(47):18654-18659. EXC6. [pmid: 18003927].
1359 Sheng JQ, Chan TL, Chan YW, et al. Microsatellite instability and novel mismatch repair gene mutations in northern Chinese population with hereditary non-polyposis colorectal cancer. Chin J Dig Dis. 2006;7(4):197-205. EXC4. [pmid: 17054581].
1360 Shetty S, Thomas P, Ramanan B, et al. Kras mutations and p53 overexpression in pseudomyxoma peritonei: association with phenotype and prognosis. J Surg Res. Mar. 2013;180(1):97-103. EXC6. [pmid: 23199549].
1361 Shi X, Li J, Zhao C, et al. Methylation analysis of hMLH1 gene promoter by a bisulfite-sensitive single-strand conformation polymorphism-capillary electrophoresis method. Biomed Chromatogr. Aug. 2006;20(8):815-820. EXC6. [pmid: 16358356].
1362 Shia J, Black D, Hummer AJ, et al. Routinely assessed morphological features correlate with microsatellite instability status in endometrial cancer. Hum Pathol. 2008;39(1):116-125. EXC5. [pmid: 17949789].
1363 Shia J, Ellis NA, Paty PB, et al. Value of histopathology in predicting microsatellite instability in hereditary nonpolyposis colorectal cancer and sporadic colorectal cancer. Am J Surg Pathol. Nov. 2003;27(11):1407-1417. EXC6. [pmid: 14576473].
1364 Shia J, Klimstra DS, Nafa K, et al. Value of immunohistochemical detection of DNA mismatch repair proteins in predicting germline mutation in hereditary colorectal neoplasms. Am J Surg Pathol. Jan. 2005;29(1):96-104. EXC4. [pmid: 15613860].
1365 Shibata T, Hanada S, Kokubu A, et al. Gene expression profiling of epidermal growth factor receptor/KRAS pathway activation in lung adenocarcinoma. Cancer Science. 2007;98(7):985-991. EXC5. [pmid: 17459062].
1366 Shigematsu H, Takahashi T, Nomura M, et al. Somatic mutations of the HER2 kinase domain in lung adenocarcinomas. Cancer Res. Mar. 1. 2005;65(5):1642-1646. EXC6. [pmid: 15753357].
1367 Shigematsu H, Takahashi T, Nomura M, et al. Somatic mutations of the HER2 kinase domain in lung adenocarcinomas. Cancer Res. 2005;65(5):1642-1646. EXC6. [pmid: 15753357].
1368 Shima K, Morikawa T, Baba Y, et al. MGMT promoter methylation, loss of expression and prognosis in 855 colorectal cancers. Cancer Causes Control. Feb. 2011;22(2):301-309. EXC4. [pmid: 21140203].
1369 Shima K, Morikawa T, Yamauchi M, et al. TGFBR2 and BAX mononucleotide tract mutations, microsatellite instability, and prognosis in 1072 colorectal cancers. PLoS One. 2011;6(9):e25062. EXC4. [pmid: 21949851].
1370 Shima K, Nosho K, Baba Y, et al. Prognostic significance of CDKN2A (p16) promoter methylation and loss of expression in 902 colorectal cancers: Cohort study and literature review. Int J Cancer. Mar. 1. 2011;128(5):1080-1094. EXC6. [pmid: 20473920].
1371 Shin HJC, Thorson P, Gu J, et al. Detection of a subset of CD30+ anaplastic large cell lymphoma by interphase fluorescence in situ hybridization. Diagn Cytopathol. 2003;29(2):61-66. EXC3. [pmid: 12889041].
1372 Shin KH, Park YJ, Park JG. Mutational analysis of the transforming growth factor beta receptor type II gene in hereditary nonpolyposis colorectal cancer and early-onset colorectal cancer patients. Clin Cancer Res. Feb. 2000;6(2):536-540. EXC4. [pmid: 10690536].
1373 Shin Y, Kim IJ, Kang HC, et al. A functional polymorphism (-347 G-->GA) in the E-cadherin gene is associated with colorectal cancer. Carcinogenesis. Nov. 2004;25(11):2173-2176. EXC4. [pmid: 15231691].
1374 Shiozawa T, Ishii G, Goto K, et al. Clinicopathological characteristics of EGFR mutated adenosquamous carcinoma of the lung. Pathol Int. Feb. 2013;63(2):77-84. EXC7. [pmid: 23464964].
1375 Shiroiwa T, Motoo Y, Tsutani K. Cost-effectiveness analysis of KRAS testing and cetuximab as last-line therapy for colorectal cancer (Structured abstract). Molecular Diagnosis and Therapy. 2010;(6):375-384. EXC6. [pmid: 21275455].
1376 Shitara K, Ura T, Matsuo K, et al. Sensitivity to previous irinotecan treatment does not predict the efficacy of combination chemotherapy with cetuximab plus irinotecan for wild-type KRAS metastatic colorectal cancer. Eur J Cancer. Dec. 2011;47(18):2673-2680. EXC4. [pmid: 21652203].
1377 Shitara K, Yokota T, Takahari D, et al. Phase II study of combination chemotherapy with irinotecan and cetuximab for pretreated metastatic colorectal cancer harboring wild-type KRAS. Invest New Drugs. Aug. 2011;29(4):688-693. EXC4. [pmid: 20072801].
1378 Shitara K, Yuki S, Yoshida M, et al. Phase II study of combination chemotherapy with biweekly cetuximab and irinotecan for wild-type KRAS metastatic colorectal cancer refractory to irinotecan, oxaliplatin, and fluoropyrimidines. Invest New Drugs. Apr. 2012;30(2):787-793. EXC4. [pmid: 21174225].
1379 Shitara M, Sasaki H, Yokota K, et al. Polymorphisms in intron 1 of the EGFR gene in non-small cell lung cancer patients. Experimental and Therapeutic Medicine. 2012;4(5):785-789. EXC5. [pmid: 23226726].
1380 Shoji F, Yano T, Yoshino I, et al. The characteristics and failure pattern of gefitinib responders with postoperative recurrence of pulmonary adenocarcinoma. Eur J Surg Oncol. Jan. 2008;34(1):89-93. EXC5. [pmid: 17449217].
1381 Shoji F, Yoshino I, Yano T, et al. Serum carcinoembryonic antigen level is associated with epidermal growth factor receptor mutations in recurrent lung adenocarcinomas. Cancer. Dec. 15. 2007;110(12):2793-2798. EXC4. [pmid: 17941001].
1382 Sholl LM, Weremowicz S, Gray SW, et al. Combined use of ALK immunohistochemistry and FISH for optimal detection of ALK-rearranged lung adenocarcinomas. J Thorac Oncol. Mar. 2013;8(3):322-328. EXC5. [pmid: 23407557].
1383 Sholl LM, Xiao Y, Joshi V, et al. EGFR mutation is a better predictor of response to tyrosine kinase inhibitors in non-small cell lung carcinoma than FISH, CISH, and immunohistochemistry. Am J Clin Pathol. Jun. 2010;133(6):922-934. EXC6. [pmid: 20472851].
1384 Sholl LM, Yeap BY, Iafrate AJ, et al. Lung adenocarcinoma with EGFR amplification has distinct clinicopathologic and molecular features in never-smokers. Cancer Res. Nov. 1. 2009;69(21):8341-8348. EXC4. [pmid: 19826035].
1385 Shukuya T, Takahashi T, Naito T, et al. Continuous EGFR-TKI administration following radiotherapy for non-small cell lung cancer patients with isolated CNS failure. Lung Cancer. Dec. 2011;74(3):457-461. EXC5. [pmid: 21571388].
1386 Siah SP, Quinn DM, Bennett GD, et al. Microsatellite instability markers in breast cancer: a review and study showing MSI was not detected at 'BAT 25' and 'BAT 26' microsatellite markers in early-onset breast cancer. Breast Cancer Res Treat. Mar. 2000;60(2):135-142. EXC4. [pmid: 10845276].
1387 Silver A, Sengupta N, Propper D, et al. A distinct DNA methylation profile associated with microsatellite and chromosomal stable sporadic colorectal cancers. Int J Cancer. Mar. 1. 2012;130(5):1082-1092. EXC4. [pmid: 21455990].
1388 Simon RM, Paik S, Hayes DF. Use of archived specimens in evaluation of prognostic and predictive biomarkers. J Natl Cancer Inst. Nov. 4. 2009;101(21):1446-1452. EXC7. [pmid: 19815849].
1389 Simone G, Mangia A, Malfettone A, et al. Chromogenic in situ hybridization to detect EGFR gene copy number in cell blocks from fine-needle aspirates of non small cell lung carcinomas and lung metastases from colo-rectal cancer. J Exp Clin Cancer Res. 2010;29:125. EXC4. [pmid: 20843314].
1390 Simonetti S, Molina MA, Queralt C, et al. Detection of EGFR mutations with mutation-specific antibodies in stage IV non-small-cell lung cancer. J Transl Med. 2010;8:135. EXC6. [pmid: 21167064].
1391 Sinicrope F, Foster NR, Sargent DJ, et al. Model-based prediction of defective DNA mismatch repair using clinicopathological variables in sporadic colon cancer patients. Cancer. Apr. 1. 2010;116(7):1691-1698. EXC4. [pmid: 20186699].
1392 Sinicrope FA, Foster NR, Thibodeau SN, et al. DNA mismatch repair status and colon cancer recurrence and survival in clinical trials of 5-fluorouracil-based adjuvant therapy. J Natl Cancer Inst. Jun. 8. 2011;103(11):863-875. EXC4. [pmid: 21597022].
1393 Sinicrope FA, Rego RL, Garrity-Park MM, et al. Alterations in cell proliferation and apoptosis in colon cancers with microsatellite instability. Int J Cancer. Mar. 15. 2007;120(6):1232-1238. EXC4. [pmid: 17187355].
1394 Sinn DH, Chang DK, Kim YH, et al. Effectiveness of each Bethesda marker in defining microsatellite instability when screening for Lynch syndrome. Hepatogastroenterology. May-Jun. 2009;56(91-92):672-676. EXC4. [pmid: 19621678].
1395 Slattery ML, Curtin K, Schaffer D, et al. Associations between family history of colorectal cancer and genetic alterations in tumors. Int J Cancer. Feb. 20. 2002;97(6):823-827. EXC6. [pmid: 11857362].
1396 Slattery ML, Curtin K, Wolff R, et al. PPARgamma and colon and rectal cancer: associations with specific tumor mutations, aspirin, ibuprofen and insulin-related genes (United States). Cancer Causes Control. Apr. 2006;17(3):239-249. EXC4. [pmid: 16489531].
1397 Slattery ML, Curtin K, Wolff RK, et al. A comparison of colon and rectal somatic DNA alterations. Dis Colon Rectum. Jul. 2009;52(7):1304-1311. EXC4. [pmid: 19571709].
1398 Slattery ML, Herrick J, Curtin K, et al. Increased risk of colon cancer associated with a genetic polymorphism of SMAD7. Cancer Res. Feb. 15. 2010;70(4):1479-1485. EXC6. [pmid: 20124488].
1399 Slattery ML, Herrick JS, Lundgreen A, et al. Genetic variation in a metabolic signaling pathway and colon and rectal cancer risk: mTOR, PTEN, STK11, RPKAA1, PRKAG2, TSC1, TSC2, PI3K and Akt1. Carcinogenesis. Sep. 2010;31(9):1604-1611. EXC6. [pmid: 20622004].
1400 Slattery ML, Wolff RK, Herrick J, et al. Tumor markers and rectal cancer: support for an inflammation-related pathway. Int J Cancer. Oct. 1. 2009;125(7):1698-1704. EXC6. [pmid: 19452524].
1401 Slodkowska EA, Ross JS. MammaPrint 70-gene signature: another milestone in personalized medical care for breast cancer patients. Expert Rev Mol Diagn. Jul. 2009;9(5):417-422. EXC2. [pmid: 19580427].
1402 Smartt P. A comparison of gene expression profiling tests for breast cancer (Structured abstract). Health Technology Assessment Database. 2010;(3). EXC1.
1403 Smetana GW, Umscheid CA, Chang S, et al. Methods guide for authors of systematic reviews of medical tests: A collaboration between the Agency for Healthcare Research and Quality (AHRQ) and the Journal of General Internal Medicine. J Gen Intern Med. Jun. Suppl 1. 2012;27:S1-S3. EXC2. [pmid: 22648668].
1404 Smit EF, Dingemans AM, Thunnissen FB, et al. Sorafenib in patients with advanced non-small cell lung cancer that harbor K-ras mutations: a brief report. J Thorac Oncol. May. 2010;5(5):719-720. EXC5. [pmid: 20421765].
1405 Smith GD, Bentz JS. "FISHing" to detect urinary and other cancers: validation of an imaging system to aid in interpretation. Cancer Cytopathol. Feb. 25. 2010;118(1):56-64. EXC6. [pmid: 20099312].
1406 Smits AJ, Kummer JA, Hinrichs JW, et al. EGFR and KRAS mutations in lung carcinomas in the Dutch population: increased EGFR mutation frequency in malignant pleural effusion of lung adenocarcinoma. Cell Oncol (Dordr). Jun. 2012;35(3):189-196. EXC6. [pmid: 22528563].
1407 Smits KM, Paranjape T, Nallur S, et al. A let-7 microRNA SNP in the KRAS 3'UTR is prognostic in early-stage colorectal cancer. Clin Cancer Res. Dec. 15. 2011;17(24):7723-7731. EXC4. [pmid: 21994416].
1408 Smouse JH, Cibas ES, Janne PA, et al. EGFR mutations are detected comparably in cytologic and surgical pathology specimens of nonsmall cell lung cancer. Cancer. Feb. 25. 2009;117(1):67-72. EXC4. [pmid: 19347832].
1409 Soda M, Isobe K, Inoue A, et al. A prospective PCR-based screening for the EML4-ALK oncogene in non-small cell lung cancer. Clin Cancer Res. Oct. 15. 2012;18(20):5682-5689. EXC5. [pmid: 22908099].
1410 Soh J, Toyooka S, Aoe K, et al. Usefulness of EGFR mutation screening in pleural fluid to predict the clinical outcome of gefitinib treated patients with lung cancer. Int J Cancer. Nov. 15. 2006;119(10):2353-2358. EXC4. [pmid: 16921488].
1411 Soh J, Toyooka S, Ichihara S, et al. Sequential molecular changes during multistage pathogenesis of small peripheral adenocarcinomas of the lung. J Thorac Oncol. Apr. 2008;3(4):340-347. EXC6. [pmid: 18379350].
1412 Sohn BS, Kim TW, Lee JL, et al. The role of KRAS mutations in predicting the efficacy of cetuximab-plus-irinotecan therapy in irinotecan-refractory Korean metastatic colorectal cancer patients. Oncology. 2009;77(3-4):224-230. EXC3. [pmid: 19738388].
1413 Soliman AS, Bondy ML, El-Badawy SA, et al. Contrasting molecular pathology of colorectal carcinoma in Egyptian and Western patients. Br J Cancer. Sep. 28. 2001;85(7):1037-1046. EXC4. [pmid: 11592777].
1414 Soliman PT, Broaddus RR, Schmeler KM, et al. Women with synchronous primary cancers of the endometrium and ovary: do they have Lynch syndrome?. J Clin Oncol. Dec. 20. 2005;23(36):9344-9350. EXC3. [pmid: 16361634].
1415 Solin LJ. The Practical Use of Molecular Profiling: In Situ Carcinoma of the Breast: DCIS. 2012. EXC6.
1416 Solin LJ, Gray R, Baehner FL, et al. A multigene expression assay to predict local recurrence risk for ductal carcinoma in situ of the breast. J Natl Cancer Inst. May. 15. 2013;105(10):701-710. EXC7. [pmid: 23641039].
1417 Solomon SB, Zakowski MF, Pao W, et al. Core needle lung biopsy specimens: adequacy for EGFR and KRAS mutational analysis. AJR Am J Roentgenol. Jan. 2010;194(1):266-269. EXC4. [pmid: 20028932].
1418 Song MJ, Lee HM, Kim SH. Clinical usefulness of fluorescence in situ hybridization for diagnosis and surveillance of bladder cancer. Cancer Genet Cytogenet. 2010;198(2):144-150. EXC5. [pmid: 20362229].
1419 Sonnweber B, Dlaska M, Skvortsov S, et al. High predictive value of epidermal growth factor receptor phosphorylation but not of EGFRvIII mutation in resected stage I non-small cell lung cancer (NSCLC). J Clin Pathol. 2006;59(3):255-259. EXC4. [pmid: 16505275].
1420 Sonobe M, Date H, Wada H, et al. Prognostic factors after complete resection of pN2 non-small cell lung cancer. J Thorac Cardiovasc Surg. Oct. 2013;146(4):788-795. EXC7. [pmid: 23810113].
1421 Sonobe M, Kobayashi M, Ishikawa M, et al. Impact of KRAS and EGFR gene mutations on recurrence and survival in patients with surgically resected lung adenocarcinomas. Ann Surg Oncol. Jul. Suppl 3. 2012;19:S347-S354. EXC5. [pmid: 21607772].
1422 Sood A, McClain D, Maitra R, et al. PTEN gene expression and mutations in the PIK3CA gene as predictors of clinical benefit to anti-epidermal growth factor receptor antibody therapy in patients with KRAS wild-type metastatic colorectal cancer. Clin Colorectal Cancer. Jun. 2012;11(2):143-150. EXC3. [pmid: 22285706].
1423 Soreide K, Nedrebo BS, Soreide JA, et al. Lymph node harvest in colon cancer: influence of microsatellite instability and proximal tumor location. World J Surg. Dec. 2009;33(12):2695-2703. EXC4. [pmid: 19823901].
1424 Soreide K, Soreide JA, Korner H. Prognostic role of carcinoembryonic antigen is influenced by microsatellite instability genotype and stage in locally advanced colorectal cancers. World J Surg. Apr. 2011;35(4):888-894. EXC4. [pmid: 21301835].
1425 Soria JC, Baselga J, Hanna N, et al. Phase I-IIa study of BMS-690514, an EGFR, HER-2 and-4 and VEGFR-1 to-3 oral tyrosine kinase inhibitor, in patients with advanced or metastatic solid tumours. Eur J Cancer. May. 2013;49(8):1815-1824. EXC2. [pmid: 23490650].
1426 Souder C, Leitzel K, Ali SM, et al. Serum epidermal growth factor receptor/HER-2 predicts poor survival in patients with metastatic breast cancer. Cancer. 2006;107(10):2337-2345. EXC4. [pmid: 17048231].
1427 Souglakos J, Philips J, Wang R, et al. Prognostic and predictive value of common mutations for treatment response and survival in patients with metastatic colorectal cancer. Br J Cancer. Aug. 4. 2009;101(3):465-472. EXC3. [pmid: 19603024].
1428 Soulie P, Fourme E, Hamelin R, et al. TP53 status and gene amplification in human colorectal carcinomas. Cancer Genet Cytogenet. Dec. 1999;115(2):118-122. EXC4. [pmid: 10598144].
1429 Soung YH, Lee JW, Kim SY, et al. Somatic mutations of the ERBB4 kinase domain in human cancers. Int J Cancer. 2006;118(6):1426-1429. EXC6. [pmid: 16187281].
1430 South CD, Yearsley M, Martin E, et al. Immunohistochemistry staining for the mismatch repair proteins in the clinical care of patients with colorectal cancer. Genet Med. Nov. 2009;11(11):812-817. EXC4. [pmid: 19752738].
1431 Southey MC, Jenkins MA, Mead L, et al. Use of molecular tumor characteristics to prioritize mismatch repair gene testing in early-onset colorectal cancer. J Clin Oncol. Sep. 20. 2005;23(27):6524-6532. EXC4. [pmid: 16116158].
1432 10-year update of E2197: Phase III doxorubicin/docetaxel (AT) versus doxorubicin/cyclophosphamide (AC) adjuvant treatment of LN+ and high-risk LN- breast cancer and the comparison of the prognostic utility of the 21-gene recurrence score (RS) with clinicopathologic features. ASCO. 2010. EXC7.
1433 Spathis A, Georgoulakis J, Foukas P, et al. KRAS and BRAF mutation analysis from liquid-based cytology brushings of colorectal carcinoma in comparison with formalin-fixed, paraffin-embedded tissue. Anticancer Res. Jun. 2010;30(6):1969-1975. EXC4. [pmid: 20651341].
1434 Spigel DR, Burris HA 3rd, Greco FA, et al. Randomized, double-blind, placebo-controlled, phase II trial of sorafenib and erlotinib or erlotinib alone in previously treated advanced non-small-cell lung cancer. J Clin Oncol. Jun. 20. 2011;29(18):2582-2589. EXC3. [pmid: 21576636].
1435 Spindler KL, Pallisgaard N, Lindebjerg J, et al. EGFR related mutational status and association to clinical outcome of third-line cetuximab-irinotecan in metastatic colorectal cancer. BMC Cancer. 2011;11:107. EXC3. [pmid: 21439039].
1436 Spindler KL, Pallisgaard N, Vogelius I, et al. Quantitative cell-free DNA, KRAS, and BRAF mutations in plasma from patients with metastatic colorectal cancer during treatment with cetuximab and irinotecan. Clin Cancer Res. Feb. 15. 2012;18(4):1177-1185. EXC4. [pmid: 22228631].
1437 Srivastava A, Redston M, Farraye FA, et al. Hyperplastic/serrated polyposis in inflammatory bowel disease: a case series of a previously undescribed entity. Am J Surg Pathol. Feb. 2008;32(2):296-303. EXC3. [pmid: 18223333].
1438 Stabile LP, Rothstein ME, Keohavong P, et al. Targeting of both the c-Met and EGFR pathways results in additive inhibition of lung tumorigenesis in transgenic mice. Cancers. 2010;2(4):2153-2170. EXC4. [pmid: 21390244].
1439 Steiner H, Bergmeister M, Verdorfer I, et al. Early results of bladder-cancer screening in a high-risk population of heavy smokers. BJU Int. Aug. 2008;102(3):291-296. EXC3. [pmid: 18336612].
1440 Stella GM, Scabini R, Inghilleri S, et al. EGFR and KRAS mutational profiling in fresh non-small cell lung cancer (NSCLC) cells. J Cancer Res Clin Oncol. Aug. 2013;139(8):1327-1335. EXC6. [pmid: 23644698].
1441 Stigliano V, Assisi D, Cosimelli M, et al. Survival of hereditary non-polyposis colorectal cancer patients compared with sporadic colorectal cancer patients. J Exp Clin Cancer Res. 2008;27:39. EXC4. [pmid: 18803843].
1442 Stintzing S, Fischer von Weikersthal L, Decker T, et al. FOLFIRI plus cetuximab versus FOLFIRI plus bevacizumab as first-line treatment for patients with metastatic colorectal cancer-subgroup analysis of patients with KRAS: mutated tumours in the randomised German AIO study KRK-0306. Ann Oncol. Jul. 2012;23(7):1693-1699. EXC4. [pmid: 22219013].
1443 Stone JG, Robertson D, Houlston RS. Immunohistochemistry for MSH2 and MHL1: a method for identifying mismatch repair deficient colorectal cancer. J Clin Pathol. Jun. 2001;54(6):484-487. EXC4. [pmid: 11376026].
1444 Storojeva I, Boulay JL, Heinimann K, et al. Prognostic and predictive relevance of microsatellite instability in colorectal cancer. Oncol Rep. Jul. 2005;14(1):241-249. EXC4. [pmid: 15944796].
1445 Straver ME, Glas AM, Hannemann J, et al. The 70-gene signature as a response predictor for neoadjuvant chemotherapy in breast cancer. Breast Cancer Res Treat. Feb. 2010;119(3):551-558. EXC6. [pmid: 19214742].
1446 Strul H, Liberman E, Kariv R, et al. Prospective assessment of microsatellite instability in gastrointestinal neoplasia in Ashkenazi and non-Ashkenazi Jews. J Med. 2003;34(1-6):139-148. EXC3. [pmid: 17682319].
1447 Comparison of Oncotype DX Recurrence Scores between surgical and core biopsy specimens in breast cancer patients. SABCS. 2011. EXC5.
1448 Suehara Y, Arcila M, Wang L, et al. Identification of KIF5B-RET and GOPC-ROS1 fusions in lung adenocarcinomas through a comprehensive mRNA-based screen for tyrosine kinase fusions. Clin Cancer Res. Dec. 15. 2012;18(24):6599-6608. EXC4. [pmid: 23052255].
1449 Suehiro Y, Wong CW, Chirieac LR, et al. Epigenetic-genetic interactions in the APC/WNT, RAS/RAF, and P53 pathways in colorectal carcinoma. Clin Cancer Res. May. 1. 2008;14(9):2560-2569. EXC6. [pmid: 18451217].
1450 Suehisa H, Toyooka S, Hotta K, et al. Epidermal growth factor receptor mutation status and adjuvant chemotherapy with uracil-tegafur for adenocarcinoma of the lung. J Clin Oncol. Sep. 1. 2007;25(25):3952-3957. EXC6. [pmid: 17761979].
1451 Suenaga M, Matsusaka S, Ueno M, et al. Predictors of the efficacy of FOLFIRI plus bevacizumab as second-line treatment in metastatic colorectal cancer patients. Surg Today. Aug. 2011;41(8):1067-1074. EXC4. [pmid: 21773895].
1452 Sueoka-Aragane N, Imai K, Komiya K, et al. Exon 19 of EGFR mutation in relation to the CA-repeat polymorphism in intron 1. Cancer Sci. Jun. 2008;99(6):1180-1187. EXC6. [pmid: 18422739].
1453 Sugai T, Habano W, Jiao YF, et al. Analysis of allelic imbalances at multiple cancer-related chromosomal loci and microsatellite instability within the same tumor using a single tumor gland from colorectal carcinomas. Int J Cancer. Apr. 10. 2005;114(3):337-345. EXC4. [pmid: 15578702].
1454 Sugai T, Habano W, Nakamura S, et al. Analysis of Ki-ras gene mutations associated with DNA diploid, aneuploid, and multiploid colorectal carcinomas using a crypt isolation technique. Cytometry. Dec. 15. 2001;46(6):345-350. EXC4. [pmid: 11754204].
1455 Sugai T, Habano W, Nakamura S, et al. Genetic alterations in DNA diploid, aneuploid and multiploid colorectal carcinomas identified by the crypt isolation technique. Int J Cancer. Nov. 15. 2000;88(4):614-619. EXC4. [pmid: 11058879].
1456 Sugai T, Habano W, Uesugi N, et al. Molecular validation of the modified Vienna classification of colorectal tumors. J Mol Diagn. Nov. 2002;4(4):191-200. EXC4. [pmid: 12411586].
1457 Sugai T, Takahashi H, Habano W, et al. Analysis of genetic alterations, classified according to their DNA ploidy pattern, in the progression of colorectal adenomas and early colorectal carcinomas. J Pathol. Jun. 2003;200(2):168-176. EXC4. [pmid: 12754737].
1458 Sugano M, Nagasaka T, Sasaki E, et al. HNF4alpha as a marker for invasive mucinous adenocarcinoma of the lung. Am J Surg Pathol. Feb. 2013;37(2):211-218. EXC4. [pmid: 23108025].
1459 Sugimoto T, Ohta M, Ikenoue T, et al. Macroscopic morphologic subtypes of laterally spreading colorectal tumors showing distinct molecular alterations. Int J Cancer. Oct. 1. 2010;127(7):1562-1569. EXC4. [pmid: 20091866].
1460 Sugio K, Uramoto H, Onitsuka T, et al. Prospective phase II study of gefitinib in non-small cell lung cancer with epidermal growth factor receptor gene mutations. Lung Cancer. Jun. 2009;64(3):314-318. EXC6. [pmid: 18992959].
1461 Sun JM, Rampal S, Lee G, et al. Real world impact of epidermal growth factor receptor mutation status on treatment patterns in patients with non-small cell lung cancer. Lung Cancer. May. 2013;80(2):191-196. EXC6. [pmid: 23384673].
1462 Sun JM, Won YW, Kim ST, et al. The different efficacy of gefitinib or erlotinib according to epidermal growth factor receptor exon 19 and exon 21 mutations in Korean non-small cell lung cancer patients. J Cancer Res Clin Oncol. Apr. 2011;137(4):687-694. EXC3. [pmid: 20552223].
1463 Sun PL, Seol H, Lee HJ, et al. High incidence of EGFR mutations in Korean men smokers with no intratumoral heterogeneity of lung adenocarcinomas: correlation with histologic subtypes, EGFR/TTF-1 expressions, and clinical features. J Thorac Oncol. Feb. 2012;7(2):323-330. EXC6. [pmid: 22237264].
1464 Sun Y, Goodison S, Li J, et al. Improved breast cancer prognosis through the combination of clinical and genetic markers. Bioinformatics. 2007;23(1):30-37. EXC7. [pmid: 17130137].
1465 Sunde L, Bisgaard ML, Soll-Johanning H, et al. Familial colorectal cancer, can it be identified by microsatellite instability and chromosomal instability? - A case-control study. Cancer Biomark. 2009;5(4):197-205. EXC3. [pmid: 19729829].
1466 Sung MT, Zhang S, Lopez-Beltran A, et al. Urothelial carcinoma following augmentation cystoplasty: an aggressive variant with distinct clinicopathological characteristics and molecular genetic alterations. Histopathology. Aug. 2009;55(2):161-173. EXC3. [pmid: 19694823].
1467 Suspitsin EN, Levchenko EV, Moiseyenko FV, et al. Rapid symptomatic improvement in gefitinib-treated patients with EGFR-mutated lung cancer: possible role of downregulation of inflammatory molecules?. Onkologie. 2011;34(10):559-560. EXC7. [pmid: 21985857].
1468 Sutter C, Dallenbach-Hellweg G, Schmidt D, et al. Molecular analysis of endometrial hyperplasia in HNPCC-suspicious patients may predict progression to endometrial carcinoma. Int J Gynecol Pathol. Jan. 2004;23(1):18-25. EXC4. [pmid: 14668545].
1469 Suwinski R, Klusek A, Tyszkiewicz T, et al. Gene expression from bronchoscopy obtained tumour samples as a predictor of outcome in advanced inoperable lung cancer. PLoS One. 2012;7(7). EXC4.
1470 Suzuki M, Shigematsu H, Hiroshima K, et al. Epidermal growth factor receptor expression status in lung cancer correlates with its mutation. Hum Pathol. Oct. 2005;36(10):1127-1134. EXC6. [pmid: 16226114].
1471 Suzuki M, Shigematsu H, Iizasa T, et al. Exclusive mutation in epidermal growth factor receptor gene, HER-2, and KRAS, and synchronous methylation of nonsmall cell lung cancer. Cancer. May. 15. 2006;106(10):2200-2207. EXC6. [pmid: 16598760].
1472 Suzuki M, Shigematsu H, Nakajima T, et al. Synchronous alterations of Wnt and epidermal growth factor receptor signaling pathways through aberrant methylation and mutation in non small cell lung cancer. Clin Cancer Res. Oct. 15. 2007;13(20):6087-6092. EXC7. [pmid: 17947472].
1473 Suzuki S, Dobashi Y, Sakurai H, et al. Protein overexpression and gene amplification of epidermal growth factor receptor in nonsmall cell lung carcinomas. An immunohistochemical and fluorescence in situ hybridization study. Cancer. Mar. 15. 2005;103(6):1265-1273. EXC5. [pmid: 15712203].
1474 Svatek RS, Sagalowsky AI, Lotan Y. Economic impact of screening for bladder cancer using bladder tumor markers: a decision analysis. Urol Oncol. Jul-Aug. 2006;24(4):338-343. EXC2. [pmid: 16818188].
1475 Svrcek M, El-Bchiri J, Chalastanis A, et al. Specific clinical and biological features characterize inflammatory bowel disease associated colorectal cancers showing microsatellite instability. J Clin Oncol. Sep. 20. 2007;25(27):4231-4238. EXC3. [pmid: 17878476].
1476 Sweeney C, Boucher KM, Samowitz WS, et al. Oncogenetic tree model of somatic mutations and DNA methylation in colon tumors. Genes Chromosomes Cancer. Jan. 2009;48(1):1-9. EXC4. [pmid: 18767147].
1477 Swinson DE, Cox G, O'Byrne KJ. Coexpression of epidermal growth factor receptor with related factors is associated with a poor prognosis in non-small-cell lung cancer. Br J Cancer. Oct. 4. 2004;91(7):1301-1307. EXC4. [pmid: 15365565].
1478 Sylvester BE, Huo D, Khramtsov A, et al. Molecular analysis of colorectal tumors within a diverse patient cohort at a single institution. Clin Cancer Res. Jan. 15. 2012;18(2):350-359. EXC6. [pmid: 22114137].
1479 Evaluation of variables that may impact the use of Oncotype DX testing. ASCO. 2012. EXC6.
1480 Taga M, Mechanic LE, Hagiwara N, et al. EGFR somatic mutations in lung tumors: Radon exposure and passive smoking in former- and never-smoking U.S. women. Cancer Epidemiology Biomarkers and Prevention. 2012;21(6):988-992. EXC5.
1481 Tahara T, Inoue N, Hisamatsu T, et al. Clinical significance of microsatellite instability in the inflamed mucosa for the prediction of colonic neoplasms in patients with ulcerative colitis. J Gastroenterol Hepatol. May. 2005;20(5):710-715. EXC4. [pmid: 15853983].
1482 Taillade L, Penault-Llorca F, Boulet T, et al. Immunohistochemichal expression of biomarkers: a comparative study between diagnostic bronchial biopsies and surgical specimens of non-small-cell lung cancer. Ann Oncol. Jun. 2007;18(6):1043-1050. EXC4. [pmid: 17355950].
1483 Takagi S, Kinouchi Y, Hiwatashi N, et al. Relationship between microsatellite instability and telomere shortening in colorectal cancer. Dis Colon Rectum. Oct. 2000;43(10 Suppl):S12-S17. EXC5. [pmid: 11052472].
1484 Takahashi T, Nosho K, Yamamoto H, et al. Flat-type colorectal advanced adenomas (laterally spreading tumors) have different genetic and epigenetic alterations from protruded-type advanced adenomas. Mod Pathol. Jan. 2007;20(1):139-147. EXC3. [pmid: 17143260].
1485 Takamochi K, Oh S, Matsuoka J, et al. Clonality status of multifocal lung adenocarcinomas based on the mutation patterns of EGFR and K-ras. Lung Cancer. Mar. 2012;75(3):313-320. EXC6. [pmid: 22209037].
1486 Takano K, Ichikawa Y, Ueno E, et al. Microsatellite instability and expression of mismatch repair genes in sporadic endometrial cancer coexisting with colorectal or breast cancer. Oncol Rep. Jan. 2005;13(1):11-16. EXC4. [pmid: 15583795].
1487 Takano T, Fukui T, Ohe Y, et al. EGFR mutations predict survival benefit from gefitinib in patients with advanced lung adenocarcinoma: a historical comparison of patients treated before and after gefitinib approval in Japan. J Clin Oncol. Dec. 1. 2008;26(34):5589-5595. EXC3. [pmid: 18794545].
1488 Takano T, Ohe Y, Sakamoto H, et al. Epidermal growth factor receptor gene mutations and increased copy numbers predict gefitinib sensitivity in patients with recurrent non-small-cell lung cancer. J Clin Oncol. Oct. 1. 2005;23(28):6829-6837. EXC3. [pmid: 15998907].
1489 Takano T, Ohe Y, Tsuta K, et al. Epidermal growth factor receptor mutation detection using high-resolution melting analysis predicts outcomes in patients with advanced non small cell lung cancer treated with gefitinib. Clin Cancer Res. Sep. 15. 2007;13(18 Pt 1):5385-5390. EXC3. [pmid: 17875767].
1490 Takeda K, Kinoshita I, Shimizu Y, et al. Expression of LGR5, an intestinal stem cell marker, during each stage of colorectal tumorigenesis. Anticancer Res. Jan. 2011;31(1):263-270. EXC4. [pmid: 21273608].
1491 Takeda M, Okamoto I, Sakai K, et al. Successful long-term treatment with pemetrexed of NSCLC associated with EML4-ALK and low thymidylate synthase expression. Clinical lung cancer. 2012;13(2):157-159. EXC7. [pmid: 22056890].
1492 Takemoto N, Konishi F, Yamashita K, et al. The correlation of microsatellite instability and tumor-infiltrating lymphocytes in hereditary non-polyposis colorectal cancer (HNPCC) and sporadic colorectal cancers: the significance of different types of lymphocyte infiltration. Jpn J Clin Oncol. Feb. 2004;34(2):90-98. EXC4. [pmid: 15067103].
1493 Tam IY, Chung LP, Suen WS, et al. Distinct epidermal growth factor receptor and KRAS mutation patterns in non-small cell lung cancer patients with different tobacco exposure and clinicopathologic features. Clin Cancer Res. Mar. 1. 2006;12(5):1647-1653. EXC6. [pmid: 16533793].
1494 Tam IY, Leung EL, Tin VP, et al. Double EGFR mutants containing rare EGFR mutant types show reduced in vitro response to gefitinib compared with common activating missense mutations. Mol Cancer Ther. Aug. 2009;8(8):2142-2151. EXC6. [pmid: 19671738].
1495 Tanaka H, Deng G, Matsuzaki K, et al. BRAF mutation, CpG island methylator phenotype and microsatellite instability occur more frequently and concordantly in mucinous than non-mucinous colorectal cancer. Int J Cancer. Jun. 1. 2006;118(11):2765-2771. EXC4. [pmid: 16381005].
1496 Tanaka M, Chang P, Li Y, et al. Association of CHFR promoter methylation with disease recurrence in locally advanced colon cancer. Clin Cancer Res. Jul. 1. 2011;17(13):4531-4540. EXC4. [pmid: 21551253].
1497 Tanaka N, Huttenhower C, Nosho K, et al. Novel application of structural equation modeling to correlation structure analysis of CpG island methylation in colorectal cancer. Am J Pathol. Dec. 2010;177(6):2731-2740. EXC4. [pmid: 21037082].
1498 Tanaka T, Watanabe T, Kitayama J, et al. Chromosome 18q deletion as a novel molecular predictor for colorectal cancer with simultaneous hepatic metastasis. Diagn Mol Pathol. Dec. 2009;18(4):219-225. EXC4. [pmid: 19861895].
1499 Tang R, Wang JY, Fan CW, et al. p53 is an independent pre-treatment markers for long-term survival in stage II and III colorectal cancers: an analysis of interaction between genetic markers and fluorouracil-based adjuvant therapy. Cancer Lett. Jul. 8. 2004;210(1):101-109. EXC6. [pmid: 15172127].
1500 Tang X, Varella-Garcia M, Xavier AC, et al. Epidermal growth factor receptor abnormalities in the pathogenesis and progression of lung adenocarcinomas. Cancer Prev Res (Phila). Aug. 2008;1(3):192-200. EXC6. [pmid: 19138956].
1501 Taniguchi K, Uchida J, Nishino K, et al. Quantitative detection of EGFR mutations in circulating tumor DNA derived from lung adenocarcinomas. Clin Cancer Res. Dec. 15. 2011;17(24):7808-7815. EXC4. [pmid: 21976538].
1502 Tapia C, Glatz K, Obermann EC, et al. Evaluation of chromosomal aberrations in patients with benign conditions and reactive changes in urinary cytology. Cancer Cytopathol. Dec. 25. 2011;119(6):404-410. EXC5. [pmid: 21732550].
1503 Taron M, Ichinose Y, Rosell R, et al. Activating mutations in the tyrosine kinase domain of the epidermal growth factor receptor are associated with improved survival in gefitinib-treated chemorefractory lung adenocarcinomas. Clin Cancer Res. Aug. 15. 2005;11(16):5878-5885. EXC3. [pmid: 16115929].
1504 Tejpar S, Celik I, Schlichting M, et al. Association of KRAS G13D tumor mutations with outcome in patients with metastatic colorectal cancer treated with first-line chemotherapy with or without cetuximab. J Clin Oncol. Oct. 10. 2012;30(29):3570-3577. EXC6. [pmid: 22734028].
1505 Teng HW, Huang YC, Lin JK, et al. BRAF mutation is a prognostic biomarker for colorectal liver metastasectomy. J Surg Oncol. Aug. 1. 2012;106(2):123-129. EXC3. [pmid: 22331825].
1506 Terdiman JP, Levin TR, Allen BA, et al. Hereditary nonpolyposis colorectal cancer in young colorectal cancer patients: high-risk clinic versus population-based registry. Gastroenterology. Apr. 2002;122(4):940-947. EXC4. [pmid: 11910346].
1507 Tessem MB, Selnaes KM, Sjursen W, et al. Discrimination of patients with microsatellite instability colon cancer using 1H HR MAS MR spectroscopy and chemometric analysis. J Proteome Res. Jul. 2. 2010;9(7):3664-3670. EXC4. [pmid: 20507057].
1508 Thomassen M, Tan Q, Eiriksdottir F, et al. Prediction of metastasis from low-malignant breast cancer by gene expression profiling. Int J Cancer. Mar. 1. 2007;120(5):1070-1075. EXC5. [pmid: 17131339].
1509 Tian S, Roepman P, Popovici V, et al. A robust genomic signature for the detection of colorectal cancer patients with microsatellite instability phenotype and high mutation frequency. J Pathol. December. 2012;228(4):586-595. FULL TEXT LINK http://dx.doi.org/10.1002/path.4092. EXC4. [pmid: 22926706].
1510 Tikidzhieva A, Benner A, Michel S, et al. Microsatellite instability and Beta2-Microglobulin mutations as prognostic markers in colon cancer: results of the FOGT-4 trial. Br J Cancer. Mar. 13. 2012;106(6):1239-1245. EXC4. [pmid: 22353804].
1511 Timmermann B, Kerick M, Roehr C, et al. Somatic mutation profiles of MSI and MSS colorectal cancer identified by whole exome next generation sequencing and bioinformatics analysis. PLoS One. 2010;5(12):e15661. EXC4. [pmid: 21203531].
1512 Tiseo M, Capelletti M, De Palma G, et al. Epidermal growth factor receptor intron-1 polymorphism predicts gefitinib outcome in advanced non-small cell lung cancer. J Thorac Oncol. Oct. 2008;3(10):1104-1111. EXC3. [pmid: 18827605].
1513 Tiseo M, Rossi G, Capelletti M, et al. Predictors of gefitinib outcomes in advanced non-small cell lung cancer (NSCLC): study of a comprehensive panel of molecular markers. Lung Cancer. Mar. 2010;67(3):355-360. EXC3. [pmid: 19473722].
1514 Togashi Y, Masago K, Kubo T, et al. Association between vascular-poor area of primary tumors and epidermal growth factor receptor gene status in advanced lung adenocarcinoma. Med Oncol. Dec. 2012;29(5):3169-3175. EXC6. [pmid: 22492281].
1515 Togashi Y, Masago K, Kubo T, et al. Association of diffuse, random pulmonary metastases, including miliary metastases, with epidermal growth factor receptor mutations in lung adenocarcinoma. Cancer. 2011;117(4):819-825. EXC3. [pmid: 20886633].
1516 Togo G, Okamoto M, Shiratori Y, et al. Does mutation of transforming growth factor-beta type II receptor gene play an important role in colorectal polyps?. Dig Dis Sci. Sep. 1999;44(9):1803-1809. EXC3. [pmid: 10505718].
1517 The first report of the association between the recurrence score and the risk of recurrence in a Japanese population (JBCRG-TR 003). Kyoto Breast Cancer Consensus Conference. 2009. EXC9.
1518 Toi M, Iwata H, Yamanaka T, et al. Clinical significance of the 21-gene signature (Oncotype DX) in hormone receptor-positive early stage primary breast cancer in the Japanese population. Cancer. Jul. 1. 2010;116(13):3112-3118. EXC7. [pmid: 20564629].
1519 Tokumo M, Toyooka S, Kiura K, et al. The relationship between epidermal growth factor receptor mutations and clinicopathologic features in non-small cell lung cancers. Clin Cancer Res. Feb. 1. 2005;11(3):1167-1173. EXC6. [pmid: 15709185].
1520 Tol J, Dijkstra JR, Klomp M, et al. Markers for EGFR pathway activation as predictor of outcome in metastatic colorectal cancer patients treated with or without cetuximab. Eur J Cancer. Jul. 2010;46(11):1997-2009. EXC6. [pmid: 20413299].
1521 Tol J, Koopman M, Cats A, et al. Chemotherapy, bevacizumab, and cetuximab in metastatic colorectal cancer. N Engl J Med. Feb. 5. 2009;360(6):563-572. EXC6. [pmid: 19196673].
1522 Tommasi S, Pinto R, Petriella D, et al. Oncosuppressor methylation: a possible key role in colon metastatic progression. J Cell Physiol. Jul. 2011;226(7):1934-1939. EXC4. [pmid: 21506124].
1523 Tougeron D, Fauquembergue E, Rouquette A, et al. Tumor-infiltrating lymphocytes in colorectal cancers with microsatellite instability are correlated with the number and spectrum of frameshift mutations. Mod Pathol. Sep. 2009;22(9):1186-1195. EXC4. [pmid: 19503063].
1524 Toyooka S, Matsuo K, Shigematsu H, et al. The impact of sex and smoking status on the mutational spectrum of epidermal growth factor receptor gene in non small cell lung cancer. Clin Cancer Res. Oct. 1. 2007;13(19):5763-5768. EXC6. [pmid: 17908966].
1525 Toyooka S, Takano T, Kosaka T, et al. Epidermal growth factor receptor mutation, but not sex and smoking, is independently associated with favorable prognosis of gefitinib-treated patients with lung adenocarcinoma. Cancer Science. 2008;99(2):303-308. EXC3. [pmid: 18271929].
1526 Toyooka S, Tokumo M, Shigematsu H, et al. Mutational and epigenetic evidence for independent pathways for lung adenocarcinomas arising in smokers and never smokers. Cancer Res. 2006;66(3):1371-1375. EXC5. [pmid: 16452191].
1527 Tran B, Kopetz S, Tie J, et al. Impact of BRAF mutation and microsatellite instability on the pattern of metastatic spread and prognosis in metastatic colorectal cancer. Cancer. 2011;117(20):4623-4632. EXC3. [pmid: 21456008].
1528 Trano G, Sjursen W, Wasmuth HH, et al. Performance of clinical guidelines compared with molecular tumour screening methods in identifying possible Lynch syndrome among colorectal cancer patients: a Norwegian population-based study. Br J Cancer. Feb. 2. 2010;102(3):482-488. EXC7. [pmid: 20051945].
1529 Trautmann K, Terdiman JP, French AJ, et al. Chromosomal instability in microsatellite-unstable and stable colon cancer. Clin Cancer Res. Nov. 1. 2006;12(21):6379-6385. EXC6. [pmid: 17085649].
1530 Tresallet C, Brouquet A, Julie C, et al. Evaluation of predictive models in daily practice for the identification of patients with Lynch syndrome. Int J Cancer. Mar. 15. 2012;130(6):1367-1377. EXC7. [pmid: 21520036].
1531 Trevisiol C, Di Fabio F, Nascimbeni R, et al. Prognostic value of circulating KRAS2 gene mutations in colorectal cancer with distant metastases. Int J Biol Markers. Oct-Dec. 2006;21(4):223-228. EXC4. [pmid: 17177160].
1532 Trojan J, Raedle J, Herrmann G, et al. Detection of microsatellite instability from archival, hematoxylin-eosin-stained colorectal cancer specimen. Arch Pathol Lab Med. Feb. 2002;126(2):202-204. EXC2. [pmid: 11825119].
1533 Truninger K, Menigatti M, Luz J, et al. Immunohistochemical analysis reveals high frequency of PMS2 defects in colorectal cancer. Gastroenterology. May. 2005;128(5):1160-1171. EXC6. [pmid: 15887099].
1534 Truta B, Chen YY, Blanco AM, et al. Tumor histology helps to identify Lynch syndrome among colorectal cancer patients. Fam Cancer. 2008;7(3):267-274. EXC4. [pmid: 18283560].
1535 Tsai JR, Wang HM, Liu PL, et al. High expression of heme oxygenase-1 is associated with tumor invasiveness and poor clinical outcome in non-small cell lung cancer patients. Cell Oncol (Dordr). Dec. 2012;35(6):461-471. EXC6. [pmid: 23055342].
1536 Tsai TH, Su KY, Wu SG, et al. RNA is favourable for analysing EGFR mutations in malignant pleural effusion of lung cancer. Eur Respir J. Mar. 2012;39(3):677-684. EXC6. [pmid: 21719485].
1537 Tsai TH, Wu SG, Chang YL, et al. Effusion immunocytochemistry as an alternative approach for the selection of first-line targeted therapy in advanced lung adenocarcinoma. J Thorac Oncol. Jun. 2012;7(6):993-1000. EXC4. [pmid: 22525557].
1538 Tsakiridis T, Cutz JC, Singh G, et al. Association of phosphorylated epidermal growth factor receptor with survival in patients with locally advanced non-small cell lung cancer treated with radiotherapy. J Thorac Oncol. Jul. 2008;3(7):716-722. EXC4. [pmid: 18594316].
1539 Tsao AS, Tang XM, Sabloff B, et al. Clinicopathologic characteristics of the EGFR gene mutation in non-small cell lung cancer. J Thorac Oncol. Mar. 2006;1(3):231-239. EXC6. [pmid: 17409862].
1540 Tsiatis AC, Norris-Kirby A, Rich RG, et al. Comparison of Sanger sequencing, pyrosequencing, and melting curve analysis for the detection of KRAS mutations: Diagnostic and clinical implications. J Molec Diagnost. 2010;12(4):425-432. EXC5.
1541 Tsoi DT, Inoue M, Kelly CM, et al. Cost-effectiveness analysis of recurrence score-guided treatment using a 21-gene assay in early breast cancer. Oncologist. 2010;15(5):457-465. EXC6. [pmid: 20421264].
1542 Tsunematsu Y, Yoshizawa Y, Miyauchi J, et al. A novel case of Wilms' tumor followed by colon cancer, both showing microsatellite instability. Oncology. Feb. 2000;58(2):159-160. EXC2. [pmid: 10705243].
1543 Tug E, Balaban YH, Sahin EK. Mapping of microsatellite instability in endoscopic normal colon. Genet Test Mol Biomarkers. May. 2012;16(5):388-395. EXC6. [pmid: 22224632].
1544 Tuononen K, Maki-Nevala S, Sarhadi VK, et al. Comparison of targeted next-generation sequencing (NGS) and real-time PCR in the detection of EGFR, KRAS, and BRAF mutations on formalin-fixed, paraffin-embedded tumor material of non-small cell lung carcinoma-superiority of NGS. Genes Chromosomes Cancer. May. 2013;52(5):503-511. EXC6. [pmid: 23362162].
1545 Tuononen K, Sarhadi VK, Wirtanen A, et al. Targeted resequencing reveals ALK fusions in non-small cell lung carcinomas detected by FISH, immunohistochemistry, and real-time RT-PCR: a comparison of four methods. Biomed Res Int. 2013;2013:757490. EXC4. [pmid: 23484153].
1546 Tveit KM, Guren T, Glimelius B, et al. Phase III trial of cetuximab with continuous or intermittent fluorouracil, leucovorin, and oxaliplatin (Nordic FLOX) versus FLOX alone in first-line treatment of metastatic colorectal cancer: the NORDIC-VII study. J Clin Oncol. May. 20. 2012;30(15):1755-1762. EXC7. [pmid: 22473155].
1547 Ueda E, Watanabe T, Ishigami H, et al. Microsatellite instability of colorectal cancer and adenoma in synchronous multiple colorectal cancer patients with associated extracolonic malignancies. Surg Today. 2001;31(5):405-409. EXC4. [pmid: 11381503].
1548 Ueda E, Watanabe T, Umetani N, et al. Microsatellite instability of cancers and concomitant adenomas in synchronous multiple colorectal cancer patients. J Exp Clin Cancer Res. Jun. 2002;21(2):149-154. EXC4. [pmid: 12148569].
1549 Ueno T, Toyooka S, Suda K, et al. Impact of age on epidermal growth factor receptor mutation in lung cancer. Lung Cancer. Dec. 2012;78(3):207-211. EXC6. [pmid: 23036155].
1550 Ulivi P, Capelli L, Valgiusti M, et al. Predictive role of multiple gene alterations in response to cetuximab in metastatic colorectal cancer: A single center study. Journal of Translational Medicine. 2012;10(1). EXC3.
1551 Ulivi P, Romagnoli M, Chiadini E, et al. Assessment of EGFR and K-ras mutations in fixed and fresh specimens from transesophageal ultrasound-guided fine needle aspiration in non-small cell lung cancer patients. Int J Oncol. Jul. 2012;41(1):147-152. EXC7. [pmid: 22504767].
1552 Ulrich CM, Curtin K, Samowitz W, et al. MTHFR variants reduce the risk of G:C->A:T transition mutations within the p53 tumor suppressor gene in colon tumors. J Nutr. Oct. 2005;135(10):2462-2467. EXC6. [pmid: 16177213].
1553 Umeda Y, Nagasaka T, Mori Y, et al. Poor prognosis of KRAS or BRAF mutant colorectal liver metastasis without microsatellite instability. J Hepatobiliary Pancreat Sci. Feb. 2013;20(2):223-233. EXC3. [pmid: 23010994].
1554 Umemura S, Tsubouchi K, Yoshioka H, et al. Clinical outcome in patients with leptomeningeal metastasis from non-small cell lung cancer: Okayama Lung Cancer Study Group. Lung Cancer. Jul. 2012;77(1):134-139. EXC7. [pmid: 22487432].
1555 Uramoto H, Iwata T, Onitsuka T, et al. Epithelial-mesenchymal transition in EGFR-TKI acquired resistant lung adenocarcinoma. Anticancer Res. Jul. 2010;30(7):2513-2517. EXC6. [pmid: 20682976].
1556 Uramoto H, So T, Nagata Y, et al. Correlation between HLA alleles and EGFR mutation in Japanese patients with adenocarcinoma of the lung. J Thorac Oncol. Aug. 2010;5(8):1136-1142. EXC6. [pmid: 20548248].
1557 Uramoto H, Yamada S, Tanaka F. Angiogenesis of lung cancer utilizes existing blood vessels rather than developing new vessels using signals from carcinogenesis. Anticancer Res. May. 2013;33(5):1913-1916. EXC6. [pmid: 23645738].
1558 Uramoto H, Yamada T, Yano S, et al. Prognostic value of aquired resistance-related molecules in Japanese patients with NSCLC treated with an EGFR-TKI. Anticancer Res. 2012;32(9):3785-3790. EXC4. [pmid: 22993320].
1559 Uramoto H, Yamada T, Yano S, et al. Prognostic value of acquired resistance-related molecules in Japanese patients with NSCLC treated with an EGFR-TKI. Anticancer Res. Sep. 2012;32(9):3785-3790. EXC6. [pmid: 22993320].
1560 Vacirca J, Tsai MC, Brufsky AM, et al. Initial results from the 21-gene Breast Cancer Assay Registry: A prospective observational study in patients (pts) with ER+, early stage invasive breast cancer (EBC). EXC9.
1561 Vaguliene N, Zemaitis M, Sarauskas V, et al. The role of mutation status of the epidermal growth factor receptor gene in advanced non-small cell lung cancer. Medicina (Kaunas). 2012;48(4):175-181. EXC6. [pmid: 22836289].
1562 Valentini AM, Renna L, Armentano R, et al. Mismatch repair, p53 and (beta)-catenin proteins in colorectal cancer. Anticancer Res. 2002;22(4):2083-2088. EXC4. [pmid: 12174887].
1563 Valle L, Carbonell P, Fernandez V, et al. MLH1 germline epimutations in selected patients with early-onset non-polyposis colorectal cancer. Clin Genet. 2007;71(3):232-237. EXC6. [pmid: 17309645].
1564 Van Cutsem E, Kohne CH, Hitre E, et al. Cetuximab and chemotherapy as initial treatment for metastatic colorectal cancer. N Engl J Med. 2009;360(14):1408-1417. EXC6. [pmid: 19339720].
1565 Van Cutsem E, Kohne CH, Lang I, et al. Cetuximab plus irinotecan, fluorouracil, and leucovorin as first-line treatment for metastatic colorectal cancer: updated analysis of overall survival according to tumor KRAS and BRAF mutation status. J Clin Oncol. May. 20. 2011;29(15):2011-2019. EXC7. [pmid: 21502544].
1566 Van Cutsem E, Tejpar S, Vanbeckevoort D, et al. Intrapatient cetuximab dose escalation in metastatic colorectal cancer according to the grade of early skin reactions: the randomized EVEREST study. J Clin Oncol. Aug. 10. 2012;30(23):2861-2868. EXC7. [pmid: 22753904].
1567 van der Drift MA, Prinsen CF, Knuiman GJ, et al. Diagnosing peripheral lung cancer: the additional value of the Ras-association domain family 1A gene methylation and Kirsten rat sarcoma 2 viral oncogene homolog mutation analyses in washings in nondiagnostic bronchoscopy. Chest. Jan. 2012;141(1):169-175. EXC6. [pmid: 21700687].
1568 Van Rijnsoever M, Elsaleh H, Joseph D, et al. CpG island methylator phenotype is an independent predictor of survival benefit from 5-fluorouracil in stage III colorectal cancer. Clin Cancer Res. Aug. 1. 2003;9(8):2898-2903. EXC3. [pmid: 12912934].
1569 Vanderlaan BF, Broder MS, Chang EY, et al. Cost-effectiveness of 21-gene assay in node-positive, early-stage breast cancer (Structured abstract). Am J Manag Care. 2011;(7):455-464. EXC4. [pmid: 21819166].
1570 Varella-Garcia M, Akduman B, Sunpaweravong P, et al. The UroVysion fluorescence in situ hybridization assay is an effective tool for monitoring recurrence of bladder cancer. Urol Oncol. Jan-Feb. 2004;22(1):16-19. EXC6. [pmid: 14969798].
1571 Varella-Garcia M, Mitsudomi T, Yatabe Y, et al. EGFR and HER2 genomic gain in recurrent non-small cell lung cancer after surgery: impact on outcome to treatment with gefitinib and association with EGFR and KRAS mutations in a Japanese cohort. J Thorac Oncol. Mar. 2009;4(3):318-325. EXC3. [pmid: 19247083].
1572 Varghese AM, Sima CS, Chaft JE, et al. Lungs don't forget: Comparison of the KRAS and EGFR mutation profile and survival of collegiate smokers and never smokers with advanced lung cancers. J Thorac Oncol. Jan. 2013;8(1):123-125. EXC6. [pmid: 23242442].
1573 Vasen HF, Hendriks Y, de Jong AE, et al. Identification of HNPCC by molecular analysis of colorectal and endometrial tumors. Dis Markers. 2004;20(4-5):207-213. EXC3. [pmid: 15528786].
1574 Vataire AL, Laas E, Aballea S, et al. [Cost-effectiveness of a chemotherapy predictive test]. Bull Cancer. Oct. 2012;99(10):907-914. EXC2. [pmid: 23041366].
1575 Veeramachaneni R, Nordberg ML, Shi R, et al. Evaluation of fluorescence in situ hybridization as an ancillary tool to urine cytology in diagnosing urothelial carcinoma. Diagn Cytopathol. Jun. 2003;28(6):301-307. EXC7. [pmid: 12768634].
1576 Viana Lde S, Affonso RJ Jr, Silva SR, et al. Relationship between the expression of the extracellular matrix genes SPARC, SPP1, FN1, ITGA5 and ITGAV and clinicopathological parameters of tumor progression and colorectal cancer dissemination. Oncology. 2013;84(2):81-91. EXC4. [pmid: 23128103].
1577 Vickers MM, Bar J, Gorn-Hondermann I, et al. Stage-dependent differential expression of microRNAs in colorectal cancer: potential role as markers of metastatic disease. Clin Exp Metastasis. Feb. 2012;29(2):123-132. EXC4. [pmid: 22120473].
1578 Vidaurreta M, Maestro ML, Rafael S, et al. Telomerase activity in colorectal cancer, prognostic factor and implications in the microsatellite instability pathway. World J Gastroenterol. Jul. 28. 2007;13(28):3868-3872. EXC6. [pmid: 17657844].
1579 Villaruz LC, Socinski MA, Cunningham DE, et al. The prognostic and predictive value of KRAS oncogene substitutions in lung adenocarcinoma. Cancer. Jun. 15. 2013;119(12):2268-2274. EXC6. [pmid: 23526491].
1580 Vincenten J, Smit EF, Vos W, et al. Negative NKX2-1 (TTF-1) as temporary surrogate marker for treatment selection during EGFR-mutation analysis in patients with non-small-cell lung cancer. J Thorac Oncol. 2012;7(10):1522-1527. EXC4. [pmid: 22982653].
1581 Vlajnic T, Andreozzi MC, Schneider S, et al. VEGFA gene locus (6pl2) amplification identifies a small but highly aggressive subgroup of colorectal cancer [corrected] patients. ModPathol. Oct. 2011;24(10):1404-1412. EXC4. [pmid: 21743435].
1582 Vlaykova T, Mitkova A, Stancheva G, et al. Microsatellite instability and promoter hypermethylation of MLH1 and MSH2 in patients with sporadic colorectal cancer. J BUON. Apr-Jun. 2011;16(2):265-273. EXC4. [pmid: 21766496].
1583 Vollebergh MA, Kappers I, Klomp HM, et al. Ligands of epidermal growth factor receptor and the insulin-like growth factor family as serum biomarkers for response to epidermal growth factor receptor inhibitors in patients with advanced non-small cell lung cancer. J Thorac Oncol. Dec. 2010;5(12):1939-1948. EXC4. [pmid: 21102259].
1584 Voortman J, Goto A, Mendiboure J, et al. MicroRNA expression and clinical outcomes in patients treated with adjuvant chemotherapy after complete resection of non-small cell lung carcinoma. Cancer Res. 2010;(21):8288-8298. EXC4. [pmid: 20978195].
1585 Voutsina A, Tzardi M, Kalikaki A, et al. Combined analysis of KRAS and PIK3CA mutations, MET and PTEN expression in primary tumors and corresponding metastases in colorectal cancer. Mod Pathol. Feb. 2013;26(2):302-313. EXC3. [pmid: 22936063].
1586 Wada M, Yamamoto M, Ryuge S, et al. Phase II study of S-l monotherapy in patients with previously treated, advanced non-small-cell lung cancer. Cancer Chemother Pharmacol. Apr. 2012;69(4):1005-1011. EXC3. [pmid: 22160350].
1587 Wagner A, Barrows A, Wijnen JT, et al. Molecular analysis of hereditary nonpolyposis colorectal cancer in the United States: high mutation detection rate among clinically selected families and characterization of an American founder genomic deletion of the MSH2 gene. Am J Hum Genet. May. 2003;72(5):1088-1100. EXC7. [pmid: 12658575].
1588 Wagner PL, Perner S, Rickman DS, et al. In situ evidence of KRAS amplification and association with increased p21 levels in non-small cell lung carcinoma. Am J Clin Pathol. Oct. 2009;132(4):500-505. EXC4. [pmid: 19762526].
1589 Wallander ML, Geiersbach KB, Tripp SR, et al. Comparison of reverse transcription-polymerase chain reaction, immunohistochemistry, and fluorescence in situ hybridization methodologies for detection of echinoderm microtubule-associated proteinlike 4-anaplastic lymphoma kinase fusion-positive non-small cell lung carcinoma: implications for optimal clinical testing. Arch Pathol Lab Med. Jul. 2012;136(7):796-803. EXC5. [pmid: 22742552].
1590 Wan YW, Raese RA, Fortney JE, et al. A smoking-associated 7-gene signature for lung cancer diagnosis and prognosis. Int J Oncol. 2012;41(4):1387-1396. EXC4. [pmid: 22825454].
1591 Wang C, van Rijnsoever M, Grieu F, et al. Prognostic significance of microsatellite instability and Ki-ras mutation type in stage II colorectal cancer. Oncology. 2003;64(3):259-265. EXC4. [pmid: 12697967].
1592 Wang F, Wang S, Wang Z, et al. Phosphorylated EGFR expression may predict outcome of EGFR-TKIs therapy for the advanced NSCLC patients with wild-type EGFR. J Exp Clin Cancer Res. 2012;31:65. EXC6. [pmid: 22901364].
1593 Wang J, Luo MH, Zhang ZX, et al. Clinical and molecular analysis of hereditary non-polyposis colorectal cancer in Chinese colorectal cancer patients. World Journal of Gastroenterology. 2007;13(10):1612-1617. EXC6. [pmid: 17461458].
1594 Wang S, An T, Wang J, et al. Potential clinical significance of a plasma-based KRAS mutation analysis in patients with advanced non-small cell lung cancer. Clin Cancer Res. Feb. 15. 2010;16(4):1324-1330. EXC3. [pmid: 20145159].
1595 Wang W, Wang GQ, Sun XW, et al. Prognostic values of chromosome 18q microsatellite alterations in stage II colonic carcinoma. World J Gastroenterol. Dec. 21. 2010;16(47):6026-6034. EXC4. [pmid: 21157981].
1596 Wang Y, Liu ZD, Zhao LM, et al. Individualized treatment of NSCLC: from research to clinical practice. Neoplasma. 2013;60(5):538-545. EXC6. [pmid: 23790173].
1597 Wang Z, Zhang X, Bai H, et al. EML4-ALK Rearrangement and its clinical significance in chinese patients with advanced non-small cell lung cancer. Oncology (Switzerland). 2012;83(5):248-256. EXC6.
1598 Wang ZJ, An TT, Mok T, et al. Immediate versus delayed treatment with EGFR tyrosine kinase inhibitors after first-line therapy in advanced mon-small-cell lung cancer. Chinese Journal of Cancer Research. 2011;23(2):112-117. EXC5. [pmid: 23483659].
1599 Evaluation of the Oncotype Dx recurrence score (RS) in hormone-positive ipsilateral breast tumor recurrences. ASCO. 2012. EXC6.
1600 Ward R, Meagher A, Tomlinson I, et al. Microsatellite instability and the clinicopathological features of sporadic colorectal cancer. Gut. Jun. 2001;48(6):821-829. EXC6. [pmid: 11358903].
1601 Ward RL, Cheong K, Ku SL, et al. Adverse prognostic effect of methylation in colorectal cancer is reversed by microsatellite instability. J Clin Oncol. Oct. 15. 2003;21(20):3729-3736. EXC6. [pmid: 14551292].
1602 Ward RL, Turner J, Williams R, et al. Routine testing for mismatch repair deficiency in sporadic colorectal cancer is justified. J Pathol. 2005;207(4):377-384. EXC4. [pmid: 16175654].
1603 Watanabe T, Kobunai T, Yamamoto Y, et al. Chromosomal instability (CIN) phenotype, CIN high or CIN low, predicts survival for colorectal cancer. J Clin Oncol. Jun. 20. 2012;30(18):2256-2264. EXC4. [pmid: 22547595].
1604 Watanabe T, Wu TT, Catalano PJ, et al. Molecular predictors of survival after adjuvant chemotherapy for colon cancer. N Engl J Med. Apr. 19. 2001;344(16):1196-1206. EXC6. [pmid: 11309634].
1605 Watanabe T, Yoshino T, Uetake H, et al. KRAS mutational status in Japanese patients with colorectal cancer: results from a nationwide, multicenter, cross-sectional study. Jpn J Clin Oncol. Jul. 2013;43(7):706-712. EXC6. [pmid: 23657052].
1606 Webb S, Thomas M, Metcalf C, et al. EGFR mutation testing in NSCLC: Patterns of care and outcomes in Western Australia. Asia-Pacific Journal of Clinical Oncology. 2009;5(1):66-71. EXC6.
1607 Webster J, Kauffman TL, Feigelson HS, et al. KRAS testing and epidermal growth factor receptor inhibitor treatment for colorectal cancer in community settings. Cancer Epidemiol Biomarkers Prev. Jan. 2013;22(1):91-101. EXC3. [pmid: 23155138].
1608 Weickhardt AJ, Price TJ, Chong G, et al. Dual targeting of the epidermal growth factor receptor using the combination of cetuximab and erlotinib: preclinical evaluation and results of the phase II DUX study in chemotherapy-refractory, advanced colorectal cancer. J Clin Oncol. May. 1. 2012;30(13):1505-1512. EXC7. [pmid: 22412142].
1609 Weinberg DS. Towards the better identification of mutation carriers: Has HNPCC met its match? Commentary. Evidence-Based Gastroenterology. 2007;8(1):18-19. EXC4.
1610 Westra JL, Schaapveld M, Hollema H, et al. Determination of TP53 mutation is more relevant than microsatellite instability status for the prediction of disease-free survival in adjuvant-treated stage III colon cancer patients. J Clin Oncol. Aug. 20. 2005;23(24):5635-5643. EXC3. [pmid: 16110022].
1611 Whitson JM, Berry AB, Carroll PR, et al. UroVysion testing can lead to early identification of intravesical therapy failure in patients with high risk non-muscle invasive bladder cancer. Int Braz J Urol. Nov-Dec. 2009;35(6):664-670. discussion 71-2. EXC5. [pmid: 20028572].
1612 Wilkerson MD, Yin X, Walter V, et al. Differential pathogenesis of lung adenocarcinoma subtypes involving sequence mutations, copy number, chromosomal instability, and methylation. PLoS One. 2012;7(5):e36530. EXC6. [pmid: 22590557].
1613 Williams DJ, Cohen C, Darrow M, et al. Proliferation (Ki-67 and phosphohistone H3) and oncotype DX recurrence score in estrogen receptor-positive breast cancer. Applied Immunohistochemistry and Molecular Morphology. 2011;19(5):431-436. EXC6. [pmid: 21297447].
1614 Williamson SR, Zhang S, Lopez-Beltran A, et al. Lymphoepithelioma-like carcinoma of the urinary bladder: clinicopathologic, immunohistochemical, and molecular features. Am J Surg Pathol. Apr. 2011;35(4):474-483. EXC5. [pmid: 21383609].
1615 Wittner BS, Sgroi DC, Ryan PD, et al. Analysis of the MammaPrint breast cancer assay in a predominantly postmenopausal cohort. Clin Cancer Res. May. 15. 2008;14(10):2988-2993. EXC6. [pmid: 18483364].
1616 Wolf I, Ben-Baruch N, Shapira-Frommer R, et al. Association between standard clinical and pathologic characteristics and the 21-gene recurrence score in breast cancer patients: a population-based study. Cancer. Feb. 15. 2008;112(4):731-736. EXC5. [pmid: 18076012].
1617 Woll E, Greil R, Eisterer W, et al. Oxaliplatin, irinotecan and cetuximab in advanced gastric cancer. A multicenter phase ii trial (Gastric-2) of the Arbeitsgemeinschaft Medikamentose Tumortherapie (AGMT). Anticancer Res. 2011;31(12):4439-4443. EXC3. [pmid: 22199312].
1618 Won YW, Han JY, Lee GK, et al. Comparison of clinical outcome of patients with non-small-cell lung cancer harbouring epidermal growth factor receptor exon 19 or exon 21 mutations. J Clin Pathol. Nov. 2011;64(11):947-952. EXC3. [pmid: 21725039].
1619 Wong AS, Teo C, Lim SW, et al. Targeted therapy at the end of life for patients with lung cancer. Journal of Palliative Medicine. 2010;13(8):945-948. EXC4. [pmid: 20712464].
1620 Wong NS, Fernando NH, Nixon AB, et al. A phase II study of capecitabine, oxaliplatin, bevacizumab and cetuximab in the treatment of metastatic colorectal cancer. Anticancer Res. Jan. 2011;31(1):255-261. EXC7. [pmid: 21273607].
1621 Wong W, Cooper J, Richardson S, et al. Relationship between Oncotype DX testing and the use of chemotherapy in high-risk patients (pts). ASCO. 2012. EXC6.
1622 Woods MO, Younghusband HB, Parfrey PS, et al. The genetic basis of colorectal cancer in a population-based incident cohort with a high rate of familial disease. Gut. Oct. 2010;59(10):1369-1377. EXC3. [pmid: 20682701].
1623 Wright CM, Dent OF, Barker M, et al. Prognostic significance of extensive microsatellite instability in sporadic clinicopathological stage C colorectal cancer. Br J Surg. Sep. 2000;87(9):1197-1202. EXC3. [pmid: 10971428].
1624 Wright CM, Dent OF, Newland RC, et al. Low level microsatellite instability may be associated with reduced cancer specific survival in sporadic stage C colorectal carcinoma. Gut. Jan. 2005;54(1):103-108. EXC3. [pmid: 15591513].
1625 Wu F, Yang LY, Li YF, et al. Novel role for epidermal growth factor-like domain 7 in metastasis of human hepatocellular carcinoma. Hepatology. 2009;50(6):1839-1850. EXC3. [pmid: 19824075].
1626 Wu JY, Shih JY, Yang CH, et al. Second-line treatments after first-line gefitinib therapy in advanced nonsmall cell lung cancer. Int J Cancer. Jan. 1. 2010;126(1):247-255. EXC3. [pmid: 19536777].
1627 Wu JY, Wu SG, Yang CH, et al. Comparison of gefitinib and erlotinib in advanced NSCLC and the effect of EGFR mutations. Lung Cancer. May. 2011;72(2):205-212. EXC3. [pmid: 20832137].
1628 Wu JY, Wu SG, Yang CH, et al. Lung cancer with epidermal growth factor receptor exon 20 mutations is associated with poor gefitinib treatment response. Clin Cancer Res. Aug. 1. 2008;14(15):4877-4882. EXC7. [pmid: 18676761].
1629 Wu JY, Yang CH, Hsu YC, et al. Use of cetuximab after failure of gefitinib in patients with advanced non-small-cell lung cancer. Clin Lung Cancer. Jul. 1. 2010;11(4):257-263. EXC6. [pmid: 20630828].
1630 Wu JY, Yu CJ, Yang CH, et al. First- or second-line therapy with gefitinib produces equal survival in non-small cell lung cancer. Am J Respir Crit Care Med. 2008;178(8):847-853. EXC5. [pmid: 18583573].
1631 Wu M, Zhao J, Song SW, et al. EGFR mutations are associated with prognosis but not with the response to front-line chemotherapy in the Chinese patients with advanced non-small cell lung cancer. Lung Cancer. Mar. 2010;67(3):343-347. EXC6. [pmid: 19477549].
1632 Wu SG, Chang YL, Lin JW, et al. Including total EGFR staining in scoring improves EGFR mutations detection by mutation-specific antibodies and EGFR TKIs response prediction. PLoS One. 2011;6(8):e23303. EXC6. [pmid: 21858063].
1633 Wu SG, Gow CH, Yu CJ, et al. Frequent epidermal growth factor receptor gene mutations in malignant pleural effusion of lung adenocarcinoma. Eur Respir J. Oct. 2008;32(4):924-930. EXC6. [pmid: 18508816].
1634 Wu SG, Hu FC, Chang YL, et al. Frequent EGFR mutations in nonsmall cell lung cancer presenting with miliary intrapulmonary carcinomatosis. Eur Respir J. Feb. 2013;41(2):417-424. EXC6. [pmid: 22523351].
1635 Wu SG, Kuo YW, Chang YL, et al. EML4-ALK translocation predicts better outcome in lung adenocarcinoma patients with wild-type EGFR. J Thorac Oncol. Jan. 2012;7(1):98-104. EXC4. [pmid: 22124476].
1636 Wu SG, Yang CH, Yu CJ, et al. Good response to pemetrexed in patients of lung adenocarcinoma with epidermal growth factor receptor (EGFR) mutations. Lung Cancer. Jun. 2011;72(3):333-339. EXC3. [pmid: 21111508].
1637 Wulf MA, Bode B, Zimmermann D, et al. Silver-enhanced in situ hybridization for determination of EGFR copy number alterations in non-small cell lung cancer. Am J Surg Pathol. Dec. 2012;36(12):1801-1808. EXC6. [pmid: 23154768].
1638 Xi JJ, Jiang W, Lu SH, et al. Primary pulmonary mucoepidermoid carcinoma: an analysis of 21 cases. World J Surg Oncol. 2012;10:232. EXC4. [pmid: 23114230].
1639 Xicola RM, Llor X, Pons E, et al. Performance of different microsatellite marker panels for detection of mismatch repair-deficient colorectal tumors. J Natl Cancer Inst. Feb. 7. 2007;99(3):244-252. EXC6. [pmid: 17284719].
1640 Xu J, He J, Yang H, et al. Somatic mutation analysis of EGFR, KRAS, BRAF and PIK3CA in 861 patients with non-small cell lung cancer. Cancer Biomark. 2011;10(2):63-69. EXC7. [pmid: 22430133].
1641 Xu JM, Han Y, Duan HQ, et al. EGFR mutations and HER2/3 protein expression and clinical outcome in Chinese advanced non-small cell lung cancer patients treated with gefitinib. J Cancer Res Clin Oncol. Jun. 2009;135(6):771-782. EXC3. [pmid: 19020901].
1642 Yagi K, Akagi K, Hayashi H, et al. Three DNA methylation epigenotypes in human colorectal cancer. Clin Cancer Res. 2010;16(1):21-33. EXC6. [pmid: 20028768].
1643 Yam I, Lam DC, Chan K, et al. EGFR array: uses in the detection of plasma EGFR mutations in non-small cell lung cancer patients. J Thorac Oncol. Jul. 2012;7(7):1131-1140. EXC6. [pmid: 22610259].
1644 Yamada K, Kanazawa S, Koike J, et al. Microsatellite instability at tetranucleotide repeats in sporadic colorectal cancer in Japan. Oncol Rep. 2010;23(2):551-561. EXC4. [pmid: 20043121].
1645 Yamada N, Oizumi S, Asahina H, et al. The peptide nucleic acid-locked nucleic acid polymerase chain reaction clamp-based test for epidermal growth factor receptor mutations in bronchoscopic cytological specimens of non-small cell lung cancer. Oncology. 2012;82(6):341-346. EXC7. [pmid: 22677909].
1646 Yamaguchi F, Kugawa S, Tateno H, et al. Analysis of EGFR, KRAS and P53 mutations in lung cancer using cells in the curette lavage fluid obtained by bronchoscopy. Lung Cancer. Dec. 2012;78(3):201-206. EXC6. [pmid: 23026641].
1647 Yamamoto H, Hanafusa H, Ouchida M, et al. Single nucleotide polymorphisms in the EXO1 gene and risk of colorectal cancer in a Japanese population. Carcinogenesis. Feb. 2005;26(2):411-416. EXC4. [pmid: 15550454].
1648 Yamauchi H, Nakagawa C, Yamashige S, et al. Societal economics of the 21-gene Recurrence Score in estrogen receptor-positive early-stage breast cancer in Japan. SABCS. 2012. EXC6.
1649 Yamazaki K, Sugio K, Yamanaka T, et al. Prognostic factors in non-small cell lung cancer patients with postoperative recurrence following third-generation chemotherapy. Anticancer Res. Apr. 2010;30(4):1311-1315. EXC4. [pmid: 20530445].
1650 Yan B, Chin SY, Ismail TM, et al. KRAS mutation analysis as a diagnostic tool. Int J Colorectal Dis. Aug. 2011;26(8):1083-1084. EXC2. [pmid: 21128077].
1651 Yan HL, Hao LQ, Jin HY, et al. Clinical features and mismatch repair genes analyses of Chinese suspected hereditary non-polyposis colorectal cancer: a cost-effective screening strategy proposal. Cancer Sci. Apr. 2008;99(4):770-780. EXC3. [pmid: 18307539].
1652 Yanagisawa S, Morikawa N, Kimura Y, et al. Large-cell neuroendocrine carcinoma with epidermal growth factor receptor mutation: possible transformation of lung adenocarcinoma. Respirology. Nov. 2012;17(8):1275-1277. EXC2. [pmid: 22943430].
1653 Yang CH, Yu CJ, Shih JY, et al. Specific EGFR mutations predict treatment outcome of stage IIIB/IV patients with chemotherapy-naive non-small-cell lung cancer receiving first-line gefitinib monotherapy. J Clin Oncol. Jun. 1. 2008;26(16):2745-2753. EXC3. [pmid: 18509184].
1654 Yang JCH, Shih JY, Su WC, et al. Afatinib for patients with lung adenocarcinoma and epidermal growth factor receptor mutations (LUX-Lung 2): A phase 2 trial. The lancet oncology. 2012;13(5):539-548. EXC5. [pmid: 22452895].
1655 Yang JJ, Chen HJ, Yan HH, et al. Clinical modes of EGFR tyrosine kinase inhibitor failure and subsequent management in advanced non-small cell lung cancer. Lung Cancer. Jan. 2013;79(1):33-39. EXC6. [pmid: 23079155].
1656 Yang M, Tufail W, Patil DS, et al. Knowledge and preferences of breast and colorectal cancer survivors and patients for pharmacogenomic molecular diagnostics. Pharmacoepidemiology and Drug Safety. 2011;20:S330. EXC4.
1657 Yang MJ, Chiu HH, Wang HM, et al. Enhancing detection of circulating tumor cells with activating KRAS oncogene in patients with colorectal cancer by weighted chemiluminescent membrane array method. Ann Surg Oncol. Feb. 2010;17(2):624-633. EXC4. [pmid: 19937133].
1658 Yang SY, Yang TY, Chen KC, et al. EGFR L858R mutation and polymorphisms of genes related to estrogen biosynthesis and metabolism in never-smoking female lung adenocarcinoma patients. Clin Cancer Res. Apr. 15. 2011;17(8):2149-2158. EXC6. [pmid: 21300759].
1659 Yang SY, Yang TY, Li YJ, et al. EGFR exon-19 in-frame deletion and polymorphisms of DNA repair genes in never-smoking female lung adenocarcinoma patients. Int J Cancer. Jan. 15. 2013;132(2):449-458. EXC6. [pmid: 22573488].
1660 Yano M, Sasaki H, Kobayashi Y, et al. Epidermal growth factor receptor gene mutation and computed tomographic findings in peripheral pulmonary adenocarcinoma. J Thorac Oncol. Jun. 2006;1(5):413-416. EXC6. [pmid: 17409892].
1661 Yardlev DA, Peacock NW, Hendricks C, et al. T Correlation of Oncotype DX Recurrence Scores with pathologic response following neoadjuvant ixabepilone and cyclophosphamide in patients with HER2-negative breast cancer. San Antonio Breast Cancer Symposium. 2011. December. San Antonio, TX. EXC6.
1662 Yardlev DA, Peacock NW, Hendricks C, et al. Ixabepilone and Cyclophosphamide as Neoadjuvant Therapy in HER2-Negative Breast Cancer with Exploratory Oncotype DX® Assessments: A Sarah Cannon Research Institute Phase II Trial. EXC5.
1663 Yasuda H, Soejima K, Nakayama S, et al. Bronchoscopic microsampling is a useful complementary diagnostic tool for detecting lung cancer. Lung Cancer. Apr. 2011;72(1):32-38. EXC4. [pmid: 20813423].
1664 Yearsley M, Hampel H, Lehman A, et al. Histologic features distinguish microsatellite-high from microsatellite-low and microsatellite-stable colorectal carcinomas, but do not differentiate germline mutations from methylation of the MLH1 promoter. HumPathol. Jul. 2006;37(7):831-838. EXC6. [pmid: 16784982].
1665 Yen LC, Uen YH, Wu DC, et al. Activating KRAS mutations and overexpression of epidermal growth factor receptor as independent predictors in metastatic colorectal cancer patients treated with cetuximab. Ann Surg. Feb. 2010;251(2):254-260. EXC7. [pmid: 20010090].
1666 Yen LC, Yeh YS, Chen CW, et al. Detection of KRAS oncogene in peripheral blood as a predictor of the response to cetuximab plus chemotherapy in patients with metastatic colorectal cancer. Clin Cancer Res. Jul. 1. 2009;15(13):4508-4513. EXC3. [pmid: 19549774].
1667 Yeo WL, Riely GJ, Yeap BY, et al. Erlotinib at a dose of 25 mg daily for non-small cell lung cancers with EGFR mutations. J Thorac Oncol. Jul. 2010;5(7):1048-1053. EXC6. [pmid: 20512075].
1668 Yip PY, Yu B, Cooper WA, et al. Patterns of DNA mutations and ALK rearrangement in resected node negative lung adenocarcinoma. J Thorac Oncol. Apr. 2013;8(4):408-414. EXC6. [pmid: 23392229].
1669 Yoder BJ, Skacel M, Hedgepeth R, et al. Reflex UroVysion testing of bladder cancer surveillance patients with equivocal or negative urine cytology: a prospective study with focus on the natural history of anticipatory positive findings. Am J Clin Pathol. Feb. 2007;127(2):295-301. EXC7. [pmid: 17210520].
1670 Yokota K, Sasaki H, Okuda K, et al. KIF5B/RET fusion gene in surgically-treated adenocarcinoma of the lung. Oncol Rep. 2012;28(4):1187-1192. EXC4. [pmid: 22797671].
1671 Yokota T, Ura T, Shibata N, et al. BRAF mutation is a powerful prognostic factor in advanced and recurrent colorectal cancer. Br J Cancer. Mar. 1. 2011;104(5):856-862. EXC3. [pmid: 21285991].
1672 Yoshida A, Kohno T, Tsuta K, et al. ROS1-rearranged lung cancer: a clinicopathologic and molecular study of 15 surgical cases. Am J SurgPathol. Apr. 2013;37(4):554-562. EXC4. [pmid: 23426121].
1673 Yoshida K, Yatabe Y, Park J, et al. Clinical outcomes of advanced non-small cell lung cancer patients screened for epidermal growth factor receptor gene mutations. J Cancer Res Clin Oncol. 2010;136(4):527-535. EXC3. [pmid: 19777258].
1674 Yoshida K, Yatabe Y, Park JY, et al. Prospective validation for prediction of gefitinib sensitivity by epidermal growth factor receptor gene mutation in patients with non-small cell lung cancer. J Thorac Oncol. Jan. 2007;2(1):22-28. EXC3. [pmid: 17410005].
1675 Yoshida Y, Shibata T, Kokubu A, et al. Mutations of the epidermal growth factor receptor gene in atypical adenomatous hyperplasia and bronchioloalveolar carcinoma of the lung. Lung Cancer. Oct. 2005;50(1):1-8. EXC6. [pmid: 15950315].
1676 Yoshimasu T, Ohta F, Oura S, et al. Histoculture drug response assay for gefitinib in non-small-cell lung cancer. Gen Thorac Cardiovasc Surg. Mar. 2009;57(3):138-143. EXC6. [pmid: 19280309].
1677 Yoshitake N, Fujii S, Mukawa K, et al. Mutational analysis of the BRAF gene in colorectal mucinous carcinoma in association with histological configuration. Oncol Rep. Jan. 2007;17(1):9-15. EXC3. [pmid: 17143472].
1678 Yoshizawa A, Sumiyoshi S, Sonobe M, et al. Validation of the IASLC/ATS/ERS lung adenocarcinoma classification for prognosis and association with EGFR and KRAS gene mutations: analysis of 440 Japanese patients. J Thorac Oncol. Jan. 2013;8(1):52-61. EXC4. [pmid: 23242438].
1679 Yothers G, O'Connell MJ, Allegra CJ, et al. Oxaliplatin as adjuvant therapy for colon cancer: updated results of NSABP C-07 trial, including survival and subset analyses. J Clin Oncol. Oct. 1. 2011;29(28):3768-3774. EXC6. [pmid: 21859995].
1680 Yothers G, O'Connell MJ, Lee M, et al. Validation of the 12-Gene Colon Cancer Recurrence Score in NS ABP C-07 As a Predictor of Recurrence in Patients With Stage II and III Colon Cancer Treated With Fluorouracil and Leucovorin (FU/LV) and FU/LVPlus Oxaliplatin. J Clin Oncol. Dec. 20. 2013;31(36):4512-4519. EX8. [pmid: 24220557].
1681 Youssef RF, Schlomer BJ, Ho R, et al. Role of fluorescence in situ hybridization in bladder cancer surveillance of patients with negative cytology. Urol Oncol. May-Jun. 2012;30(3):273-277. EXC3. [pmid: 20451422].
1682 Alberts SR, Yu T, Behrens RJ, et al. Real-world comparative economics of a 12-gene assay for prognosis in stage II colon cancer. American Society of Clinical Oncology. 2013. June. Chicago, IL. EXC6.
1683 Yuan S, Yu SL, Chen HY, et al. Clustered genomic alterations in chromosome 7p dictate outcomes and targeted treatment responses of lung adenocarcinoma with EGFR-activating mutations. J Clin Oncol. Sep. 1. 2011;29(25):3435-3442. EXC4. [pmid: 21810691].
1684 Yuen ST, Chan TL, Ho JWC, et al. Germline, somatic and epigenetic events underlying mismatch repair deficiency in colorectal and HNPCC-related cancers. Oncogene. 2002;21(49):7585-7592. EXC4. [pmid: 12386821].
1685 Yun HR, Yi LJ, Cho YK, et al. Double primary malignancy in colorectal cancer patients-MSI is the useful marker for predicting double primary tumors. Int J Colorectal Dis. Apr. 2009;24(4):369-375. EXC6. [pmid: 18797888].
1686 Zaanan A, Flejou JF, Emile JF, et al. Defective mismatch repair status as a prognostic biomarker of disease-free survival in stage III colon cancer patients treated with adjuvant FOLFOX chemotherapy. Clin Cancer Res. Dec. 1. 2011;17(23):7470-7478. EXC6. [pmid: 21998335].
1687 Zavodna K, Konecny M, Krivulcik T, et al. Genetic analysis of KRAS mutation status in metastatic colorectal cancer patients. Neoplasma. 2009;56(3):275-278. EXC3. [pmid: 19309232].
1688 Zech VF, Dlaska M, Tzankov A, et al. Prognostic and diagnostic relevance of hnRNP A2/B1, hnRNP B1 and S100 A2 in non-small cell lung cancer. Cancer Detect Prev. 2006;30(5):395-402. EXC4. [pmid: 17067748].
1689 Zhang H, Song J, Ren H, et al. Detection of low-abundance KRAS mutations in colorectal cancer using microfluidic capillary electrophoresis-based restriction fragment length polymorphism method with optimized assay conditions. PLoS One. 2013;8(1):e54510. EXC4. [pmid: 23355875].
1690 Zhang J, Liang Z, Gao J, et al. Pulmonary adenocarcinoma with a micropapillary pattern: a clinicopathological, immunophenotypic and molecular analysis. Histopathology. Dec. 2011;59(6):1204-1214. EXC6. [pmid: 22175900].
1691 Zhang L. Immunohistochemistry versus microsatellite instability testing for screening colorectal cancer patients at risk for hereditary nonpolyposis colorectal cancer syndrome. Part II. The utility of microsatellite instability testing. J Mol Diagn. Jul. 2008;10(4):301-307. EXC2. [pmid: 18556776].
1692 Zhang L, Xiao H, Zhou H, et al. Development of transcriptomic biomarker signature in human saliva to detect lung cancer. Cell Mol Life Sci. 2012;69(19):3341-3350. EXC5. [pmid: 22689099].
1693 Zhang L, Yang H, Zhao Y, et al. Detection of EGFR somatic mutations in non-small cell lung cancer (NSCLC) using a novel mutant-enriched liquidchip (MEL) technology. Current Drug Metabolism. 2012;13(7):1007-1011. EXC6. [pmid: 22591345].
1694 Zhang W, Azuma M, Lurje G, et al. Molecular predictors of combination targeted therapies (cetuximab, bevacizumab) in irinotecan-refractory colorectal cancer (BOND-2 study). Anticancer Res. Oct. 2010;30(10):4209-4217. EXC8. [pmid: 21036743].
1695 Zhang W, Stabile LP, Keohavong P, et al. Mutation and polymorphism in the EGFR-TK domain associated with lung cancer. J Thorac Oncol. Sep. 2006;1(7):635-647. EXC6. [pmid: 17409930].
1696 Zhang W, Winder T, Ning Y, et al. A let-7 microRNA-binding site polymorphism in 3'-untranslated region of KRAS gene predicts response in wild-type KRAS patients with metastatic colorectal cancer treated with cetuximab monotherapy. Ann Oncol. Jan. 2011;22(1):104-109. EXC8. [pmid: 20603437].
1697 Zhang X, Liu G, Kang Y, et al. N-cadherin expression is associated with acquisition of EMT phenotype and with enhanced invasion in erlotinib-resistant lung cancer cell lines. PLoS One. 2013;8(3):e57692. EXC4. [pmid: 23520479].
1698 Zhang Y, Sun Y, Pan Y, et al. Frequency of driver mutations in lung adenocarcinoma from female never-smokers varies with histologic subtypes and age at diagnosis. Clin Cancer Res. Apr. 1. 2012;18(7):1947-1953. EXC6. [pmid: 22317764].
1699 Zhao Q, Shentu J, Xu N, et al. Phase I study of icotinib hydrochloride (BPI-2009H), an oral EGFR tyrosine kinase inhibitor, in patients with advanced NSCLC and other solid tumors. Lung Cancer. Aug. 2011;73(2):195-202. EXC6. [pmid: 21144613].
1700 Zhao X, Han RB, Zhao J, et al. Comparison of epidermal growth factor receptor mutation statuses in tissue and plasma in stage I-IV non-small cell lung cancer patients. Respiration. 2013;85(2):119-125. EXC6. [pmid: 22797485].
1701 Zhao Y, Oki E, Ando K, et al. The impact of a high-frequency microsatellite instability phenotype on the tumor location-related genetic differences in colorectal cancer. Cancer Genet Cytogenet. Jan. 15. 2010;196(2):133-139. EXC8. [pmid: 20082848].
1702 Zhao YY, Li S, Zhang Y, et al. The relationship between drug exposure and clinical outcomes of non-small cell lung cancer patients treated with gefitinib. Med Oncol. Sep. 2011;28(3):697-702. EXC3. [pmid: 20458561].
1703 Zheng T, Bepler G, Cantor A, et al. Small tumor size and limited smoking history predicts activated epidermal growth factor receptor in early-stage non-small cell lung cancer. Chest. 2005;128(1):308-316. EXC4. [pmid: 16002951].
1704 Zhou HH, Yan SY, Zhou XY, et al. MLH1 promoter germline-methylation in selected probands of Chinese hereditary non-polyposis colorectal cancer families. World J Gastroenterol. Dec. 28. 2008;14(48):7329-7334. EXC8. [pmid: 19109866].
1705 Zhou Q, Zhang XC, Chen ZH, et al. Relative abundance of EGFR mutations predicts benefit from gefitinib treatment for advanced non-small-cell lung cancer. J Clin Oncol. 2011;29(24):3316-3321. EXC5. [pmid: 21788562].
1706 Zhou ZW, Rieger N, Ruszkiewicz A, et al. Detection of lymph nodes micrometastases in Dukes' A and B colorectal cancer using anti-cytokeratin antibodies AE1/AE3. World Journal of Gastroenterology. 2005;11(23):3640-3643. EXC4. [pmid: 15962393].
1707 Zhu CQ, da Cunha Santos G, Ding K, et al. Role of KRAS and EGFR as biomarkers of response to erlotinib in National Cancer Institute of Canada Clinical Trials Group Study BR.21. J Clin Oncol. Sep. 10. 2008;26(26):4268-4275. EXC3. [pmid: 18626007].
1708 Zhu YJ, Xia Y, Ren GJ, et al. Efficacy and clinical/molecular predictors of erlotinib monotherapy for Chinese advanced non-small cell lung cancer. Chin Med J (Engl). Nov. 2010;123(22):3200-3205. EXC6. [pmid: 21163115].
1709 Zhuo ML, Wu MN, Zhao J, et al. Epidermal growth factor receptor genotype in plasma DNA and outcome of chemotherapy in the Chinese patients with advanced non-small cell lung cancer. Chin Med J (Engl). 2011;124(21):3510-3514. EXC4. [pmid: 22340169].
1710 Zikria J, Krishnamoorthy S, Kaley K, et al. Sweeping KRAS generalizations: Are we depriving patients of an effective treatment? A novel KRAS mutation and dramatic response to panitumumab in a patient with metastatic colorectal cancer. Int J Colorectal Dis. 2011;26(10):1353-1354. EXC4. [pmid: 21229361].
1711 Zlobec I, Baker K, Terracciano LM, et al. RHAMM, p21 combined phenotype identifies microsatellite instability-high colorectal cancers with a highly adverse prognosis. Clin Cancer Res. Jun. 15. 2008;14(12):3798-3806. EXC8. [pmid: 18559599].
1712 Zlobec I, Bihl M, Foerster A, et al. Comprehensive analysis of CpG island methylator phenotype (CIMP)-high, -low, and -negative colorectal cancers based on protein marker expression and molecular features. J Pathol. Nov. 2011;225(3):336-343. EXC8. [pmid: 21660972].
1713 Zlobec I, Kovac M, Erzberger P, et al. Combined analysis of specific KRAS mutation, BRAF and microsatellite instability identifies prognostic subgroups of sporadic and hereditary colorectal cancer. Int J Cancer. Dec. 1. 2010;127(11):2569-2575. EXC5. [pmid: 20162668].
1714 Zlobec I, Molinari F, Kovac M, et al. Prognostic and predictive value of TOPK stratified by KRAS and BRAF gene alterations in sporadic, hereditary and metastatic colorectal cancer patients. Br J Cancer. Jan. 5. 2010;102(1):151-161. EXC4. [pmid: 19935791].
1715 Zupa A, Improta G, Silvestri A, et al. A pilot characterization of human lung NSCLC by protein pathway activation mapping. J Thorac Oncol. Dec. 2012;7(12):1755-1766. EXC6. [pmid: 23154546].
1716 Zwitter M, Rajer M, Kovac V, et al. Intermittent chemotherapy and erlotinib for nonsmokers or light smokers with advanced adenocarcinoma of the lung: a phase II clinical trial. J Biomed Biotechnol. 2011;2011:185646. EXC3. [pmid: 21541241].