# Search Strategies

We conducted searches for relevant scientific literature using the following search strategies on 10/29/2012 and found 3,340 articles. We conducted an update literature using the same search terms and databases on 11/12/2013 with the following date limits: 10/29/2011 through 11/12/2013 to find more recently published articles. The update searches yielded a total of 1,233 citations, and after removing duplicates we added 468 new articles. The total number of unique sources found from the original and update searches and other sources such as hand searching and peer and public review comments was 3,850.

Table A1 PubMed update search strategies 11-11-2013

Search | Queries | Number of Citations
Urinary Bladder Cancer Search
#1 | Search "Urinary Bladder Neoplasms"[MeSH] | 42283
#2 | Search UroVysion | 148
#3 | Search IVDMIA OR "in vitro diagnostic multivariate index assay" | 6
#4 | Search #1 AND (#2 OR #3) | 104
#5 | Search "Biological Assay"[MeSH] | 32692
#6 | Search "Predictive Value of Tests"[MeSH] | 133463
#7 | Search "Proportional Hazards Models"[MeSH] | 40213
#8 | Search "Outcome and Process Assessment (Health Care)"[MeSH] | 670462
#9 | Search assay OR assays OR test OR tests | 7676643
#10 | Search #5 OR #6 OR #7 OR #8 OR #9 | 8058148
#11 | Search #4 AND #10 | 101
#12 | Search "Reproducibility of Results"[MeSH] OR “reproducibility of results”[all fields] | 257185
#13 | Search “Signal-to-Noise Ratio”[MeSH] OR “signal-to-noise ratio”[all fields] | 16217
#14 | Search “ROC Curve”[Mesh] OR "ROC curve" [All Fields] OR "receiver operating characteristic" [All Fields] OR “observer variation”[MeSH] OR “observer variation”[all fields] | 71690
#15 | Search “Sensitivity and Specificity”[Mesh] OR sensitiv*[Title/Abstract] OR "sensitivity and specificity" [All Fields] OR “analytic validity”[all fields] | 1194419
#16 | Search “Diagnostic Errors”[Mesh] OR diagnos*[Title/Abstract] OR diagnosis[MeSH:noexp] OR diagnostic[MeSH:noexp] OR diagnosis,differential[MeSH:noexp] OR diagnosis[Subheading:noexp] OR “accuracy”[All Fields] OR "diagnosis"[MeSH] "diagnostic accuracy”[All Fields] OR “precision”[All Fields] OR "diagnostic error*" [All Fields] | 96343
#17 | Search “Predictive Value of Tests”[Mesh] OR "probability"[MeSH] OR "probability" [All Fields] OR "likelihood" [All Fields] OR “false negative reactions”[MeSH] OR “false positive reactions”[MeSH] OR "predictive value of tests" [All Fields] OR "forecasting" [All Fields] OR "forecasting"[MeSH] | 1212754
#18 | Search #12 OR #13 OR #14 OR #15 OR #16 OR #17 | 2407314
#19 | Search #4 AND (#10 OR #18) | 103
#20 | Search #4 AND (#10 OR #18) Humans | 103
#21 | Search #4 AND (#10 OR #18) Humans; English | 97
#22 | Search #4 AND (#10 OR #18) Humans; English; Adult: 19+ years | 54
#23 | Search #4 AND (#10 OR #18) Humans; English; Adult: 19+ years; Publication date from 1980/01/01 | 54
#24 | Search #4 AND (#10 OR #18) Humans; English; Adult: 19+ years; Publication date from 2011/10/29 | 7
Breast Cancer Search
#1 | Search "Breast Neoplasms"[MeSH] | 207319
#2 | Search "oncotype DX" OR "21 gene recurrence score" OR "21 gene recurrence" | 210
#3 | Search “Mammaprint” OR “70 gene signature” | 130
#4 | Search IVDMIA OR "in vitro diagnostic multivariate index assay" | 6
#5 | Search #2 OR #3 OR #4 | 298
#6 | Search #1 AND #5 | 213
#7 | Search "Biological Assay"[MeSH] | 32692
#8 | Search "Predictive Value of Tests"[MeSH] | 133463
#9 | Search "Proportional Hazards Models"[MeSH] | 40213
#10 | Search "Outcome and Process Assessment (Health Care)"[MeSH] | 670462
#11 | Search assay OR assays OR test OR tests | 7676643
#12 | Search #7 OR #8 OR #9 OR #10 OR #11 | 8058148
#13 | Search #6 AND #12 | 194
#14 | Search "Reproducibility of Results"[MeSH] OR “reproducibility of results”[all fields] | 257185
#15 | Search “Signal-to-Noise Ratio”[MeSH] OR “signal-to-noise ratio”[all fields] | 16217
#16 | Search “ROC Curve”[Mesh] OR "ROC curve" [All Fields] OR "receiver operating characteristic" [All Fields] OR “observer variation”[MeSH] OR “observer variation”[all fields] | 71690
#17 | Search “Sensitivity and Specificity”[Mesh] OR sensitiv*[Title/Abstract] OR "sensitivity and specificity" [All Fields] OR “analytic validity”[all fields] | 1194419
#18 | Search “Diagnostic Errors”[Mesh] OR diagnos*[Title/Abstract] OR diagnosis[MeSH:noexp] OR diagnostic[MeSH:noexp] OR diagnosis,differential[MeSH:noexp] OR diagnosis[Subheading:noexp] OR “accuracy”[All Fields] OR "diagnosis"[MeSH] "diagnostic accuracy”[All Fields] OR “precision”[All Fields] OR "diagnostic error*" [All Fields] | 96343
#19 | Search “Predictive Value of Tests”[Mesh] OR "probability" [MeSH Terms] OR "probability" [All Fields] OR "likelihood" [All Fields] OR “false negative reactions”[MeSH] OR “false positive reactions”[MeSH] OR "predictive value of tests" [All Fields] OR "forecasting" [All Fields] OR "forecasting"[MeSH] | 1212754
#20 | Search #14 OR #15 OR #16 OR #17 OR #18 OR #19 | 2407314
#21 | Search #6 AND (#12 OR #20) | 202
#22 | Search #6 AND (#12 OR #20) Humans | 202
#23 | Search #6 AND (#12 OR #20) Humans; English | 195
#24 | Search #6 AND (#12 OR #20) Humans; English; Adult: 19+ years | 97
#25 | Search #6 AND (#12 OR #20) Humans; English; Adult: 19+ years; Publication date from 1980/01/01 | 97
#26 | Search #6 AND (#12 OR #20) Humans; English; Adult: 19+ years; Publication date from 2011/10/29 | 33
Colorectal Cancer Search
#1 | Search "Colorectal Neoplasms"[MeSH] | 140842
#2 | Search "Microsatellite Instability"[MeSH] OR "Microsatellite Instability" | 5399
#3 | Search MLH1 promoter methylation | 627
#4 | Search "KRAS protein, human" [Supplementary Concept] OR KRAS | 8312
#5 | Search "BRAF protein, human" [Supplementary Concept] OR BRAF | 4522
#6 | Search "Oncotype DX Colon" OR "21 gene recurrence score" OR "21 gene recurrence" | 58
#7 | Search IVDMIA OR "in vitro diagnostic multivariate index assay" | 6
#8 | Search #2 OR #3 OR #4 OR #5 OR #6 OR #7 | 16721
#9 | Search #1 AND #8 | 4188
#10 | Search "Biological Assay"[MeSH] | 32692
#11 | Search "Predictive Value of Tests"[MeSH] | 133463
#12 | Search "Proportional Hazards Models"[MeSH] | 40213
#13 | Search "Outcome and Process Assessment (Health Care)"[MeSH] | 670462
#14 | Search assay OR assays OR test OR tests | 7676643
#15 | Search #10 OR #11 OR #12 OR #13 OR #14 | 8058148
#16 | Search #9 AND #15 | 2770
#17 | Search "Reproducibility of Results"[MeSH] OR “reproducibility of results”[all fields] | 257185
#18 | Search “Signal-to-Noise Ratio”[MeSH] OR “signal-to-noise ratio”[all fields] | 16217
#19 | Search “ROC Curve”[Mesh] OR "ROC curve" [All Fields] OR "receiver operating characteristic" [All Fields] OR “observer variation”[MeSH] OR “observer variation”[all fields] | 71690
#20 | Search “Sensitivity and Specificity”[Mesh] OR sensitiv*[Title/Abstract] OR "sensitivity and specificity" [All Fields] OR “analytic validity”[all fields] | 1194419
#21 | Search “Diagnostic Errors”[Mesh] OR diagnos*[Title/Abstract] OR diagnosis[MeSH:noexp] OR diagnostic[MeSH:noexp] OR diagnosis,differential[MeSH:noexp] OR diagnosis[Subheading:noexp] OR “accuracy”[All Fields] OR "diagnosis"[MeSH] "diagnostic accuracy”[All Fields] OR “precision”[All Fields] OR "diagnostic error*" [All Fields] | 96343
#22 | Search “Predictive Value of Tests”[Mesh] OR "probability" [MeSH Terms] OR "probability" [All Fields] OR "likelihood" [All Fields] OR “false negative reactions”[MeSH] OR “false positive reactions”[MeSH] OR "predictive value of tests" [All Fields] OR "forecasting" [All Fields] OR "forecasting"[MeSH] | 1212754
#23 | Search #17 OR #18 OR #19 OR #20 OR #21 OR #22 | 2407314
#24 | Search #9 AND (#15 OR #23) | 2993
#25 | Search #9 AND (#15 OR #23) Filters: Humans | 2962
#26 | Search #9 AND (#15 OR #23) Filters: Humans; English | 2797
#27 | Search #9 AND (#15 OR #23) Filters: Humans; English; Adult: 19+ years | 1563
#28 | Search #9 AND (#15 OR #23) Filters: Humans; English; Adult: 19+ years; Publication date from 1980/01/01 | 1563
#29 | Search #9 AND (#15 OR #23) Filters: Humans; English; Adult: 19+ years; Publication date from 2011/10/29 | 345
Lung Cancer Search
#1 | Search "Lung Neoplasms"[MeSH] | 166161
#2 | Search "Carcinoma, Bronchogenic"[MeSH] | 38075
#3 | Search #1 OR #2 | 166161
#4 | Search EML4-ALK fusion protein, human[Supplementary Concept] | 143
#5 | Search ALK | 3768
#6 | Search "EGFR protein, human" [Supplementary Concept] OR EGFR | 26495
#7 | Search "KRAS protein, human" [Supplementary Concept] OR KRAS | 8312
#8 | Search IVDMIA OR "in vitro diagnostic multivariate index assay" | 6
#9 | Search #4 OR #5 OR #6 OR #7 OR #8 | 36797
#10 | Search #3 AND #9 | 4329
#11 | Search "Biological Assay"[MeSH] | 32692
#12 | Search "Predictive Value of Tests"[MeSH] | 133463
#13 | Search "Proportional Hazards Models"[MeSH] | 40213
#14 | Search "Outcome and Process Assessment (Health Care)"[MeSH] | 670462
#15 | Search assay OR assays OR test OR tests | 7676643
#16 | Search #11 OR #12 OR #13 OR #14 OR #15 | 8058148
#17 | Search #10 AND #16 | 2682
#18 | Search "Reproducibility of Results"[MeSH] OR “reproducibility of results”[all fields] | 257185
#19 | Search “Signal-to-Noise Ratio”[MeSH] OR “signal-to-noise ratio”[all fields] | 16217
#20 | Search “ROC Curve”[Mesh] OR "ROC curve" [All Fields] OR "receiver operating characteristic" [All Fields] OR “observer variation”[MeSH] OR “observer variation”[all fields] | 71690
#21 | Search “Sensitivity and Specificity”[Mesh] OR sensitiv*[Title/Abstract] OR "sensitivity and specificity" [All Fields] OR “analytic validity”[all fields] | 1194419
#22 | Search “Diagnostic Errors”[Mesh] OR diagnos*[Title/Abstract] OR diagnosis[MeSH:noexp] OR diagnostic[MeSH:noexp] OR diagnosis,differential[MeSH:noexp] OR diagnosis[Subheading:noexp] OR “accuracy”[All Fields] OR "diagnosis"[MeSH] "diagnostic accuracy”[All Fields] OR “precision”[All Fields] OR "diagnostic error*" [All Fields] | 96343
#23 | Search “Predictive Value of Tests”[Mesh] OR "probability" [MeSH Terms] OR "probability" [All Fields] OR "likelihood" [All Fields] OR “false negative reactions”[MeSH] OR “false positive reactions”[MeSH] OR "predictive value of tests" [All Fields] OR "forecasting" [All Fields] OR "forecasting"[MeSH] | 1212754
#24 | Search #18 OR #19 OR #20 OR #21 OR #22 OR #23 | 2407314
#25 | Search #10 AND (#16 OR #24) | 2992
#26 | Search #10 AND (#16 OR #24) Filters: Humans | 2912
#27 | Search #10 AND (#16 OR #24) Humans; English | 2696
#28 | Search #10 AND (#16 OR #24) Humans; English; Adult: 19+ years | 1292
#29 | Search #10 AND (#16 OR #24) Humans; English; Adult: 19+ years; Publication date from 1980/01/01 | 1292
#30 | Search #10 AND (#16 OR #24) Humans; English; Adult: 19+ years; Publication date from 2011/10/29 | 423

Table A2 Embase search strategies update 11-12-2013

Search | Queries | Number of Citations
Urinary Bladder Cancer Search
#1 | 'bladder tumor'/exp AND ([embase]/lim OR [embase classic]/lim) | 46,402
#2 | urovysion AND ([embase]/lim OR [embase classic]/lim) | 257
#3 | ivdmia OR 'in vitro diagnostic multivariate index assay' AND ([embase]/lim OR [embase classic]/lim) | 13
#4 | #1 AND (#2 OR #3) | 170
#5 | 'biological assay'/exp AND ([embase]/lim OR [embase classic]/lim) | 27,120
#6 | 'predictive value of tests'/exp AND ([embase]/lim OR [embase classic]/lim) | 36,618
#7 | 'proportional hazards models'/exp AND ([embase]/lim OR [embase classic]/lim) | 31,586
#8 | 'treatment outcome'/exp AND ([embase]/lim OR [embase classic]/lim) | 770,815
#9 | 'assay'/de OR assay OR assays OR test OR tests AND ([embase]/lim OR [embase classic]/lim) | 2,791,862
#10 | #5 OR #6 OR #7 OR #8 OR #9 | 3,455,670
#11 | #4 AND #10 | 124
#12 | 'reproducibility of results'/exp OR 'reproducibility of results' AND ([embase]/lim OR [embase classic]/lim) | 58,613
#13 | 'signal-to-noise ratio'/exp OR 'signal-to-noise ratio' AND ([embase]/lim OR [embase classic]/lim) | 21,815
#14 | 'roc curve'/exp OR 'roc curve' OR 'receiver operating characteristic'/exp OR 'receiver operating characteristic' OR 'observer variation'/exp OR 'observer variation' AND ([embase]/lim OR [embase classic]/lim) | 42,593
#15 | 'sensitivity and specificity'/exp OR 'sensitivity and specificity' OR 'sensitivity':ti OR 'sensitivity':ab OR 'analytic validity' AND ([embase]/lim OR [embase classic]/lim) | 553,407
#16 | 'diagnostic errors'/exp OR 'diagnostic errors' OR 'diagnosis':ti OR 'diagnosis':ab OR 'diagnostic accuracy'/exp OR 'diagnostic accuracy' OR 'precision'/exp OR 'precision' AND ([embase]/lim OR [embase classic]/lim) | 1,266,288
#17 | 'probability'/exp OR probability OR likelihood OR 'false negative reactions'/exp OR 'false negative reactions' OR 'false positive reactions'/exp OR 'false positive reactions' OR 'predictive value of tests'/exp OR 'predictive value of tests' OR 'forecasting'/exp OR forecasting AND ([embase]/lim OR [embase classic]/lim) | 284,237
#18 | #12 OR #13 OR #14 OR #15 OR #16 OR #17 | 1,942,881
#19 | #4 AND (#10 OR #18) | 158
#20 | #19 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1980–2012]/py | 33
#21 | #19 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1980–2012]/py AND [29-10-2011]/sd | 5
Breast Cancer Search
#1 | 'breast cancer'/exp AND ([embase]/lim OR [embase classic]/lim) | 269,829
#2 | 'oncotype dx' OR '21 gene recurrence score' OR '21 gene recurrence' AND ([embase]/lim OR [embase classic]/lim) | 606
#3 | 'mammaprint' OR '70 gene signature' AND ([embase]/lim OR [embase classic]/lim) | 341
#4 | ivdmia OR 'in vitro diagnostic multivariate index assay' AND ([embase]/lim OR [embase classic]/lim) | 13
#5 | #2 OR #3 OR #4 | 825
#6 | #1 AND #5 | 762
#7 | 'biological assay'/exp AND ([embase]/lim OR [embase classic]/lim) | 27,120
#8 | 'predictive value of tests'/exp AND ([embase]/lim OR [embase classic]/lim) | 36,618
#9 | 'proportional hazards models'/exp AND ([embase]/lim OR [embase classic]/lim) | 31,586
#10 | 'treatment outcome'/exp AND ([embase]/lim OR [embase classic]/lim) | 770,815
#11 | 'assay' OR 'assay'/exp OR assay OR assays OR test OR tests AND ([embase]/lim OR [embase classic]/lim) | 2,791,862
#12 | #7 OR #8 OR #9 OR #10 OR #11 | 3,455,570
#13 | #6 AND #12 | 551
#14 | 'reproducibility of results'/exp OR 'reproducibility of results' AND ([embase]/lim OR [embase classic]/lim) | 58,613
#15 | 'signal-to-noise ratio'/exp OR 'signal-to-noise ratio' AND ([embase]/lim OR [embase classic]/lim) | 21,815
#16 | 'roc curve'/exp OR 'roc curve' OR 'receiver operating characteristic'/exp OR 'receiver operating characteristic' OR 'observer variation'/exp OR 'observer variation' AND ([embase]/lim OR [embase classic]/lim) | 42,593
#17 | 'sensitivity and specificity'/exp OR 'sensitivity and specificity' OR 'sensitivity':ti OR 'sensitivity':ab OR 'analytic validity' AND ([embase]/lim OR [embase classic]/lim) | 563,407
#18 | 'diagnostic errors'/exp OR 'diagnostic errors' OR 'diagnosis':ti OR 'diagnosis':ab OR 'diagnostic accuracy'/exp OR 'diagnostic accuracy' OR 'precision'/exp OR 'precision' AND ([embase]/lim OR [embase classic]/lim) | 1,266,228
#19 | 'probability' OR 'probability'/exp OR probability OR likelihood OR 'false negative reactions'/exp OR 'false negative reactions' OR 'false positive reactions'/exp OR 'false positive reactions' OR 'predictive value of tests'/exp OR 'predictive value of tests' OR 'forecasting' OR 'forecasting'/exp OR forecasting AND ([embase]/lim OR [embase classic]/lim) | 284,237
#20 | #14 OR #15 OR #16 OR #17 OR #18 OR #19 | 1,942,881
#21 | #6 AND (#12 OR #20) | 610
#22 | #21 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1980–2012]/py | 68
#23 | #21 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1980–2012]/py AND [29-10-2011]/sd | 22
Colorectal Cancer Search
#1 | 'colorectal cancer'/exp AND ([embase]/lim OR [embase classic]/lim) | 75,215
#2 | 'microsatellite instability'/exp OR 'microsatellite instability' AND ([embase]/lim OR [embase classic]/lim) | 6,746
#3 | mlh1 AND ('promoter'/exp OR promoter) AND ('methylation'/exp OR methylation) AND ([embase]/lim OR [embase classic]/lim) | 275
#4 | kras AND ([embase]/lim OR [embase classic]/lim) | 7,176
#5 | braf AND ([embase]/lim OR [embase classic]/lim) | 6,862
#6 | 'oncotype dx colon' OR '21 gene recurrence score' OR '21 gene recurrence' AND ([embase]/lim OR [embase classic]/lim) | 135
#7 | ivdmia OR 'in vitro diagnostic multivariate index assay' AND ([embase]/lim OR [embase classic]/lim) | 13
#8 | #2 OR #3 OR #4 OR #5 OR #6 OR #7 | 18,195
#9 | #1 AND #8 | 4,955
#10 | 'biological assay'/exp AND ([embase]/lim OR [embase classic]/lim) | 27,120
#11 | 'predictive value of tests'/exp AND ([embase]/lim OR [embase classic]/lim) | 36,618
#12 | 'proportional hazards models'/exp AND ([embase]/lim OR [embase classic]/lim) | 31,586
#13 | 'treatment outcome'/exp AND ([embase]/lim OR [embase classic]/lim) | 770,815
#14 | 'assay' OR 'assay'/exp OR assay OR assays OR test OR tests AND ([embase]/lim OR [embase classic]/lim) | 2,791,862
#15 | #10 OR #11 OR #12 OR #13 OR #14 | 3,455,670
#16 | #9 AND #15 | 1,455
#17 | 'reproducibility of results'/exp OR 'reproducibility of results' AND ([embase]/lim OR [embase classic]/lim) | 58,613
#18 | 'signal-to-noise ratio'/exp OR 'signal-to-noise ratio' AND ([embase]/lim OR [embase classic]/lim) | 21,815
#19 | 'roc curve'/exp OR 'roc curve' OR 'receiver operating characteristic'/exp OR 'receiver operating characteristic' OR 'observer variation'/exp OR 'observer variation' AND ([embase]/lim OR [embase classic]/lim) | 42,593
#20 | 'sensitivity and specificity'/exp OR 'sensitivity and specificity' OR 'sensitivity':ti OR 'sensitivity':ab OR 'analytic validity' AND ([embase]/lim OR [embase classic]/lim) | 553,407
#21 | 'diagnostic errors'/exp OR 'diagnostic errors' OR 'diagnosis':ti OR 'diagnosis':ab OR 'diagnostic accuracy'/exp OR 'diagnostic accuracy' OR 'precision'/exp OR 'precision' AND ([embase]/lim OR [embase classic]/lim) | 1,266,228
#22 | 'probability' OR 'probability'/exp OR probability OR likelihood OR 'false negative reactions'/exp OR 'false negative reactions' OR 'false positive reactions'/exp OR 'false positive reactions' OR 'predictive value of tests'/exp OR 'predictive value of tests' OR 'forecasting' OR 'forecasting'/exp OR forecasting AND ([embase]/lim OR [embase classic]/lim) | 284,237
#23 | #17 OR #18 OR #19 OR #20 OR #21 OR #22 | 1,942,881
#24 | #9 AND (#15 OR #23) | 2,108
#25 | #24 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1980–2012]/py | 446
#26 | #24 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1980–2012]/py AND [29-10-2011]/sd | 100
Lung Cancer Search
#1 | 'lung cancer'/exp AND ([embase]/lim OR [embase classic]/lim) | 185,331
#2 | 'lung carcinoma'/exp AND ([embase]/lim OR [embase classic]/lim) | 95,316
#3 | #1 OR #2 | 185,331
#4 | 'eml4-alk' AND ([embase]/lim OR [embase classic]/lim) | 592
#5 | alk AND ([embase]/lim OR [embase classic]/lim) | 6,136
#6 | egfr AND ([embase]/lim OR [embase classic]/lim) | 37,705
#7 | kras AND ([embase]/lim OR [embase classic]/lim) | 7,176
#8 | ivdmia OR 'in vitro diagnostic multivariate index assay' AND ([embase]/lim OR [embase classic]/lim) | 13
#9 | #4 OR #5 OR #6 OR #7 OR #8 | 47,551
#10 | #3 AND #9 | 8,953
#11 | 'biological assay'/exp AND ([embase]/lim OR [embase classic]/lim) | 27,120
#12 | 'predictive value of tests'/exp AND ([embase]/lim OR [embase classic]/lim) | 36,618
#13 | 'proportional hazards models'/exp AND ([embase]/lim OR [embase classic]/lim) | 31,586
#14 | 'treatment outcome'/exp AND ([embase]/lim OR [embase classic]/lim) | 770,815
#15 | 'assay' OR 'assay'/exp OR assay OR assays OR test OR tests AND ([embase]/lim OR [embase classic]/lim) | 2,791,862
#16 | #11 OR #12 OR #13 OR #14 OR #15 | 3,455,670
#17 | #10 AND #16 | 2,799
#18 | 'reproducibility of results'/exp OR 'reproducibility of results' AND ([embase]/lim OR [embase classic]/lim) | 58,613
#19 | 'signal-to-noise ratio'/exp OR 'signal-to-noise ratio' AND ([embase]/lim OR [embase classic]/lim) | 21,815
#20 | 'roc curve'/exp OR 'roc curve' OR 'receiver operating characteristic'/exp OR 'receiver operating characteristic' OR 'observer variation'/exp OR 'observer variation' AND ([embase]/lim OR [embase classic]/lim) | 42,593
#21 | 'sensitivity and specificity'/exp OR 'sensitivity and specificity' OR 'sensitivity':ti OR 'sensitivity':ab OR 'analytic validity' AND ([embase]/lim OR [embase classic]/lim) | 553,407
#22 | 'diagnostic errors'/exp OR 'diagnostic errors' OR 'diagnosis':ti OR 'diagnosis':ab OR 'diagnostic accuracy'/exp OR 'diagnostic accuracy' OR 'precision'/exp OR 'precision' AND ([embase]/lim OR [embase classic]/lim) | 1,266,228
#23 | 'probability' OR 'probability'/exp OR probability OR likelihood OR 'false negative reactions'/exp OR 'false negative reactions' OR 'false positive reactions'/exp OR 'false positive reactions' OR 'predictive value of tests'/exp OR 'predictive value of tests' OR 'forecasting' OR 'forecasting'/exp OR forecasting AND ([embase]/lim OR [embase classic]/lim) | 284,237
#24 | #18 OR #19 OR #20 OR #21 OR #22 OR #23 | 1,942,881
#25 | #10 AND (#16 OR #24) | 4,029
#26 | #25 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1980–2012]/py | 756
#27 | #25 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1980–2012]/py AND [29-10-2011]/sd | 241

Table A3 Cochrane search strategies update 11-12-2013

Search | Queries | Number of Citations
Urinary Bladder Cancer Search
#1 | MeSH descriptor: [Urinary Bladder Neoplasms] explode all trees | 988
#2 | urovysion | 2
#3 | ivdmia | 1
#4 | "in vitro multivariate index assay" | 0
#5 | #1 and (#2 or #3 or #4) | 2
#6 | MeSH descriptor: [Biological Assay] explode all trees | 153
#7 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5420
#8 | MeSH descriptor: [Proportional Hazards Models] explode all trees | 3086
#9 | MeSH descriptor: [Outcome and Process Assessment (Health Care)] explode all trees | 89878
#10 | assay | 11865
#11 | assays | 11865
#12 | test | 149897
#13 | tests | 149897
#14 | #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 | 225622
#15 | MeSH descriptor: [Reproducibility of Results] explode all trees | 8399
#16 | "reproducibility of results" | 8720
#17 | MeSH descriptor: [Signal-To-Noise Ratio] explode all trees | 4
#18 | "signal-to-noise ratio" | 154
#19 | MeSH descriptor: [ROC Curve] explode all trees | 939
#20 | "ROC Curve" | 1224
#21 | "receiver operating characteristic" | 1253
#22 | MeSH descriptor: [Observer Variation] explode all trees | 1601
#23 | “observer variation” | 1796
#24 | MeSH descriptor: [Sensitivity and Specificity] explode all trees | 14453
#25 | sensitivity:ti (Word variations have been searched) | 2853
#26 | sensitivity:ab (Word variations have been searched) | 15946
#27 | "sensitivity and specificity" | 11631
#28 | “analytic validity” | 9
#29 | MeSH descriptor: [Diagnostic Errors] explode all trees | 2444
#30 | diagnos*:ti,ab | 35756
#31 | MeSH descriptor: [Diagnosis] this term only | 232499
#32 | MeSH descriptor: [Diagnosis, Differential] this term only | 1401
#33 | Any MeSH descriptor with qualifier(s): [Diagnosis - DI] | 35316
#34 | accuracy | 10492
#35 | MeSH descriptor: [Diagnosis] explode all trees | 232499
#36 | diagnostic accuracy | 4494
#37 | precision | 3052
#38 | "diagnostic error*" | 312
#39 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5420
#40 | MeSH descriptor: [Probability] explode all trees | 34522
#41 | probability | 12210
#42 | likelihood | 6636
#43 | MeSH descriptor: [False Negative Reactions] explode all trees | 323
#44 | MeSH descriptor: [False Positive Reactions] explode all trees | 490
#45 | "predictive value of test*" | 5548
#46 | forecasting | 624
#47 | MeSH descriptor: [Forecasting] explode all trees | 456
#48 | #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 or #46 or #47 | 289183
#49 | #5 and (#14 or #48) | 2
#50 | #5 and (#14 or #48) from 1980 | 2
#51 | #5 and (#14 or #48) from 2011 | 0
Breast Cancer Search
#1 | MeSH descriptor: [Breast Neoplasms] explode all trees | 8030
#2 | "oncotype DX" | 13
#3 | "21 gene recurrence score" | 11
#4 | "21 gene recurrence" | 11
#5 | Mammaprint | 10
#6 | "70 gene signature" | 3
#7 | ivdmia | 1
#8 | "in vitro multivariate index assay" | 0
#9 | #1 AND (#2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8) | 30
#10 | MeSH descriptor: [Biological Assay] explode all trees | 153
#11 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5420
#12 | MeSH descriptor: [Proportional Hazards Models] explode all trees | 3086
#13 | MeSH descriptor: [Outcome and Process Assessment (Health Care)] explode all trees | 89878
#14 | assay | 11865
#15 | assays | 11865
#16 | test | 149897
#17 | tests | 149897
#18 | #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 | 225622
#19 | MeSH descriptor: [Reproducibility of Results] explode all trees | 8399
#20 | "reproducibility of results" | 8720
#21 | MeSH descriptor: [Signal-To-Noise Ratio] explode all trees | 4
#22 | "signal-to-noise ratio" | 154
#23 | MeSH descriptor: [ROC Curve] explode all trees | 939
#24 | "ROC Curve" | 1224
#25 | "receiver operating characteristic" | 1253
#26 | MeSH descriptor: [Observer Variation] explode all trees | 1601
#27 | “observer variation” | 1796
#28 | MeSH descriptor: [Sensitivity and Specificity] explode all trees | 14453
#29 | sensitivity:ti (Word variations have been searched) | 2853
#30 | sensitivity:ab (Word variations have been searched) | 15946
#31 | "sensitivity and specificity" | 11631
#32 | “analytic validity” | 9
#33 | MeSH descriptor: [Diagnostic Errors] explode all trees | 2444
#34 | diagnos*:ti,ab | 35756
#35 | MeSH descriptor: [Diagnosis] this term only | 232499
#36 | MeSH descriptor: [Diagnosis, Differential] this term only | 1401
#37 | Any MeSH descriptor with qualifier(s): [Diagnosis - DI] | 35316
#38 | accuracy | 10492
#39 | MeSH descriptor: [Diagnosis] explode all trees | 232499
#40 | diagnostic accuracy | 4494
#41 | precision | 3052
#42 | "diagnostic error*" | 312
#43 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5420
#44 | MeSH descriptor: [Probability] explode all trees | 34522
#45 | probability | 12210
#46 | likelihood | 6636
#47 | MeSH descriptor: [False Negative Reactions] explode all trees | 323
#48 | MeSH descriptor: [False Positive Reactions] explode all trees | 490
#49 | "predictive value of test*" | 5548
#50 | forecasting | 624
#51 | MeSH descriptor: [Forecasting] explode all trees | 456
#52 | #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 or #46 or #47 or #48 or #49 or #50 or #51 | 289183
#53 | #9 and (#18 or #52) | 29
#54 | #9 and (#18 or #52) from 1980 | 29
#55 | #9 and (#18 or #52) from 2011 | 16
Colorectal Cancer Search
#1 | MeSH descriptor: [Colorectal Neoplasms] explode all trees | 8030
#2 | MeSH descriptor: [Microsatellite Instability] explode all trees | 25
#3 | "Microsatellite Instability" | 59
#4 | MLH1 promoter methylation | 3
#5 | KRAS protein, human | 90
#6 | KRAS | 140
#7 | BRAF protein, human | 41
#8 | "Oncotype DX Colon" | 0
#9 | "21 gene recurrence score" | 11
#10 | "21 gene recurrence" | 11
#11 | ivdmia | 1
#12 | "in vitro multivariate index assay" | 0
#13 | #1 and (#2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12) | 14
#14 | MeSH descriptor: [Biological Assay] explode all trees | 153
#15 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5420
#16 | MeSH descriptor: [Proportional Hazards Models] explode all trees | 3086
#17 | MeSH descriptor: [Outcome and Process Assessment (Health Care)] explode all trees | 89878
#18 | assay | 11865
#19 | assays | 11865
#20 | test | 149897
#21 | tests | 149897
#22 | #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 | 225622
#23 | MeSH descriptor: [Reproducibility of Results] explode all trees | 8399
#24 | "reproducibility of results" | 8720
#25 | MeSH descriptor: [Signal-To-Noise Ratio] explode all trees | 4
#26 | "signal-to-noise ratio" | 154
#27 | MeSH descriptor: [ROC Curve] explode all trees | 939
#28 | "ROC Curve" | 1224
#29 | "receiver operating characteristic" | 1253
#30 | MeSH descriptor: [Observer Variation] explode all trees | 1601
#31 | “observer variation” | 1796
#32 | MeSH descriptor: [Sensitivity and Specificity] explode all trees | 14453
#33 | sensitivity:ti (Word variations have been searched) | 2853
#34 | sensitivity:ab (Word variations have been searched) | 15946
#35 | "sensitivity and specificity" | 11631
#36 | “analytic validity” | 9
#37 | MeSH descriptor: [Diagnostic Errors] explode all trees | 2444
#38 | diagnos*:ti,ab | 35756
#39 | MeSH descriptor: [Diagnosis] this term only | 232499
#40 | MeSH descriptor: [Diagnosis, Differential] this term only | 1401
#41 | Any MeSH descriptor with qualifier(s): [Diagnosis - DI] | 35316
#42 | accuracy | 10492
#43 | MeSH descriptor: [Diagnosis] explode all trees | 232499
#44 | diagnostic accuracy | 4494
#45 | precision | 3052
#46 | "diagnostic error*" | 312
#47 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5420
#48 | MeSH descriptor: [Probability] explode all trees | 34522
#49 | probability | 12210
#50 | likelihood | 6636
#51 | MeSH descriptor: [False Negative Reactions] explode all trees | 323
#52 | MeSH descriptor: [False Positive Reactions] explode all trees | 490
#53 | "predictive value of test*" | 5548
#54 | forecasting | 624
#55 | MeSH descriptor: [Forecasting] explode all trees | 456
#56 | #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 or #46 or #47 or #48 or #49 or #50 or #51 or #52 or #53 or #54 or #55 | 289183
#57 | #13 and (#22 or #56) | 14
#58 | #13 and (#22 or #56) from 1980 | 14
#59 | #13 and (#22 or #56) from 2011 | 7
Lung Cancer Search
#1 | MeSH descriptor: [Lung Neoplasms] explode all trees | 4548
#2 | MeSH descriptor: [Carcinoma, Bronchogenic] explode all trees | 2388
#3 | #1 or #2 | 4548
#4 | EML4-ALK fusion protein, human | 0
#5 | ALK | 125
#6 | EGFR protein, human | 221
#7 | EGFR | 655
#8 | KRAS protein, human | 90
#9 | KRAS | 140
#10 | ivdmia | 1
#11 | "in vitro multivariate index assay" | 0
#12 | #3 and (#4 or #5 or #6 or #8 or #9 or #10 or #11) | 75
#13 | MeSH descriptor: [Biological Assay] explode all trees | 153
#14 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5420
#15 | MeSH descriptor: [Proportional Hazards Models] explode all trees | 3086
#16 | MeSH descriptor: [Outcome and Process Assessment (Health Care)] explode all trees | 89878
#17 | assay | 11865
#18 | assays | 11865
#19 | test | 149897
#20 | tests | 149897
#21 | #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 | 225622
#22 | MeSH descriptor: [Reproducibility of Results] explode all trees | 8399
#23 | "reproducibility of results" | 8720
#24 | MeSH descriptor: [Signal-To-Noise Ratio] explode all trees | 4
#25 | "signal-to-noise ratio" | 154
#26 | MeSH descriptor: [ROC Curve] explode all trees | 939
#27 | "ROC Curve" | 1224
#28 | "receiver operating characteristic" | 1253
#29 | MeSH descriptor: [Observer Variation] explode all trees | 1601
#30 | “observer variation” | 1796
#31 | MeSH descriptor: [Sensitivity and Specificity] explode all trees | 14453
#32 | sensitivity:ti (Word variations have been searched) | 2853
#33 | sensitivity:ab (Word variations have been searched) | 15946
#34 | "sensitivity and specificity" | 11631
#35 | “analytic validity” | 9
#36 | MeSH descriptor: [Diagnostic Errors] explode all trees | 2444
#37 | diagnos*:ti,ab | 35756
#38 | MeSH descriptor: [Diagnosis] this term only | 232499
#39 | MeSH descriptor: [Diagnosis, Differential] this term only | 1401
#40 | Any MeSH descriptor with qualifier(s): [Diagnosis - DI] | 35316
#41 | accuracy | 10492
#42 | MeSH descriptor: [Diagnosis] explode all trees | 232499
#43 | diagnostic accuracy | 4494
#44 | precision | 3052
#45 | "diagnostic error*" | 312
#46 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5420
#47 | MeSH descriptor: [Probability] explode all trees | 34522
#48 | probability | 12210
#49 | likelihood | 6636
#50 | MeSH descriptor: [False Negative Reactions] explode all trees | 323
#51 | MeSH descriptor: [False Positive Reactions] explode all trees | 490
#52 | "predictive value of test*" | 5548
#53 | forecasting | 624
#54 | MeSH descriptor: [Forecasting] explode all trees | 456
#55 | #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 or #46 or #47 or #48 or #49 or #50 or #51 or #52 or #53 or #54 | 289183
#56 | #12 and (#21 or #55) | 60
#57 | #12 and (#21 or #55) from 1980 | 60
#58 | #12 and (#21 or #55) from 2011 | 34

Table A4 PubMed search strategies 10-29-2012

Search | Queries | Number of Citations
Urinary Bladder Cancer Search
#1 | Search "Urinary Bladder Neoplasms"[MeSH] | 40721
#2 | Search UroVysion | 127
#3 | Search IVDMIA OR "in vitro diagnostic multivariate index assay" | 138
#4 | Search #1 AND (#2 OR #3) | 98
#5 | Search "Biological Assay"[MeSH] | 31814
#6 | Search "Predictive Value of Tests"[MeSH] | 123188
#7 | Search "Proportional Hazards Models"[MeSH] | 35131
#8 | Search "Outcome and Process Assessment (Health Care)"[MeSH] | 616326
#9 | Search assay OR assays OR test OR tests | 7254565
#10 | Search #5 OR #6 OR #7 OR #8 OR #9 | 7608298
#11 | Search #4 AND #10 | 95
#12 | Search "Reproducibility of Results"[MeSH] OR “reproducibility of results”[all fields] | 237807
#13 | Search “Signal-to-Noise Ratio”[MeSH] OR “signal-to-noise ratio”[all fields] | 14372
#14 | Search “ROC Curve”[Mesh] OR "ROC curve" [All Fields] OR "receiver operating characteristic" [All Fields] OR “observer variation”[MeSH] OR “observer variation”[all fields] | 63708
#15 | Search “Sensitivity and Specificity”[Mesh] OR sensitiv*[Title/Abstract] OR "sensitivity and specificity" [All Fields] OR “analytic validity”[all fields] | 1119176
#16 | Search “Diagnostic Errors”[Mesh] OR diagnos*[Title/Abstract] OR diagnosis[MeSH:noexp] OR diagnostic[MeSH:noexp] OR diagnosis,differential[MeSH:noexp] OR diagnosis[Subheading:noexp] OR “accuracy”[All Fields] OR "diagnosis"[MeSH] "diagnostic accuracy”[All Fields] OR “precision”[All Fields] OR "diagnostic error*" [All Fields] | 87894
#17 | Search “Predictive Value of Tests”[Mesh] OR "probability"[MeSH] OR "probability" [All Fields] OR "likelihood" [All Fields] OR “false negative reactions”[MeSH] OR “false positive reactions”[MeSH] OR "predictive value of tests" [All Fields] OR "forecasting" [All Fields] OR "forecasting"[MeSH] | 1129894
#18 | Search #12 OR #13 OR #14 OR #15 OR #16 OR #17 | 2249689
#19 | Search #4 AND (#10 OR #18) | 97
#20 | Search #4 AND (#10 OR #18) Humans | 97
#21 | Search #4 AND (#10 OR #18) Humans; English | 92
#22 | Search #4 AND (#10 OR #18) Humans; English; Adult: 19+ years | 51
#23 | Search #4 AND (#10 OR #18) Humans; English; Adult: 19+ years; Publication date from 1980/01/01 | 51
Breast Cancer Search
#1 | Search "Breast Neoplasms"[MeSH] | 196562
#2 | Search "oncotype DX" OR "21 gene recurrence score" OR "21 gene recurrence" | 158
#3 | Search “Mammaprint” OR “70 gene signature” | 101
#4 | Search IVDMIA OR "in vitro diagnostic multivariate index assay" | 138
#5 | Search #2 OR #3 OR #4 | 358
#6 | Search #1 AND #5 | 178
#7 | Search "Biological Assay"[MeSH] | 31814
#8 | Search "Predictive Value of Tests"[MeSH] | 123188
#9 | Search "Proportional Hazards Models"[MeSH] | 35131
#10 | Search "Outcome and Process Assessment (Health Care)"[MeSH] | 616326
#11 | Search assay OR assays OR test OR tests | 7254565
#12 | Search #7 OR #8 OR #9 OR #10 OR #11 | 7588075
#13 | Search #6 AND #12 | 164
#14 | Search "Reproducibility of Results"[MeSH] OR “reproducibility of results”[all fields] | 237807
#15 | Search “Signal-to-Noise Ratio”[MeSH] OR “signal-to-noise ratio”[all fields] | 14372
#16 | Search “ROC Curve”[Mesh] OR "ROC curve" [All Fields] OR "receiver operating characteristic" [All Fields] OR “observer variation”[MeSH] OR “observer variation”[all fields] | 63708
#17 | Search “Sensitivity and Specificity”[Mesh] OR sensitiv*[Title/Abstract] OR "sensitivity and specificity" [All Fields] OR “analytic validity”[all fields] | 1119176
#18 | Search “Diagnostic Errors”[Mesh] OR diagnos*[Title/Abstract] OR diagnosis[MeSH:noexp] OR diagnostic[MeSH:noexp] OR diagnosis,differential[MeSH:noexp] OR diagnosis[Subheading:noexp] OR “accuracy”[All Fields] OR "diagnosis"[MeSH] "diagnostic accuracy”[All Fields] OR “precision”[All Fields] OR "diagnostic error*" [All Fields] | 87894
#19 | Search “Predictive Value of Tests”[Mesh] OR "probability" [MeSH Terms] OR "probability" [All Fields] OR "likelihood" [All Fields] OR “false negative reactions”[MeSH] OR “false positive reactions”[MeSH] OR "predictive value of tests" [All Fields] OR "forecasting" [All Fields] OR "forecasting"[MeSH] | 1129894
#20 | Search #14 OR #15 OR #16 OR #17 OR #18 OR #19 | 2249689
#21 | Search #6 AND (#12 OR #20) | 170
#22 | Search #6 AND (#12 OR #20) Humans | 170
#23 | Search #6 AND (#12 OR #20) Humans; English | 166
#24 | Search #6 AND (#12 OR #20) Humans; English; Adult: 19+ years | 84
#25 | Search #6 AND (#12 OR #20) Humans; English; Adult: 19+ years; Publication date from 1980/01/01 | 84
Colorectal Cancer Search
#1 | Search "Colorectal Neoplasms"[MeSH] | 133525
#2 | Search "Microsatellite Instability"[MeSH] OR "Microsatellite Instability" | 5029
#3 | Search MLH1 promoter methylation | 581
#4 | Search "KRAS protein, human" [Supplementary Concept] OR KRAS | 3263
#5 | Search "BRAF protein, human" [Supplementary Concept] OR BRAF | 3374
#6 | Search "Oncotype DX Colon" OR "21 gene recurrence score" OR "21 gene recurrence" | 46
#7 | Search IVDMIA OR "in vitro diagnostic multivariate index assay" | 138
#8 | Search #2 OR #3 OR #4 OR #5 OR #6 OR #7 | 10733
#9 | Search #1 AND #8 | 3532
#10 | Search "Biological Assay"[MeSH] | 31814
#11 | Search "Predictive Value of Tests"[MeSH] | 123188
#12 | Search "Proportional Hazards Models"[MeSH] | 35131
#13 | Search "Outcome and Process Assessment (Health Care)"[MeSH] | 616326
#14 | Search assay OR assays OR test OR tests | 7254565
#15 | Search #10 OR #11 OR #12 OR #13 OR #14 | 7608298
#16 | Search #9 AND #15 | 2315
#17 | Search "Reproducibility of Results"[MeSH] OR “reproducibility of results”[all fields] | 237807
#18 | Search “Signal-to-Noise Ratio”[MeSH] OR “signal-to-noise ratio”[all fields] | 14372
#19 | Search “ROC Curve”[Mesh] OR "ROC curve" [All Fields] OR "receiver operating characteristic" [All Fields] OR “observer variation”[MeSH] OR “observer variation”[all fields] | 63708
#20 | Search “Sensitivity and Specificity”[Mesh] OR sensitiv*[Title/Abstract] OR "sensitivity and specificity" [All Fields] OR “analytic validity”[all fields] | 1119176
#21 | Search “Diagnostic Errors”[Mesh] OR diagnos*[Title/Abstract] OR diagnosis[MeSH:noexp] OR diagnostic[MeSH:noexp] OR diagnosis,differential[MeSH:noexp] OR diagnosis[Subheading:noexp] OR “accuracy”[All Fields] OR "diagnosis"[MeSH] "diagnostic accuracy”[All Fields] OR “precision”[All Fields] OR "diagnostic error*" [All Fields] | 87894
#22 | Search “Predictive Value of Tests”[Mesh] OR "probability" [MeSH Terms] OR "probability" [All Fields] OR "likelihood" [All Fields] OR “false negative reactions”[MeSH] OR “false positive reactions”[MeSH] OR "predictive value of tests" [All Fields] OR "forecasting" [All Fields] OR "forecasting"[MeSH] | 1129894
#23 | Search #17 OR #18 OR #19 OR #20 OR #21 OR #22 | 2249689
#24 | Search #9 AND (#15 OR #23) | 2513
#25 | Search #9 AND (#15 OR #23) Filters: Humans | 2492
#26 | Search #9 AND (#15 OR #23) Filters: Humans; English | 2363
#27 | Search #9 AND (#15 OR #23) Filters: Humans; English; Adult: 19+ years | 1338
#28 | Search #9 AND (#15 OR #23) Filters: Humans; English; Adult: 19+ years; Publication date from 1980/01/01 | 1338
Lung Cancer Search
#1 | Search "Lung Neoplasms"[MeSH] | 158827
#2 | Search "Carcinoma, Bronchogenic"[MeSH] | 35282
#3 | Search #1 OR #2 | 158827
#4 | Search EML4-ALK fusion protein, human[Supplementary Concept] | 90
#5 | Search ALK | 3208
#6 | Search "EGFR protein, human" [Supplementary Concept] OR EGFR | 22440
#7 | Search "KRAS protein, human" [Supplementary Concept] OR KRAS | 3263
#8 | Search IVDMIA OR "in vitro diagnostic multivariate index assay" | 138
#9 | Search #4 OR #5 OR #6 OR #7 OR #8 | 27905
#10 | Search #3 AND #9 | 3380
#11 | Search "Biological Assay"[MeSH] | 31814
#12 | Search "Predictive Value of Tests"[MeSH] | 123188
#13 | Search "Proportional Hazards Models"[MeSH] | 35131
#14 | Search "Outcome and Process Assessment (Health Care)"[MeSH] | 616326
#15 | Search assay OR assays OR test OR tests | 7254565
#16 | Search #11 OR #12 OR #13 OR #14 OR #15 | 7608298
#17 | Search #10 AND #16 | 2081
#18 | Search "Reproducibility of Results"[MeSH] OR “reproducibility of results”[all fields] | 237807
#19 | Search “Signal-to-Noise Ratio”[MeSH] OR “signal-to-noise ratio”[all fields] | 14372
#20 | Search “ROC Curve”[Mesh] OR "ROC curve" [All Fields] OR "receiver operating characteristic" [All Fields] OR “observer variation”[MeSH] OR “observer variation”[all fields] | 63708
#21 | Search “Sensitivity and Specificity”[Mesh] OR sensitiv*[Title/Abstract] OR "sensitivity and specificity" [All Fields] OR “analytic validity”[all fields] | 1119176
#22 | Search “Diagnostic Errors”[Mesh] OR diagnos*[Title/Abstract] OR diagnosis[MeSH:noexp] OR diagnostic[MeSH:noexp] OR diagnosis,differential[MeSH:noexp] OR diagnosis[Subheading:noexp] OR “accuracy”[All Fields] OR "diagnosis"[MeSH] "diagnostic accuracy”[All Fields] OR “precision”[All Fields] OR "diagnostic error*" [All Fields] | 87894
#23 | Search “Predictive Value of Tests”[Mesh] OR "probability" [MeSH Terms] OR "probability" [All Fields] OR "likelihood" [All Fields] OR “false negative reactions”[MeSH] OR “false positive reactions”[MeSH] OR "predictive value of tests" [All Fields] OR "forecasting" [All Fields] OR "forecasting"[MeSH] | 1129894
#24 | Search #18 OR #19 OR #20 OR #21 OR #22 OR #23 | 2249689
#25 | Search #10 AND (#16 OR #24) | 2338
#26 | Search #10 AND (#16 OR #24) Filters: Humans | 2294
#27 | Search #10 AND (#16 OR #24) Humans; English | 2122
#28 | Search #10 AND (#16 OR #24) Humans; English; Adult: 19+ years | 1005
#29 | Search #10 AND (#16 OR #24) Humans; English; Adult: 19+ years; Publication date from 1980/01/01 | 1005

Table A5 Embase search strategies 10-26-2012

Search | Queries | Number of Citations
Urinary Bladder Cancer Search
#1 | 'bladder tumor'/exp AND ([embase]/lim OR [embase classic]/lim) | 44,524
#2 | urovysion AND ([embase]/lim OR [embase classic]/lim) | 221
#3 | ivdmia OR 'in vitro diagnostic multivariate index assay' AND ([embase]/lim OR [embase classic]/lim) | 11
#4 | #1 AND (#2 OR #3) | 147
#5 | 'biological assay'/exp AND ([embase]/lim OR [embase classic]/lim) | 27,952
#6 | 'predictive value of tests'/exp AND ([embase]/lim OR [embase classic]/lim) | 20,862
#7 | 'proportional hazards models'/exp AND ([embase]/lim OR [embase classic]/lim) | 24,303
#8 | 'treatment outcome'/exp AND ([embase]/lim OR [embase classic]/lim) | 700,975
#9 | 'assay'/de OR assay OR assays OR test OR tests AND ([embase]/lim OR [embase classic]/lim) | 2,963,585
#10 | #5 OR #6 OR #7 OR #8 OR #9 | 3,557,123
#11 | #4 AND #10 | 114
#12 | 'reproducibility of results'/exp OR 'reproducibility of results' AND ([embase]/lim OR [embase classic]/lim) | 55,781
#13 | 'signal-to-noise ratio'/exp OR 'signal-to-noise ratio' AND ([embase]/lim OR [embase classic]/lim) | 22,964
#14 | 'roc curve'/exp OR 'roc curve' OR 'receiver operating characteristic'/exp OR 'receiver operating characteristic' OR 'observer variation'/exp OR 'observer variation' AND ([embase]/lim OR [embase classic]/lim) | 45,019
#15 | 'sensitivity and specificity'/exp OR 'sensitivity and specificity' OR 'sensitivity':ti OR 'sensitivity':ab OR 'analytic validity' AND ([embase]/lim OR [embase classic]/lim) | 532,369
#16 | 'diagnostic errors'/exp OR 'diagnostic errors' OR 'diagnosis':ti OR 'diagnosis':ab OR 'diagnostic accuracy'/exp OR 'diagnostic accuracy' OR 'precision'/exp OR 'precision' AND ([embase]/lim OR [embase classic]/lim) | 1,314,969
#17 | 'probability'/exp OR probability OR likelihood OR 'false negative reactions'/exp OR 'false negative reactions' OR 'false positive reactions'/exp OR 'false positive reactions' OR 'predictive value of tests'/exp OR 'predictive value of tests' OR 'forecasting'/exp OR forecasting AND ([embase]/lim OR [embase classic]/lim) | 809,717
#18 | #12 OR #13 OR #14 OR #15 OR #16 OR #17 | 2,381,955
#19 | #4 AND (#10 OR #18) | 142
#20 | #19 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1980–2012]/py | 32
Breast Cancer Search
#1 | 'breast cancer'/exp AND ([embase]/lim OR [embase classic]/lim) | 250,650
#2 | 'oncotype dx' OR '21 gene recurrence score' OR '21 gene recurrence' AND ([embase]/lim OR [embase classic]/lim) | 404
#3 | 'mammaprint' OR '70 gene signature' AND ([embase]/lim OR [embase classic]/lim) | 251
#4 | ivdmia OR 'in vitro diagnostic multivariate index assay' AND ([embase]/lim OR [embase classic]/lim) | 11
#5 | #2 OR #3 OR #4 | 562
#6 | #1 AND #5 | 520
#7 | 'biological assay'/exp AND ([embase]/lim OR [embase classic]/lim) | 27,957
#8 | 'predictive value of tests'/exp AND ([embase]/lim OR [embase classic]/lim) | 20,904
#9 | 'proportional hazards models'/exp AND ([embase]/lim OR [embase classic]/lim) | 24,333
#10 | 'treatment outcome'/exp AND ([embase]/lim OR [embase classic]/lim) | 701,175
#11 | 'assay' OR 'assay'/exp OR assay OR assays OR test OR tests AND ([embase]/lim OR [embase classic]/lim) | 2,964,565
#12 | #7 OR #8 OR #9 OR #10 OR #11 | 3,558,292
#13 | #6 AND #12 | 386
#14 | 'reproducibility of results'/exp OR 'reproducibility of results' AND ([embase]/lim OR [embase classic]/lim) | 55,807
#15 | 'signal-to-noise ratio'/exp OR 'signal-to-noise ratio' AND ([embase]/lim OR [embase classic]/lim) | 22,980
#16 | 'roc curve'/exp OR 'roc curve' OR 'receiver operating characteristic'/exp OR 'receiver operating characteristic' OR 'observer variation'/exp OR 'observer variation' AND ([embase]/lim OR [embase classic]/lim) | 45,053
#17 | 'sensitivity and specificity'/exp OR 'sensitivity and specificity' OR 'sensitivity':ti OR 'sensitivity':ab OR 'analytic validity' AND ([embase]/lim OR [embase classic]/lim) | 532,590
#18 | 'diagnostic errors'/exp OR 'diagnostic errors' OR 'diagnosis':ti OR 'diagnosis':ab OR 'diagnostic accuracy'/exp OR 'diagnostic accuracy' OR 'precision'/exp OR 'precision' AND ([embase]/lim OR [embase classic]/lim) | 1,315,423
#19 | 'probability' OR 'probability'/exp OR probability OR likelihood OR 'false negative reactions'/exp OR 'false negative reactions' OR 'false positive reactions'/exp OR 'false positive reactions' OR 'predictive value of tests'/exp OR 'predictive value of tests' OR 'forecasting' OR 'forecasting'/exp OR forecasting AND ([embase]/lim OR [embase classic]/lim) | 810,061
#20 | #14 OR #15 OR #16 OR #17 OR #18 OR #19 | 2,382,853
#21 | #6 AND (#12 OR #20) | 480
#22 | #21 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1980–2012]/py | 82
Colorectal Cancer Search
#1 | 'colorectal cancer'/exp AND ([embase]/lim OR [embase classic]/lim) | 64,587
#2 | 'microsatellite instability'/exp OR 'microsatellite instability' AND ([embase]/lim OR [embase classic]/lim) | 7,045
#3 | mlh1 AND ('promoter'/exp OR promoter) AND ('methylation'/exp OR methylation) AND ([embase]/lim OR [embase classic]/lim) | 703
#4 | kras AND ([embase]/lim OR [embase classic]/lim) | 4,869
#5 | braf AND ([embase]/lim OR [embase classic]/lim) | 4,411
#6 | 'oncotype dx colon' OR '21 gene recurrence score' OR '21 gene recurrence' AND ([embase]/lim OR [embase classic]/lim) | 86
#7 | ivdmia OR 'in vitro diagnostic multivariate index assay' AND ([embase]/lim OR [embase classic]/lim) | 11
#8 | #2 OR #3 OR #4 OR #5 OR #6 OR #7 | 14,748
#9 | #1 AND #8 | 4,149
#10 | 'biological assay'/exp AND ([embase]/lim OR [embase classic]/lim) | 27,957
#11 | 'predictive value of tests'/exp AND ([embase]/lim OR [embase classic]/lim) | 20,904
#12 | 'proportional hazards models'/exp AND ([embase]/lim OR [embase classic]/lim) | 24,333
#13 | 'treatment outcome'/exp AND ([embase]/lim OR [embase classic]/lim) | 701,175
#14 | 'assay' OR 'assay'/exp OR assay OR assays OR test OR tests AND ([embase]/lim OR [embase classic]/lim) | 2,964,565
#15 | #10 OR #11 OR #12 OR #13 OR #14 | 3,558,292
#16 | #9 AND #15 | 1,190
#17 | 'reproducibility of results'/exp OR 'reproducibility of results' AND ([embase]/lim OR [embase classic]/lim) | 55,807
#18 | 'signal-to-noise ratio'/exp OR 'signal-to-noise ratio' AND ([embase]/lim OR [embase classic]/lim) | 22,980
#19 | 'roc curve'/exp OR 'roc curve' OR 'receiver operating characteristic'/exp OR 'receiver operating characteristic' OR 'observer variation'/exp OR 'observer variation' AND ([embase]/lim OR [embase classic]/lim) | 45,053
#20 | 'sensitivity and specificity'/exp OR 'sensitivity and specificity' OR 'sensitivity':ti OR 'sensitivity':ab OR 'analytic validity' AND ([embase]/lim OR [embase classic]/lim) | 532,590
#21 | 'diagnostic errors'/exp OR 'diagnostic errors' OR 'diagnosis':ti OR 'diagnosis':ab OR 'diagnostic accuracy'/exp OR 'diagnostic accuracy' OR 'precision'/exp OR 'precision' AND ([embase]/lim OR [embase classic]/lim) | 1,315,423
#22 | 'probability' OR 'probability'/exp OR probability OR likelihood OR 'false negative reactions'/exp OR 'false negative reactions' OR 'false positive reactions'/exp OR 'false positive reactions' OR 'predictive value of tests'/exp OR 'predictive value of tests' OR 'forecasting' OR 'forecasting'/exp OR forecasting AND ([embase]/lim OR [embase classic]/lim) | 810,061
#23 | #17 OR #18 OR #19 OR #20 OR #21 OR #22 | 2,382,853
#24 | #9 AND (#15 OR #23) | 2,184
#25 | #24 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1980–2012]/py | 605
Lung Cancer Search
#1 | 'lung cancer'/exp AND ([embase]/lim OR [embase classic]/lim) | 176,206
#2 | 'lung carcinoma'/exp AND ([embase]/lim OR [embase classic]/lim) | 90,226
#3 | #1 OR #2 | 176,206
#4 | 'eml4-alk' AND ([embase]/lim OR [embase classic]/lim) | 337
#5 | alk AND ([embase]/lim OR [embase classic]/lim) | 4,992
#6 | egfr AND ([embase]/lim OR [embase classic]/lim) | 30,017
#7 | kras AND ([embase]/lim OR [embase classic]/lim) | 4,869
#8 | ivdmia OR 'in vitro diagnostic multivariate index assay' AND ([embase]/lim OR [embase classic]/lim) | 11
#9 | #4 OR #5 OR #6 OR #7 OR #8 | 37,784
#10 | #3 AND #9 | 6,492
#11 | 'biological assay'/exp AND ([embase]/lim OR [embase classic]/lim) | 27,957
#12 | 'predictive value of tests'/exp AND ([embase]/lim OR [embase classic]/lim) | 20,904
#13 | 'proportional hazards models'/exp AND ([embase]/lim OR [embase classic]/lim) | 24,333
#14 | 'treatment outcome'/exp AND ([embase]/lim OR [embase classic]/lim) | 701,175
#15 | 'assay' OR 'assay'/exp OR assay OR assays OR test OR tests AND ([embase]/lim OR [embase classic]/lim) | 2,964,565
#16 | #11 OR #12 OR #13 OR #14 OR #15 | 3,558,292
#17 | #10 AND #16 | 2,150
#18 | 'reproducibility of results'/exp OR 'reproducibility of results' AND ([embase]/lim OR [embase classic]/lim) | 55,807
#19 | 'signal-to-noise ratio'/exp OR 'signal-to-noise ratio' AND ([embase]/lim OR [embase classic]/lim) | 22,980
#20 | 'roc curve'/exp OR 'roc curve' OR 'receiver operating characteristic'/exp OR 'receiver operating characteristic' OR 'observer variation'/exp OR 'observer variation' AND ([embase]/lim OR [embase classic]/lim) | 45,053
#21 | 'sensitivity and specificity'/exp OR 'sensitivity and specificity' OR 'sensitivity':ti OR 'sensitivity':ab OR 'analytic validity' AND ([embase]/lim OR [embase classic]/lim) | 532,590
#22 | 'diagnostic errors'/exp OR 'diagnostic errors' OR 'diagnosis':ti OR 'diagnosis':ab OR 'diagnostic accuracy'/exp OR 'diagnostic accuracy' OR 'precision'/exp OR 'precision' AND ([embase]/lim OR [embase classic]/lim) | 1,315,423
#23 | 'probability' OR 'probability'/exp OR probability OR likelihood OR 'false negative reactions'/exp OR 'false negative reactions' OR 'false positive reactions'/exp OR 'false positive reactions' OR 'predictive value of tests'/exp OR 'predictive value of tests' OR 'forecasting' OR 'forecasting'/exp OR forecasting AND ([embase]/lim OR [embase classic]/lim) | 810,061
#24 | #18 OR #19 OR #20 OR #21 OR #22 OR #23 | 2,382,853
#25 | #10 AND (#16 OR #24) | 3,437
#26 | #25 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1980–2012]/py | 878

Table A6 Cochrane search strategies 10-29-2012

Search | Queries | Number of Citations
Urinary Bladder Cancer Search
#1 | MeSH descriptor: [Urinary Bladder Neoplasms] explode all trees | 919
#2 | urovysion | 2
#3 | ivdmia | 1
#4 | "in vitro multivariate index assay" | 0
#5 | #1 and (#2 or #3 or #4) | 2
#6 | MeSH descriptor: [Biological Assay] explode all trees | 152
#7 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5083
#8 | MeSH descriptor: [Proportional Hazards Models] explode all trees | 2827
#9 | MeSH descriptor: [Outcome and Process Assessment (Health Care)] explode all trees | 83811
#10 | assay | 11447
#11 | assays | 11447
#12 | test | 144378
#13 | tests | 144378
#14 | #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 | 215226
#15 | MeSH descriptor: [Reproducibility of Results] explode all trees | 8077
#16 | "reproducibility of results" | 8375
#17 | MeSH descriptor: [Signal-To-Noise Ratio] explode all trees | 0
#18 | "signal-to-noise ratio" | 145
#19 | MeSH descriptor: [ROC Curve] explode all trees | 851
#20 | "ROC Curve" | 1113
#21 | "receiver operating characteristic" | 1107
#22 | MeSH descriptor: [Observer Variation] explode all trees | 1556
#23 | “observer variation” | 2444
#24 | MeSH descriptor: [Sensitivity and Specificity] explode all trees | 13656
#25 | sensitivity:ti (Word variations have been searched) | 2714
#26 | sensitivity:ab (Word variations have been searched) | 15456
#27 | "sensitivity and specificity" | 11058
#28 | “analytic validity” | 1481
#29 | MeSH descriptor: [Diagnostic Errors] explode all trees | 2362
#30 | diagnos*:ti,ab | 34133
#31 | MeSH descriptor: [Diagnosis] this term only | 79
#32 | MeSH descriptor: [Diagnosis, Differential] this term only | 1338
#33 | Any MeSH descriptor with qualifier(s): [Diagnosis - DI] | 33493
#34 | accuracy | 9811
#35 | MeSH descriptor: [Diagnosis] explode all trees | 221504
#36 | diagnostic accuracy | 4126
#37 | precision | 2746
#38 | "diagnostic error*" | 288
#39 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5083
#40 | MeSH descriptor: [Probability] explode all trees | 31596
#41 | probability | 11646
#42 | likelihood | 6058
#43 | MeSH descriptor: [False Negative Reactions] explode all trees | 314
#44 | MeSH descriptor: [False Positive Reactions] explode all trees | 470
#45 | "predictive value of test*" | 5202
#46 | forecasting | 588
#47 | MeSH descriptor: [Forecasting] explode all trees | 423
#48 | #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 or #46 or #47 | 275562
#49 | #5 and (#14 or #48) | 2
#50 | #5 and (#14 or #48) from 1980 | 2
Breast Cancer Search
#1 | MeSH descriptor: [Breast Neoplasms] explode all trees | 7522
#2 | "oncotype DX" | 10
#3 | "21 gene recurrence score" | 6
#4 | "21 gene recurrence" | 6
#5 | Mammaprint | 8
#6 | "70 gene signature" | 3
#7 | ivdmia | 1
#8 | "in vitro multivariate index assay" | 0
#9 | #1 AND (#2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8) | 21
#10 | MeSH descriptor: [Biological Assay] explode all trees | 152
#11 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5083
#12 | MeSH descriptor: [Proportional Hazards Models] explode all trees | 2827
#13 | MeSH descriptor: [Outcome and Process Assessment (Health Care)] explode all trees | 83811
#14 | assay | 11447
#15 | assays | 11447
#16 | test | 144378
#17 | tests | 144378
#18 | #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 | 215226
#19 | MeSH descriptor: [Reproducibility of Results] explode all trees | 8077
#20 | "reproducibility of results" | 8375
#21 | MeSH descriptor: [Signal-To-Noise Ratio] explode all trees | 0
#22 | "signal-to-noise ratio" | 145
#23 | MeSH descriptor: [ROC Curve] explode all trees | 851
#24 | "ROC Curve" | 1113
#25 | "receiver operating characteristic" | 1107
#26 | MeSH descriptor: [Observer Variation] explode all trees | 1556
#27 | “observer variation” | 2444
#28 | MeSH descriptor: [Sensitivity and Specificity] explode all trees | 13656
#29 | sensitivity:ti (Word variations have been searched) | 2714
#30 | sensitivity:ab (Word variations have been searched) | 15456
#31 | "sensitivity and specificity" | 11058
#32 | “analytic validity” | 1481
#33 | MeSH descriptor: [Diagnostic Errors] explode all trees | 2362
#34 | diagnos*:ti,ab | 34133
#35 | MeSH descriptor: [Diagnosis] this term only | 79
#36 | MeSH descriptor: [Diagnosis, Differential] this term only | 1338
#37 | Any MeSH descriptor with qualifier(s): [Diagnosis - DI] | 33493
#38 | accuracy | 9811
#39 | MeSH descriptor: [Diagnosis] explode all trees | 221504
#40 | diagnostic accuracy | 4126
#41 | precision | 2746
#42 | "diagnostic error*" | 288
#43 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5083
#44 | MeSH descriptor: [Probability] explode all trees | 31596
#45 | probability | 11646
#46 | likelihood | 6058
#47 | MeSH descriptor: [False Negative Reactions] explode all trees | 314
#48 | MeSH descriptor: [False Positive Reactions] explode all trees | 470
#49 | "predictive value of test*" | 5202
#50 | forecasting | 588
#51 | MeSH descriptor: [Forecasting] explode all trees | 423
#52 | #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 or #46 or #47 or #48 or #49 or #50 or #51 | 275562
#53 | #9 and (#18 or #52) | 20
#54 | #9 and (#18 or #52) from 1980 | 20
Colorectal Cancer Search
#1 | MeSH descriptor: [Colorectal Neoplasms] explode all trees | 4390
#2 | MeSH descriptor: [Microsatellite Instability] explode all trees | 21
#3 | "Microsatellite Instability" | 54
#4 | MLH1 promoter methylation | 2
#5 | KRAS protein, human | 58
#6 | KRAS | 93
#7 | BRAF protein, human | 27
#8 | "Oncotype DX Colon" | 0
#9 | "21 gene recurrence score" | 6
#10 | "21 gene recurrence" | 6
#11 | ivdmia | 1
#12 | "in vitro multivariate index assay" | 0
#13 | #1 and (#2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12) | 87
#14 | MeSH descriptor: [Biological Assay] explode all trees | 152
#15 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5083
#16 | MeSH descriptor: [Proportional Hazards Models] explode all trees | 2827
#17 | MeSH descriptor: [Outcome and Process Assessment (Health Care)] explode all trees | 83811
#18 | assay | 11447
#19 | assays | 11447
#20 | test | 144378
#21 | tests | 144378
#22 | #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 | 215226
#23 | MeSH descriptor: [Reproducibility of Results] explode all trees | 8077
#24 | "reproducibility of results" | 8375
#25 | MeSH descriptor: [Signal-To-Noise Ratio] explode all trees | 0
#26 | "signal-to-noise ratio" | 145
#27 | MeSH descriptor: [ROC Curve] explode all trees | 851
#28 | "ROC Curve" | 1113
#29 | "receiver operating characteristic" | 1107
#30 | MeSH descriptor: [Observer Variation] explode all trees | 1556
#31 | “observer variation” | 2444
#32 | MeSH descriptor: [Sensitivity and Specificity] explode all trees | 13656
#33 | sensitivity:ti (Word variations have been searched) | 2714
#34 | sensitivity:ab (Word variations have been searched) | 15456
#35 | "sensitivity and specificity" | 11058
#36 | “analytic validity” | 1481
#37 | MeSH descriptor: [Diagnostic Errors] explode all trees | 2362
#38 | diagnos*:ti,ab | 34133
#39 | MeSH descriptor: [Diagnosis] this term only | 79
#40 | MeSH descriptor: [Diagnosis, Differential] this term only | 1338
#41 | Any MeSH descriptor with qualifier(s): [Diagnosis - DI] | 33493
#42 | accuracy | 9811
#43 | MeSH descriptor: [Diagnosis] explode all trees | 221504
#44 | diagnostic accuracy | 4126
#45 | precision | 2746
#46 | "diagnostic error*" | 288
#47 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5083
#48 | MeSH descriptor: [Probability] explode all trees | 31596
#49 | probability | 11646
#50 | likelihood | 6058
#51 | MeSH descriptor: [False Negative Reactions] explode all trees | 314
#52 | MeSH descriptor: [False Positive Reactions] explode all trees | 470
#53 | "predictive value of test*" | 5202
#54 | forecasting | 588
#55 | MeSH descriptor: [Forecasting] explode all trees | 423
#56 | #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 or #46 or #47 or #48 or #49 or #50 or #51 or #52 or #53 or #54 or #55 | 275562
#57 | #13 and (#22 or #56) | 71
#58 | #13 and (#22 or #56) from 1980 | 71
Lung Cancer Search
#1 | MeSH descriptor: [Lung Neoplasms] explode all trees | 4189
#2 | MeSH descriptor: [Carcinoma, Bronchogenic] explode all trees | 2159
#3 | #1 or #2 | 4189
#4 | EML4-ALK fusion protein, human | 0
#5 | ALK | 115
#6 | EGFR protein, human | 177
#7 | EGFR | 526
#8 | KRAS protein, human | 58
#9 | KRAS | 93
#10 | ivdmia | 1
#11 | "in vitro multivariate index assay" | 0
#12 | #3 and (#4 or #5 or #6 or #8 or #9 or #10 or #11) | 56
#13 | MeSH descriptor: [Biological Assay] explode all trees | 152
#14 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5083
#15 | MeSH descriptor: [Proportional Hazards Models] explode all trees | 2827
#16 | MeSH descriptor: [Outcome and Process Assessment (Health Care)] explode all trees | 83811
#17 | assay | 11447
#18 | assays | 11447
#19 | test | 144378
#20 | tests | 144378
#21 | #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 | 215226
#22 | MeSH descriptor: [Reproducibility of Results] explode all trees | 8077
#23 | "reproducibility of results" | 8375
#24 | MeSH descriptor: [Signal-To-Noise Ratio] explode all trees | 0
#25 | "signal-to-noise ratio" | 145
#26 | MeSH descriptor: [ROC Curve] explode all trees | 851
#27 | "ROC Curve" | 1113
#28 | "receiver operating characteristic" | 1107
#29 | MeSH descriptor: [Observer Variation] explode all trees | 1556
#30 | “observer variation” | 2444
#31 | MeSH descriptor: [Sensitivity and Specificity] explode all trees | 13656
#32 | sensitivity:ti (Word variations have been searched) | 2714
#33 | sensitivity:ab (Word variations have been searched) | 15456
#34 | "sensitivity and specificity" | 11058
#35 | “analytic validity” | 1481
#36 | MeSH descriptor: [Diagnostic Errors] explode all trees | 2362
#37 | diagnos*:ti,ab | 34133
#38 | MeSH descriptor: [Diagnosis] this term only | 79
#39 | MeSH descriptor: [Diagnosis, Differential] this term only | 1338
#40 | Any MeSH descriptor with qualifier(s): [Diagnosis - DI] | 33493
#41 | accuracy | 9811
#42 | MeSH descriptor: [Diagnosis] explode all trees | 221504
#43 | diagnostic accuracy | 4126
#44 | precision | 2746
#45 | "diagnostic error*" | 288
#46 | MeSH descriptor: [Predictive Value of Tests] explode all trees | 5083
#47 | MeSH descriptor: [Probability] explode all trees | 31596
#48 | probability | 11646
#49 | likelihood | 6058
#50 | MeSH descriptor: [False Negative Reactions] explode all trees | 314
#51 | MeSH descriptor: [False Positive Reactions] explode all trees | 470
#52 | "predictive value of test*" | 5202
#53 | forecasting | 588
#54 | MeSH descriptor: [Forecasting] explode all trees | 423
#55 | #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 or #46 or #47 or #48 or #49 or #50 or #51 or #52 or #53 or #54 | 275562
#56 | #12 and (#21 or #55) | 44
#57 | #12 and (#21 or #55) from 1980 | 44