# Executive Summary

## Background

Molecular pathology tests that identify pathogenic mutations and cytogenetic translocations help us define the molecular subtypes of common cancers. Because several of these acquired mutations/translocations may predict response to specific therapies, screening tests for “targetable” mutations are now commonly available in clinical laboratory improvement amendments (CLIA)-approved clinical labs. It is unclear whether these test results can also serve as independent prognostic factors. This review aims to clarify the value of certain molecular pathology tests for improving our estimates of prognosis for common cancers (breast, lung, colon, urinary bladder) affecting Medicare beneficiaries. The main purpose of this review is to determine whether these tests improve estimation of prognosis (for recurrence), affect physician decision making, and/or improve clinical outcomes when compared with traditional assessment of prognosis of recurrence. These genetic tests are used in two different contexts. In one, the tests are used in a specific context of a diagnostic/therapy combination, where the diagnostic test is being used to predict response to a very specific treatment. In the second context, the genetic tests are used to estimate the patient’s prognosis, and physicians use this prognostic information to choose from a variety of different treatment options. CMS requested this report to evaluate the second context. Therefore, studies that evaluate specific diagnostic/therapy combinations are excluded from this report

The following tests are under consideration for this assessment and apply to all Key Questions (KQs): microsatellite instability (MSI) for colorectal cancer (CRC), MLH1 promoter methylation for CRC, KRAS mutations for CRC, BRAF mutations for CRC, Oncotype DX Colon mRNA expression for CRC, Oncotype DX Breast mRNA expression for breast cancer, MammaPrint mRNA expression for breast cancer, ALK cytogenetics for lung cancer, EGFR mutations for lung cancer, KRAS mutations for lung cancer, and UroVysion cytogenetics for urinary bladder cancer.

Our overarching question was whether there is direct evidence that the addition of the results of these molecular pathology tests to traditional prognostic factors changed physician decisionmaking and improved clinical outcomes for adult patients. We also examined analytic validity, clinical validity and utility, and any harms to patients associated with these tests. In this review, we address the following KQs:

- KQ 1. Overarching Question: Is there direct evidence that the addition of the specified molecular pathology tests used alone or in combination with traditional prognostic factors changes physician decisionmaking and improves outcomes for adult patients with CRC, breast, lung, or bladder cancer compared with the use of traditional factors to predict risk of recurrence (RR) for adults with these cancers?
- KQ 2. Analytic Validity: Does existing evidence establish the technical accuracy and reliability of these tests for detecting the relevant molecular analytes?
- KQ 3. Clinical Validity: Does existing evidence establish the prognostic accuracy of the tests for predicting recurrence?
- KQ 4. Clinical Utility: Does existing evidence support clinical utility of the molecular pathology tests?
- KQ 4a. What is the evidence that the prognostic information provided by the molecular pathology tests modifies physician decisions regarding use of adjuvant antineoplastic chemo- and/or radiotherapy, enhanced diagnostic testing for recurrence, and/or surgery among adult patients with malignant tumors?
- KQ 4b. What is the evidence that modified decisions lead to improved outcomes, including patient-centered outcomes such as improved quality of life, reduced disease recurrence, increased overall survival (OS) or disease-free survival (DFS), or reduced therapeutic side effects?
- KQ 5. What are the harms associated with treatment decisions that are informed by the molecular pathology tests?

### Analytic Framework

We developed an analytic framework to guide the systematic review process (Figure A).

Figure A Analytic framework

Abbreviation: KQ = Key Question.

Figure A is titled Analytic framework. The framework starts on the left with s square indicating the population of interest: Adults with colorectal, breast, lung, or urinary bladder tumors. A straight line with an arrow labeled KQ 2 extends to the right pointing to a box with rounded corners labeled "Genetic marker." Moving straight across to the right, another line with an arrow labeled KQ 3 points to a box with rounded corners labeled "Predicted risk of recurrence/prognosis." Next is a line with an arrow labeled KQ 4a pointing to a box with rounded corners labeled "Treatment decisions." From here, another line with an arrow is labeled KQ 4b and it points to a square that lists health outcomes: recurrence, survival, and quality of life. Extending down from the line labeled KQ 4b is a curved line labeled KQ 5 pointing to a circle representing harms of treatment decisions. On the top of the figure, a line extends from the KQ 2 arrow on the left to the "Health Outcomes" box on the far right. This line represents the overarching question, KQ 1.

## Methods

### Literature Search Strategy

We searched PubMed^®^, the Cochrane Library, and EMBASE^®^ for English-language, adult, and human-only studies published from inception through November 2013. Searches were run by an experienced Evidence-based Practice Center (EPC) librarian and were peer reviewed by another EPC librarian. We manually searched reference lists of pertinent review articles and studies meeting our inclusion criteria to look for any relevant citations that our searches might have missed. We searched for unpublished studies relevant to this review using test developers’ Web sites, ClinicalTrials.gov, the Food and Drug Administration Web site, Health Services Research Projects in Progress, and the European Union Clinical Trials Register. In addition, we requested information from the College of American Pathologists (CAP) and from relevant companies, asking for data that they believe should be considered for the review.

### Eligibility Criteria

We developed eligibility criteria for Populations, Interventions (i.e., tests for this report), Comparators, Outcomes, Timing, Settings (PICOTS), and study designs. Briefly, we included studies of adult patients with one of the cancer types of interest that evaluated an eligible molecular pathology test (listed in the Background). For KQs 1, 4, and 5, we included studies that compare at least 1 of the 11 molecular pathology tests plus standard prognostic factors with the standard prognostic factors alone to determine whether the molecular pathology test adds independent prognostic value (benefit) or introduces additional harms (KQ 5). Studies that compare an eligible molecular pathology test alone with standard prognostic factors were also eligible for inclusion. For KQ 2 (analytic validity), we included studies of test performance, including intra/interlab reproducibility. For KQ 3 (clinical validity), we included studies comparing patients with different test results (e.g., those with a mutation versus those who are wild-type) to establish prognostic value, with a multivariate analysis to adjust for known factors. To inform whether these molecular pathology tests add value above standard prognostic factors, we required that results were either adjusted for known prognostic factors or were specifically addressed in other ways, such as through inclusion/exclusion criteria of the study or stratification.

We required studies to report one of the following outcomes: for KQ 1, direct evidence of the impact of the test on physician decisionmaking and also on health outcomes (OS, DFS, time to recurrence, or quality of life); for KQ 2, tissue sample acceptance/rejection criteria, test performance, intra- and interlab reproducibility for the same specimen, lower limit of detection in admixtures of carcinoma and normal cells, and quality controls; for KQ 3, assessment of added prognostic value (i.e., by assessing discrimination, calibration, or association of test results with recurrence) beyond known independent prognostic factors for recurrence, cancer-specific survival (CSS), and overall survival (OS); for KQ 4a, modification of physician decisions about treatment; for KQ 4b, health outcomes (OS, DFS, time to recurrence, quality of life); and for KQ 5, adverse effects of tests, adverse effects of adjuvant therapy, and decreased quality of life.

We did not include studies focused on patients with advanced/metastatic cancer or studies focused on predicting response to treatments (e.g., studies focused on response to gefitinib for people with EGFR-mutant advanced lung adenocarcinomas). Progression-free survival was not an eligible outcome. Additional details of the eligibility criteria, including eligible study designs, are provided in the full technical report.

### Study Selection

Two members of the research team independently reviewed each title and abstract identified through searches for eligibility. Studies marked for possible inclusion by either reviewer and those that lacked adequate information to determine eligibility underwent a full-text review. Two members of the research team independently reviewed each full-text article to determine eligibility. If the reviewers disagreed, they resolved conflicts by discussion and consensus or by consulting a third member of the review team.

### Data Extraction

We designed and used structured data extraction forms to gather pertinent information from each article; this included characteristics of study populations, settings, interventions, comparators, study designs, methods, and results. Trained reviewers extracted the relevant data from each included article. All data extractions were reviewed for completeness and accuracy by a second member of the team.

### Risk-of-Bias Assessment of Individual Studies

We assessed the risk of bias (RoB) (internal validity) using an approach supported by the Methods Guide for Medical Test Reviews.1 For studies of analytic validity, we considered the potential for bias due to flaws in the sample selection, testing protocol, reference standards, verification procedures, interpretation, and analysis. We used the questions relevant for prognostic tests from the QUADAS-2^2,3^ (which was developed for diagnostic tests) for assessing risk of relevant biases. For studies of clinical validity and clinical utility, we assessed the potential for selection bias, confounding, performance bias, attrition bias, and detection bias. We assessed these biases using relevant questions and predefined criteria based on guidance from the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews and the RTI Question Bank.4 We rated RoB for each study as low, medium, high, or unclear. Two independent reviewers assessed the RoB for each study. Disagreements between the two reviewers were resolved by discussion and consensus or by a third member of the team.

### Data Synthesis

For clinical validity (KQ 3), we conducted meta-analyses using techniques described in Hedges and Vevea.4 We estimated summary hazard ratios (HRs) for outcomes (for any given test-cancer pair) with three or more independent adjusted HR estimates. We tested the null hypothesis of homogeneity of effect sizes across the studies4,5 for each of the outcomes. If the null hypothesis was rejected at a significance level of 0.05, the summary HR was estimated using a random effects model; if not, it was estimated using a fixed effects model. In both cases, the inverse of the variance was used to estimate a weighted summary HR.

For the other KQs, we did not find sufficient data to conduct meta-analyses. Therefore, we synthesized the information qualitatively, in tabular and narrative format.

We did not include studies with a high or unclear RoB in our main analyses/main data syntheses.

### Strength of the Body of Evidence

We graded the strength of evidence (SOE) as high, moderate, low, or insufficient based on the guidance established for the EPC Program.6,7 Developed to grade the overall strength of a body of evidence, this approach incorporates four key domains: RoB (includes study design and aggregate quality), consistency, directness, and precision of the evidence. It also considers other optional domains. For each test being evaluated in this review, two reviewers assessed each domain for each key outcome and determined an overall SOE grade based on domain ratings. In the event of disagreements on the domain or overall grade, they resolved differences by consensus discussion or by consulting with a third investigator.

We attempted to find studies that directly address the overarching question (KQ 1). If we did not find adequate direct evidence addressing the overarching question, we attempted to construct an indirect chain of evidence (using studies identified for the other KQs). We graded the SOE separately for analytic validity and for evidence on our overarching KQ. For analytic validity, we graded the SOE for the following: sensitivity and specificity, positive and negative predictive value, and intra/interlab reproducibility. For evidence on the overarching KQ, we graded the SOE for the following outcomes: RR, CSS, OS, and decisions about treatment.

### Applicability

We assessed applicability of the evidence following guidance from the Methods Guide for Comparative Effectiveness Reviews.5,8 We used the PICOTS framework to explore factors that affect applicability.

## Results

We included 112 publications reporting on tests of interest for the 4 cancers (Figure B).

Figure B Disposition of articles

Figure B is a PRISMA tree that documents the disposition of publications reviewed for this review. There were 5,445 citations identified from searches across the databases of PubMed, EMBASE, and Cochrane. Additionally, 1,107 publications were detected from manufacturers' clinical trials, manufacturers' published articles, manufacturers' unpublished documents, manufacturers' conference proceedings, clinical trials.gov website, HSR Proj Trials database, hand searches, and peer and public review comments. The total number of duplicates removed was 2,702. Of the total 3,850 abstracts screened, 2,022 citations were excluded. Working from 1,828 articles retrieved for full-text review, 1,716 were excluded at this stage. Of the studies excluded at the full-text review, 9 were excluded for a systematic review, 97 were excluded for wrong publication type, 235 were excluded for wrong population, 526 were excluded for wrong intervention, 155 were excluded for wrong or no comparator, 573 were excluded for wrong or no outcome, 97 were excluded for wrong study design, 18 were excluded for not applying to a key question, and 6 were excluded for not being able to retrieve the full-text article. The review included 112 publications.

We found no studies that directly addressed our overarching questions (KQ 1) (i.e., no study directly assessed the impact of a molecular pathology test result of interest on both physician decisionmaking and downstream health outcomes). We attempted to construct an indirect chain of evidence to answer the overarching question, but no studies addressed whether modified decisions lead to improved health outcomes (KQ 4b, clinical utility), so we were unable to do so. The furthest downstream evidence that we found addressed whether prognostic information provided by the molecular pathology tests modifies treatment decisions (KQ 4a).

The majority of studies meeting inclusion criteria for our review focused on clinical validity (KQ 3), and they evaluated associations between prognostic tests and outcomes. For two tests, MammaPrint and Oncotype DX Breast, we found studies rated as low or medium RoB addressing whether prognostic information provided by their mRNA abundance risk stratification tests modified treatment decisions (KQ 4a).

### Analytic Validity

Included studies provide some evidence regarding analytic validity (KQ 2) for all of the included tests. Data from included studies was supplemented with proficiency tests results provided by the College of American Pathologists (CAP) for five tests for which this data was available.

Data on intra- and interlab reproducibility is available in the primary literature and through national organization proficiency testing programs. Beau-Faller9 found high interlab reproducibility for EGFR and KRAS mutation testing. Cronin’s10 group at Genomic Health (Clin Chem 2007) found high intralab reproducibility for Oncotype quantitative RT-PCR mRNA abundance measurements relevant to the Oncotype DX tests for breast and colon carcinoma. The College of American Pathologists sends proficiency test unknowns to CLIA-approved US clinical laboratories or International clinical laboratories, an excellent mechanism for assessing nationwide interlab reproducibility. The three most recent surveys for each of these analytes showed average accuracy rates of 95 percent for EGFR (413/438), 98 percent for KRAS (602/612), 99 percent for BRAF (528/533), 99 percent for MSI (288/291), and 99 percent for UroVysion (552/555) (data presented are percentage of labs with correct results; and number with correct results/total number of labs that tested in parentheses).11–15

### Clinical Validity

Included studies provided some evidence on clinical validity for 9 of the included tests, adjusted for known prognostic factors (Table A). Evidence from multiple studies supports clinical validity, with added value beyond traditional prognostic factors, for MammaPrint, Oncotype DX Breast, KRAS mutation testing for lung cancer, BRAF mutation testing for CRC, KRAS mutation testing for CRC, and MSI for CRC for at least one of our included outcomes (i.e., RR, CSS, or OS). For UroVysion, limited evidence from 2 small studies (total N=168) rated as low or medium RoB supported prognostic value for RR. EGFR lung cancer did not add prognostic value to the traditional factors used to determine prognosis. For CRC, evidence did not adequately support added prognostic value for Oncotype DX Colon. The metric used to assess the clinical validity of the test for recurrence, CSS, or OS in all of these studies was the HR. HRs in this report range from 0.57 to 3.93. If the test is noninformative, we expect that the probability of experiencing the end point would be the same for either group, with an HR of 1. If the HR is greater than 1, the probability of the endpoint is higher in the group with the higher hazard. If the HR is lower than 1, the probability of experiencing the endpoint is lower in the group with the lower hazard. For example, an HR of 2 for CSS indicates that one group (e.g., those with high risk results for Oncotype DX Breast) has twice the rate per unit of time as the comparison group (e.g., those with low-risk test results).

Table A Summary of findings on clinical validity

Test: Cancer | Outcome | N studies; N subjects | Results Effect Size (95% CI) | Evidence from Multiple Studies Supports Association between Test Result and Prognosis?
MammaPrint: Breast | RR | 6; 1,913 | HR: 2.84 (2.11 to 3.89) for poor prognosis vs. good prognosis | Yes
MammaPrint: Breast | CSS | 5; 1,615 | HR: 3.3 (2.22 to 4.9) for poor prognosis vs. good prognosis | Yes
MammaPrint: Breast | OS | 1; 144 | HR: 1.67 (0.73 to 3.82) for poor prognosis vs. good prognosis | No
Oncotype DX Breast | RR | 6; 3,222 | HR: 2.97 (2.19 to 4.02) for high risk vs. low risk | Yes
Oncotype DX Breast | CSS | 2; 1,234 | HR: 2.02 (1.35 to 3.00) for high risk vs. low risk | Yes
Oncotype DX Breast | OS | 1; 668 | HR: 1.65 (1.24 to 2.19) for high risk vs. low risk | No, single study
EGFR: Lung | RR | 6; 1,870 | HR: 0.87 (0.65 to 1.15); No association | No
EGFR: Lung | CSS | 0; 0 | NA | No
EGFR: Lung | OS | 6; 1,820 | HR: 0.76 (0.50 to 1.19); No association | No
KRAS: Lung | RR | 4; 611 | 2.84 (1.14 to 7.1) KRAS: mutation associated with greater RR | Yes
KRAS: Lung | CSS | 0; 0 | NA | No
KRAS: Lung | OS | 2; 253 | 2.69 (1.91 to 3.8); 3.33 (1.03 to 10.82) | Yes^a^
BRAF: CRC | RR | 5; 4,106 | HR 1.07 (0.76 to 1.52) for wild-type vs. mutation | No
BRAF: CRC | CSS | 7; 5,409 | HR 1.50 (1.26 to 1.77) for wild-type vs. mutation | Yes
BRAF: CRC | OS | 11; 7,610 | HR 1.45 (1.29 to 1.62) for wild-type vs. mutation | Yes
KRAS: CRC | RR | 5; 4,085 | HR 1.02 (0.91 to 1.14) for wild-type vs. mutation | No
KRAS: CRC | CSS | 2; 1,174 | HR 1.30 (1.02 to 1.66) for wild-type vs. mutation | Yes
KRAS: CRC | OS | 10; 5,328 | HR 1.22 (0.93 to 1.60) for wild-type vs. mutation | No
MSI: CRC | RR | 10; 7,130 | HR 0.60 (0.50 to 0.72) for MSI-H vs. MSS | Yes
MSI: CRC | CSS | 6; 3,439 | HR 0.65 (0.51 to 0.82) for MSI-H vs. MSS | Yes
MSI: CRC | OS | 12; 8,839 | HR 0.57 (0.43 to 0.77) for MSI-H vs. MSS | Yes
Oncotype DX: CRC | RR | 1; 690 | HR 1.68 (1.18 to 2.38) | No, single study
Oncotype DX: CRC | CSS | 0; 0 | NA | No
Oncotype DX: CRC | OS | 0; 0 | NA | No
UroVysion: Bladder | RR | 2; 168 | Association between mutation and RR in 2 small studies | Yes, but limited to 168 subjects
UroVysion: Bladder | CSS | 0; 0 | NA | No
UroVysion: Bladder | OS | 0; 0 | NA | No

a Meta-analyses were conducted only when we had 3 or more HRs to combine

Notes: Table includes results of our main analyses that were based on studies rated as low or medium RoB. HRs reported are results of our meta-analyses of studies rated as low or medium RoB reporting adjusted associations for clinical validity (KQ 3).

Abbreviations: BRAF = gene name; CI = confidence interval; CRC = colorectal cancer; CSS = cancer-specific survival; EGFR = gene name; HR = hazard ratio; KRAS = gene name; MSI = microsatellite instability; MSI-H = microsatellite instability high; MSS = microsatellite stability: N = number; NA = not applicable; OS = overall survival; RR = risk of recurrence; vs. = versus.

### Clinical Utility and the Overarching Question

Table B summarizes the evidence on the overarching question, clinical utility, and the impact of test use on treatment decisions. Ultimately, we found insufficient SOE to answer the overarching question for most tests. Even in the cases where the tests seemed to add value in determining prognosis (i.e., evidence of clinical validity), we found no evidence that using the test was related to improved outcomes for patients. For a few tests, we found low SOE, suggesting that using the test would not improve outcomes for patients—for these tests we found evidence that did not support clinical validity (because with evidence suggesting lack of clinical validity, it is unlikely that the tests will be found to have clinical utility).

For impact on treatment decisions, we found moderate SOE that one test, Oncotype DX Breast, leads to changes in decisions. Although the decision changes were observed in both directions for individual patients, studies consistently showed an overall shift to less-intensive treatment recommendations as a result of using Oncotype DX Breast, with fewer recommendations for chemotherapy (and therefore less exposure to potential harms of chemotherapy; but studies did not follow patients to actually report on harms or to assess the overall balance of clinical benefits and harms). We found just one study of low or medium RoB for the impact of MammaPrint on treatment decisions, and we concluded that evidence was insufficient to determine the impact of MammaPrint on treatment decisions, primarily because of unknown consistency and imprecision.

Table B Summary of findings and strength of evidence for impact on treatment decisions, clinical utility, and our overarching question

Test: Cancer | Outcome | N studies; N subjects | Conclusions | Strength of Evidence
MammaPrint: Breast | RR | 6; 1,913 | All studies assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
MammaPrint: Breast | CSS | 5; 1,615 | All studies assessed clinical validity; no evidence that test use leads to improved CSS | Insufficient
MammaPrint: Breast | OS | 1; 144 | Study assessed clinical validity; no evidence that test use leads to improved mortality | Insufficient
MammaPrint: Breast | Decisions about Rx | 1; 427 | Adjuvant therapy was used less if the prognosis signature is used | Insufficient
Oncotype DX Breast | RR | 6; 3,222 | All studies assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
Oncotype DX Breast | CSS | 2; 1,234 | All studies assessed clinical validity; no evidence that test use leads to improved CSS | Insufficient
Oncotype DX Breast | OS | 1; 668 | All studies assessed clinical validity; no evidence that test use leads to improved mortality | Insufficient
Oncotype DX Breast | Decisions about Rx | 16; 2,251 | ~30% of treatment decisions changed by the test | Moderate
EGFR: Lung | RR | 6; 1,870 | All studies assessed clinical validity and found no prognostic value; test is unlikely to improve outcomes | Low
EGFR: Lung | CSS | 0; 0 | NA | Insufficient
EGFR: Lung | OS | 6;1,820 | No prognostic value; none of the reported HRs were statistically significant; test unlikely to improve mortality | Low
EGFR: Lung | Decisions about Rx | 0; 0 | NA | Insufficient
KRAS: Lung | RR | 4; 611 | All studies assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
KRAS: Lung | CSS | 0; 0 | NA | Insufficient
KRAS: Lung | OS | 2; 253 | Studies assessed clinical validity; no prognostic value; no evidence that test use leads to improved mortality | Insufficient
KRAS: Lung | Decisions about Rx | 0; 0 | NA | Insufficient
BRAF: CRC | RR | 5; 4,106 | All studies assessed clinical validity; no prognostic value; test is unlikely to improve outcomes | Low
BRAF: CRC | CSS | 7; 5,409 | All studies assessed clinical validity; no evidence that test use leads to improved CSS | Insufficient
BRAF: CRC | OS | 10; 7,610 | All studies assessed clinical validity; no evidence that test use leads to improved mortality | Insufficient
BRAF: CRC | Decisions about Rx | 0; 0 | NA | Insufficient
KRAS: CRC | RR | 5; 4,085 | All studies assessed clinical validity; no prognostic value; test is unlikely to improve outcomes | Low
KRAS: CRC | CSS | 2; 1,174 | All studies assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
KRAS: CRC | OS | 10; 5,328 | All studies assessed clinical validity; no prognostic value; test is unlikely to improve mortality | Low
KRAS: CRC | Decisions about Rx | 0; 0 | NA | Insufficient
MSI: CRC | RR | 10; 7,130 | All studies assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
MSI: CRC | CSS | 6; 3,439 | All studies assessed clinical validity; no evidence that test use leads to improved CSS | Insufficient
MSI: CRC | OS | 12; 8,839 | All studies assessed clinical validity; no evidence that test use leads to improved mortality | Insufficient
MSI: CRC | Decisions about Rx | 0; 0 | NA | Insufficient
Oncotype DX: CRC | RR | 1; 690 | Study assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
Oncotype DX: CRC | CSS | 0; 0 | NA | Insufficient
Oncotype DX: CRC | OS | 0; 0 | NA | Insufficient
Oncotype DX: CRC | Decisions about Rx | 0; 0 | NA | Insufficient
UroVysion: Bladder | RR | 2; 168 | Both studies assessed clinical validity; no evidence that test use leads to improved outcomes | Insufficient
UroVysion: Bladder | CSS | 0; 0 | NA | Insufficient
UroVysion: Bladder | OS | 0; 0 | NA | Insufficient
UroVysion: Bladder | Decisions about Rx | 0; 0 | NA | Insufficient

Abbreviations: BRAF = gene name; CRC = colorectal cancer; CSS = cancer-specific survival; EGFR = gene name; HR = hazard ratio; KRAS = gene name; MSI = microsatellite instability; N = number; NA = not applicable; OS = overall survival; RR = risk of recurrence; Rx = treatment.

## Discussion

Our review demonstrated that the weight of published research to date in the area of molecular pathology tests for improving estimates of prognosis has focused on the clinical validity of the tests of interest in giving information about prognosis and little emphasis on how these tests can be integrated into the overall care of cancer patients in terms of measuring changes in management decisions or the effect of those altered decisions on downstream outcomes of value to patients. Such changes in management may be occurring and may be of benefit, or possibly of harm, to patients, but they have not been measured and studied, with the notable exception of the Oncotype DX assay in breast cancer, which does have a sizeable body of evidence to suggest an effect on treatment decisions (resulting in fewer recommendations for chemotherapy), though not yet a clear effect on downstream outcomes.

At this point, physicians can, in many cases, rely on the prognostic value of molecular pathology tests, share test results with patients, and discuss whether the test result indicates a better- or worse-than-average prognosis. However, in most cases, physicians cannot be sure whether using this information will improve any clinical outcomes. Although having accurate information about prognosis may be valued by patients independent of its effects on survival and recurrence outcomes, this has yet to be demonstrated for the tests of interest.

## Limitations

Many of the included studies had methodological limitations, introducing some RoB. For example, most of them were observational studies assessing associations between test results and outcomes, and are susceptible to potential confounding. To limit such bias, we only included studies for KQ 3 that adjusted for most or all standard prognostic factors. Also, we assessed potential selection bias and confounding in our RoB assessments—limiting our main data syntheses to studies with low or medium RoB.

We were also not able to address the prognostic value of the tests for the Medicare population due to a lack of data that was specific to that age group. However, several studies included subjects from the Medicare agegroup and although there wre no analyses done specific to the agegroup, there was no evidence that suggested that the prognostic value of the tests would be different for this group.

## Future Research

We found no direct evidence of the impact of the information provided by these tests on downstream health outcomes such as patients’ quality of life or survival. Thus, future research should focus on quality of life, survival, and other health outcomes.

There is no information on the differential effects of the test by race or cancer subtype (e.g., ductal versus lobular in breast cancer) or location (e.g., proximal versus distal in CRC). As described in the results, the subpopulations that were represented in the studies varied in terms of stage, tumor type, and location in the case of CRC. Race and location have both been shown to be important predictors of the prognostic value of genetic markers in CRC.16,17 Similar differences in prognostic value by subpopulations could be a factor in terms of EGFR and KRAS in the lung. There is thus a need to create an evidence base that replicates results in the same subpopulations, particularly in CRC and lung cancer.

As in many studies in the oncology field, the published literature uses a variety of specific definitions for outcomes such as recurrence, distant recurrence, DFS, CSS, and OS, making comparison of effects across studies more difficult. Future research should take into account careful selection of the most appropriate endpoints, both in the context of the existing body of literature and the endpoints of most clinical relevance to doctors and patients.

## Conclusions

We found modest evidence supporting added prognostic value (i.e., clinical validity), beyond traditional prognostic factors, for MammaPrint; Oncotype DX Breast; KRAS mutation testing for lung; BRAF mutation testing for CRC; KRAS mutation testing for CRC; and MSI for CRC for RR, CSS, and/or OS. For UroVysion, which is marketed as a diagnostic (not prognostic) test, limited evidence supported an association between test result and prognosis for RR. For impact of test use on treatment decisions, we found moderate SOE that Oncotype DX Breast leads to changes in treatment decisions, resulting in fewer recommendations for chemotherapy.

We found no studies that directly assessed the impact of test use on downstream health outcomes to establish clinical utility. Even for the tests with good evidence supporting clinical validity, we found no evidence that using the test was related to improved outcomes for patients.

Many of the included tests are currently used to predict response to specific treatments, an aspect that was not evaluated in this report. Determining whether the tests have clinical utility for predicting therapeutic response is beyond the scope of this review.

## References

1 Rector TS, Taylor BC, Wilt TJ. Systematic review of prognostic tests. Chapter 12 of Methods Guide for Medical Test Reviews. AHRQ Publication No. 12-EHC017. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm. Also published in a special supplement to the Journal of General Internal Medicine, July 2012.
2 Whiting PF, Rutjes AW, Sterne J, et al. A quality assessment tool for diagnostic accuracy studies. Bristol, UK. University of Bristol. http://www.bris.ac.uk/quadas/resources/quadas2.pdf. Accessed September 12, 2013.
3 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. Oct. 18. 2011;155(8):529-536. [pmid: 22007046].
4 Hedges LV, Vevea JL. Fixed- and random-effects models in meta-analysis. Psychological Methods. 1998;3(4):486-504.
5 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
6 Norris S, Atkins D, Bruening W, et al. Selecting Observational Studies for Comparing Medical Interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
7 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-523. [pmid: 19595577].
8 Atkins D, Chang S, Gartlehner G, et al. Assessing the Applicability of Studies When Comparing Medical Interventions. Agency for Healthcare Research and Quality, Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No. 11-EHC019-EF. Rockville, MD. January. 2011. http://effectivehealthcare.ahrq.gov/.
9 Beau-Faller M, Degeorges A, Rolland E, et al. Cross-validation study for epidermal growth factor receptor and KRAS mutation detection in 74 blinded non-small cell lung carcinoma samples: a total of 5550 exons sequencedby 15 molecular French laboratories (evaluation of the EGFR mutation status for the administration of EGFR-TKIs in non-small cell lung carcinoma [ERMETIC] project-part 1). J Thorac Oncol. Jun. 2011;6(6):1006-1015. [pmid: 21532509].
10 Cronin M, Sangli C, Liu ML, et al. Analytical validation of the Oncotype DX genomic diagnostic test for recurrence prognosis and therapeutic response prediction in node-negative, estrogen receptor-positive breast cancer. Clin Chem. Jun. 2007;53(6):1084-1091. [pmid: 17463177].
11 CAP Molecular Oncology Committee. EGFR Educational Challenge Participant Summary Report. Surveys 2012 EGFR-B, 2013 EGFR-A, 2013 EGFR-B. Northfield, IL. College of American Pathologists. 2012. 2013.
12 CAP Molecular Oncology Committee. KRAS Educational Challenge Participant Summary Report. Surveys 2012 KRAS-B, 2013 KRAS-A, 2013 KRAS-B. Northfield, IL. College of American Pathologists. 2012. 2013.
13 CAP Molecular Oncology Committee. BRAF Educational Challenge Participant Summary Report. Surveys 2012 BRAF-B, 2013 BRAF-A, 2013 BRAF-B. Northfield, IL. College of American Pathologists. 2012. 2013.
14 CAP Molecular Oncology Committee. MSI Educational Challenge Participant Summary Report. Surveys 2012 MSI-B, 2013 MSI-A, 2013 MSI-B. Northfield, IL. College of American Pathologists. 2012. 2013.
15 CAP/ACMG Cytogenetics Resource Committee. FISH for Urothelial Carcinoma Educational Challenge Participant Summary Report. Surveys 2013 CYI-A, CYI-B, CYI-C. Northfield, IL. College of American Pathologists. 2013.
16 Katkoori VR, Jia X, Shanmugam C, et al. Prognostic significance of p53 codon72 polymorphism differs with race in colorectal adenocarcinoma. Clin Cancer Res. Apr. 1. 2009;15(7):2406-2416. [pmid: 19339276].
17 Marine U, Weiss HL, Myers RB, et al. Nuclear accumulation of p53 in colorectal adenocarcinoma: prognostic importance differs with race and location of the tumor. Cancer. Dec. 15. 1998;83(12):2456-2467. [pmid: 9874449].