# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Harry Burke, MD, PhD
  George Washington University
  Washington, DC
- Ned Calogne, MD
  Colorado Department of Public Health and Environment
  Denver, CO
- Roger Klein, MD, JD
  H. Lee Moffitt Cancer Center & Research Institute, University of South Florida College of Medicine
  Tampa, FL
- Marc S. Williams, MD
  Geisinger Health System, Genomic Medicine Institute
  Danville, PA