# References

1 Howlader N, Noone AM, Krapcho M, et al., editors. SEER Cancer Statistics Review, 1975-2009 (Vintage 2009 Populations). Bethesda, MD. National Cancer Institute. 2012.
2 Webster’s Encyclopedia Unabridged Dictionary of the English Language. New York. Portland House. 2001.
3 Rector TS, Taylor BC, Wilt TJ. Systematic review of prognostic tests. Chapter 12 of Methods Guide for Medical Test Reviews. AHRQ Publication No. 12-EHC017. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm. Also published in a special supplement to the Journal of General Internal Medicine, July 2012.
4 National Cancer Institute at the National Institutes of Health. Cancer Staging. Bethesda, MD. National Cancer Institute. www.cancer.gov/cancertopics/factsheet/detection/staging.
5 American Joint Committee on Cancer. Cancer Staging Manual. 7th ed. New York. Springer. 2010.
6 Carey LA, Perou CM, Livasy CA, et al. Race, breast cancer subtypes, and survival in the Carolina Breast Cancer Study. JAMA. Jun. 7. 2006;295(21):2492-2502. [pmid: 16757721].
7 Compton CC, Fielding LP, Burgart LJ, et al. Prognostic factors in colorectal cancer. College of American Pathologists Consensus Statement 1999. Arch Pathol Lab Med. Jul. 2000;124(7):979-994. [pmid: 10888773].
8 Sun LC, Chu KS, Cheng SC, et al. Preoperative serum carcinoembryonic antigen, albumin and age are supplementary to UICC staging systems in predicting survival for colorectal cancer patients undergoing surgical treatment. BMC Cancer. 2009;9:288. [pmid: 19691850].
9 Fitzgibbons PL, Page DL, Weaver D, et al. Prognostic factors in breast cancer. College of American Pathologists Consensus Statement 1999. Arch Pathol Lab Med. Jul. 2000;124(7):966-978. [pmid: 10888772].
10 Rakha EA, El-Sayed ME, Lee AH, et al. Prognostic significance of Nottingham histologic grade in invasive breast carcinoma. J Clin Oncol. Jul. 1. 2008;26(19):3153-3158. [pmid: 18490649].
11 Groome PA, Bolejack V, Crowley JJ, et al. The IASLC Lung Cancer Staging Project: validation of the proposals for revision of the T, N, and M descriptors and consequent stage groupings in the forthcoming (seventh) edition of the TNM classification of malignant tumours. J Thorac Oncol. Aug. 2007;2(8):694-705. [pmid: 17762335].
12 Sculier JP, Chansky K, Crowley JJ, et al. The impact of additional prognostic factors on survival and their relationship with the anatomical extent of disease expressed by the 6th edition of the TNM Classification of Malignant Tumors and the proposals for the 7th edition. J Thorac Oncol. May. 2008;3(5):457-466. [pmid: 18448996].
13 International Bladder Cancer Nomogram Consortium, Bochner BH, Kattan MW, et al. Postoperative nomogram predicting risk of recurrence after radical cystectomy for bladder cancer. J Clin Oncol. Aug. 20. 2006;24(24):3967-3972. [pmid: 16864855].
14 Shariat SF, Karakiewicz PI, Palapattu GS, et al. Nomograms provide improved accuracy for predicting survival after radical cystectomy. Clin Cancer Res. Nov. 15. 2006;12(22):6663-6676. [pmid: 17121885].
15 Iasonos A, Schrag D, Raj GV, et al. How to build and interpret a nomogram for cancer prognosis. J Clin Oncol. Mar. 10. 2008;26(8):1364-1370. [pmid: 18323559].
16 Newman TB, Kohn MA. Evidence-Based Diagnosis. New York. Cambridge University Press. 2009.
17 Lloyd-Jones DM. Cardiovascular risk prediction: basic concepts, current status, and future directions. Circulation. Apr. 20. 2010;121(15):1768-1777. [pmid: 20404268].
18 Pencina MJ, D'Agostino RB Sr, D'Agostino RB Jr, et al. Evaluating the added predictive ability of a new marker: from area under the ROC curve to reclassification and beyond. Stat Med. Jan. 30. 2008;27(2):157-172. discussion 207-12. [pmid: 17569110].
19 So HC, Sham PC. A unifying framework for evaluating the predictive power of genetic variants based on the level of heritability explained. PLoS Genet. 2010;6(12):e1001230. [pmid: 21151957].
20 Methods Guide for Medical Test Reviews. Agency for Healthcare Research and Quality. AHRQ Publication No. 12-EC017. Rockville, MD. June. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
21 Smetana GW, Umscheid CA, Chang S, et al. Methods guide for authors of systematic reviews of medical tests: A collaboration between the Agency for Healthcare Research and Quality (AHRQ) and the Journal of General Internal Medicine. J Gen Intern Med. Jun. Suppl 1. 2012;27:S1-S3. [pmid: 22648668].
22 Jonas DE, Wilt TJ, Taylor BC, et al. Chapter 11: Challenges in and principles for conducting systematic reviews of genetic tests used as predictive indicators. J Gen Intern Med. Jun. Suppl 1. 2012;27:S83-S93. PMID:ISI:000304661300012. [pmid: 22648679].
23 Jonas DE, Wilt TJ, Taylor BC, et al. Challenges in and principles for conducting systematic reviews of genetic tests used as predictive indicators. Agency for Healthcare Research and Quality AHRQ Publication No. 12-EHC083-EF. Rockville, MD. June. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
24 Whiting PF, Rutjes AW, Sterne J, et al. A quality assessment tool for diagnostic accuracy studies. Bristol, UK. University of Bristol. http://www.bris.ac.uk/quadas/resources/quadas2.pdf. Accessed September 12, 2013.
25 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. Oct. 18. 2011;155(8):529-536. [pmid: 22007046].
26 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. Feb. 2012;65(2):163-178. [pmid: 21959223].
27 Hedges LV, Vevea JL. Fixed- and random-effects models in meta-analysis. Psychological Methods. 1998;3(4):486-504.
28 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-1207. [pmid: 21463926].
29 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-523. [pmid: 19595577].
30 Norris S, Atkins D, Bruening W, et al. Selecting Observational Studies for Comparing Medical Interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
31 Atkins D, Chang S, Gartlehner G, et al. Assessing the Applicability of Studies When Comparing Medical Interventions. Agency for Healthcare Research and Quality, Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No. 11-EHC019-EF. Rockville, MD. January. 2011. http://effectivehealthcare.ahrq.gov/.
32 Abbott Molecular Division. Vysis ALK Break Apart FISH Probe Kit Information Package. March. 2013.
33 Lynch TJ, Bell DW, Sordella R, et al. Activating mutations in the epidermal growth factor receptor underlying responsiveness of non-small-cell lung cancer to gefitinib. N Engl J Med. May. 20. 2004;350(21):2129-2139. [pmid: 15118073].
34 Bando I, Cillero L, Sanz-Ortega J, et al. Study of KRAS new predictive marker in a clinical laboratory. Clin Transl Oncol. Dec. 2012;14(12):937-942. [pmid: 22865324].
35 Beau-Faller M, Degeorges A, Rolland E, et al. Cross-validation study for epidermal growth factor receptor and KRAS mutation detection in 74 blinded non-small cell lung carcinoma samples: a total of 5550 exons sequenced by 15 molecular French laboratories (evaluation of the EGFR mutation status for the administration of EGFR-TKIs in non-small cell lung carcinoma [ERMETIC] project--part 1). J Thorac Oncol. Jun. 2011;6(6):1006-1015. [pmid: 21532509].
36 Beau-Faller M, Legrain M, Voegeli AC, et al. Detection of K-Ras mutations in tumour samples of patients with non-small cell lung cancer using PNA-mediated PCR clamping. Br J Cancer. Mar. 24. 2009;100(6):985-992. [pmid: 19293811].
37 Clark-Langone KM, Sangli C, Krishnakumar J, et al. Translating tumor biology into personalized treatment planning: analytical performance characteristics of the Oncotype DX Colon Cancer Assay. BMC Cancer. 2010;10:691. [pmid: 21176237].
38 Cronin M, Sangli C, Liu ML, et al. Analytical validation of the Oncotype DX genomic diagnostic test for recurrence prognosis and therapeutic response prediction in node-negative, estrogen receptor-positive breast cancer. Clin Chem. Jun. 2007;53(6):1084-1091. [pmid: 17463177].
39 Delahaye LJM, Wehkamp D, Floore AN, et al. Performance characteristics of the MammaPrint®breast cancer diagnostic gene signature. Personalized Medicine. 2013;10(8):801-811.
40 Feigelson HS, Goddard KA, Johnson MA, et al. Reliability of KRAS mutation testing in metastatic colorectal cancer patients across five laboratories. BMC Res Notes. 2012;5:196. [pmid: 22534075].
41 Gao J, Li YY, Sun PN, et al. Comparative analysis of dideoxy sequencing, the KRAS StripAssay and pyrosequencing for detection of KRAS mutation. World J Gastroenterol. Oct. 14. 2010;16(38):4858-4864. [pmid: 20939116].
42 Gonzalez de Castro D, Angulo B, Gomez B, et al. A comparison of three methods for detecting KRAS mutations in formalin-fixed colorectal cancer specimens. Br J Cancer. Jul. 10. 2012;107(2):345-351. [pmid: 22713664].
43 Hancer VS, Buyukdogan M, Turkmen I, et al. Comparison of KRAS mutation tests in colorectal cancer patients. Genet Test Mol Biomarkers. Nov. 2011;15(11):831-834. [pmid: 21699410].
44 Jancik S, Drabek J, Berkovcova J, et al. A comparison of Direct sequencing, Pyrosequencing, High resolution melting analysis, TheraScreen DxS, and the K-ras StripAssay for detecting KRAS mutations in non small cell lung carcinomas. J Exp Clin Cancer Res. 2012;31:79. [pmid: 22995035].
45 Kobunai T, Watanabe T, Yamamoto Y, et al. The frequency of KRAS mutation detection in human colon carcinoma is influenced by the sensitivity of assay methodology: a comparison between direct sequencing and real-time PCR. Biochem Biophys Res Commun. Apr. 23. 2010;395(1):158-162. [pmid: 20361930].
46 Lopez-Rios F, Angulo B, Gomez B, et al. Comparison of molecular testing methods for the detection of EGFR mutations in formalin-fixed paraffin-embedded tissue specimens of non-small cell lung cancer. J Clin Pathol. May. 2013;66(5):381-385. [pmid: 23386666].
47 Mancini I, Santucci C, Sestini R, et al. The use of COLD-PCR and high-resolution melting analysis improves the limit of detection of KRAS and BRAF mutations in colorectal cancer. J Molec Diagnost. 2010;12(5):705-711.
48 Pang NK, Nga ME, Chin SY, et al. KRAS and BRAF mutation analysis can be reliably performed on aspirated cytological specimens of metastatic colorectal carcinoma. Cytopathology. Dec. 2011;22(6):358-364. [pmid: 21029218].
49 van 't Veer LJ, Dai H, van de Vijver MJ, et al. Gene expression profiling predicts clinical outcome of breast cancer. Nature. Jan. 31. 2002;415(6871):530-536. [pmid: 11823860].
50 Angulo B, Conde E, Suarez-Gauthier A, et al. A comparison of EGFR mutation testing methods in lung carcinoma: direct sequencing, real-time PCR and immunohistochemistry. PLoS One. 2012;7(8):e43842. [pmid: 22952784].
51 Naoki K, Soejima K, Okamoto H, et al. The PCR-invader method (structure-specific 5' nuclease-based method), a sensitive method for detecting EGFR gene mutations in lung cancer specimens; comparison with direct sequencing. Int J Clin Oncol. Aug. 2011;16(4):335-344. [pmid: 21311943].
52 Poulet B, Jamshidian F, Butler S, et al. Risk Classification of Early Stage Breast Cancer as Assessed by MammaPrint and Oncotype DX Genomic Assays. SABCS. 2012.
53 Sriram KB, Tan ME, Savarimuthu SM, et al. Screening for activating EGFR mutations in surgically resected nonsmall cell lung cancer. Eur Respir J. Oct. 2011;38(4):903-910. [pmid: 21349912].
54 CAP Molecular Oncology Committee. EGFR Educational Challenge Participant Summary Report. Surveys 2012 EGFR-B, 2013 EGFR-A, 2013 EGFR-B. Northfield, IL. College of American Pathologists. 2012. 2013.
55 CAP Molecular Oncology Committee. KRAS Educational Challenge Participant Summary Report. Surveys 2012 KRAS-B, 2013 KRAS-A, 2013 KRAS-B. Northfield, IL. College of American Pathologists. 2012. 2013.
56 CAP Molecular Oncology Committee. BRAF Educational Challenge Participant Summary Report. Surveys 2012 BRAF-B, 2013 BRAF-A, 2013 BRAF-B. Northfield, IL. College of American Pathologists. 2012. 2013.
57 CAP Molecular Oncology Committee. MSI Educational Challenge Participant Summary Report. Surveys 2012 MSI-B, 2013 MSI-A, 2013 MSI-B. Northfield, IL. College of American Pathologists. 2012. 2013.
58 CAP/ACMG Cytogenetics Resource Committee. FISH for Urothelial Carcinoma Educational Challenge Participant Summary Report. Surveys 2013 CYI-A, CYI-B, CYI-C. Northfield, IL. College of American Pathologists. 2013.
59 Bueno-de-Mesquita JM, Linn SC, Keijzer R, et al. Validation of 70-gene prognosis signature in node-negative breast cancer. Breast Cancer Res Treat. Oct. 2009;117(3):483-495. [pmid: 18819002].
60 Buyse M, Loi S, van't Veer L, et al. Validation and clinical utility of a 70-gene prognostic signature for women with node-negative breast cancer. J Natl Cancer Inst. Sep. 6. 2006;98(17):1183-1192. [pmid: 16954471].
61 Iwamoto T, Lee JS, Bianchini G, et al. First generation prognostic gene signatures for breast cancer predict both survival and chemotherapy sensitivity and identify overlapping patient populations. Breast Cancer Res Treat. Nov. 2011;130(1):155-164. [pmid: 21833625].
62 Knauer M, Cardoso F, Wesseling J, et al. Identification of a low-risk subgroup of HER-2-positive breast cancer by the 70-gene prognosis signature. Br J Cancer. Dec. 7. 2010;103(12):1788-1793. [pmid: 21081926].
63 Mook S, Schmidt MK, Viale G, et al. The 70-gene prognosis-signature predicts disease outcome in breast cancer patients with 1-3 positive lymph nodes in an independent validation study. Breast Cancer Res Treat. Jul. 2009;116(2):295-302. [pmid: 18661261].
64 Mook S, Knauer M, Bueno-De-Mesquita JM, et al. Metastatic potential of T1 breast cancer can be predicted by the 70-gene MammaPrint signature. Ann Surg Oncol. 2010;17(5):1406-1413. [pmid: 20094918].
65 Mook S, Schmidt MK, Weigelt B, et al. The 70-gene prognosis signature predicts early metastasis in breast cancer patients between 55 and 70 years of age. Ann Oncol. Apr. 2010;21(4):717-722. [pmid: 19825882].
66 Nuyten DSA, Hastie T, Chi JTA, et al. Combining biological gene expression signatures in predicting outcome in breast cancer: An alternative to supervised classification. Eur J Cancer. 2008;44(15):2319-2329. [pmid: 18715778].
67 van de Vijver MJ, He YD, van't Veer LJ, et al. A gene-expression signature as a predictor of survival in breast cancer. N Engl J Med. Dec. 19. 2002;347(25):1999-2009. [pmid: 12490681].
68 Saghatchian M, Mook S, Pruneri G, et al. Additional prognostic value of the 70-gene signature (MammaPrint((R))) among breast cancer patients with 4-9 positive lymph nodes. Breast. Oct. 2013;22(5):682-690. [pmid: 23347730].
69 Olivotto IA, Bajdik CD, Ravdin PM, et al. Population-based validation of the prognostic model ADJUVANT! for early breast cancer. J Clin Oncol. Apr. 20. 2005;23(12):2716-2725. [pmid: 15837986].
70 Dowsett M, Cuzick J, Wale C, et al. Prediction of risk of distant recurrence using the 21-gene recurrence score in node-negative and node-positive postmenopausal patients with breast cancer treated with anastrozole or tamoxifen: a TransATAC study. J Clin Oncol. Apr. 10. 2010;28(11):1829-1834. [pmid: 20212256].
71 Habel LA, Shak S, Jacobs MK, et al. A population-based study of tumor gene expression and risk of breast cancer death among lymph node-negative patients. Breast Cancer Res. 2006;8(3):R25. [pmid: 16737553].
72 Mamounas EP, Tang G, Fisher B, et al. Association between the 21-gene recurrence score assay and risk of locoregional recurrence in node-negative, estrogen receptor-positive breast cancer: results from NSABP B-14 and NSABP B-20. J Clin Oncol. Apr. 1. 2010;28(10):1677-1683. [pmid: 20065188].
73 Mamounas EP, Tang G, Paik S, et al. Abstract #1: Prognostic impact of the 21-gene recurrence score (RS) on disease-free and overall survival of node-positive, ER-positive breast cancer patients (pts) treated with adjuvant chemotherapy: Results from NSABP B-28. ASCO. 2012.
74 Paik S, Shak S, Tang G, et al. A multigene assay to predict recurrence of tamoxifen-treated, node-negative breast cancer. N Engl J Med. Dec. 30. 2004;351(27):2817-2826. [pmid: 15591335].
75 Solin LJ, Gray R, Goldstein LJ, et al. Prognostic value of biologic subtype and the 21-gene recurrence score relative to local recurrence after breast conservation treatment with radiation for early stage breast carcinoma: results from the Eastern Cooperative Oncology Group E2197 study. Breast Cancer Res Treat. Jul. 2012;134(2):683-692. [pmid: 22547108].
76 Tang G, Shak S, Paik S, et al. Comparison of the prognostic and predictive utilities of the 21-gene Recurrence Score assay and Adjuvant! for women with node-negative, ER-positive breast cancer: results from NSABP B-14 and NSABP B-20. Breast Cancer Res Treat. May. 2011;127(1):133-142. [pmid: 21221771].
77 Yorozuya K, Takeuchi T, Yoshida M, et al. Evaluation of Oncotype DX Recurrence Score as a prognostic factor in Japanese women with estrogen receptor-positive, node-negative primary Stage I or IIA breast cancer. J Cancer Res Clin Oncol. Jun. 2010;136(6):939-944. [pmid: 19946706].
78 An SJ, Chen ZH, Su J, et al. Identification of enriched driver gene alterations in subgroups of non-small cell lung cancer patients based on histology and smoking status. PLoS One. 2012;7(6).
79 Hiramatsu M, Ninomiya H, Inamura K, et al. Activation status of receptor tyrosine kinase downstream pathways in primary lung adenocarcinoma with reference of KRAS and EGFR mutations. Lung Cancer. Oct. 2010;70(1):94-102. [pmid: 20117855].
80 Kim YT, Kim TY, Lee DS, et al. Molecular changes of epidermal growth factor receptor (EGFR) and KRAS and their impact on the clinical outcomes in surgically resected adenocarcinoma of the lung. Lung Cancer. Jan. 2008;59(1):111-118. [pmid: 17904685].
81 Kobayashi N, Toyooka S, Ichimura K, et al. Non-BAC component but not epidermal growth factor receptor gene mutation is associated with poor outcomes in small adenocarcinoma of the lung. J Thorac Oncol. Jul. 2008;3(7):704-710. [pmid: 18594314].
82 Koh Y, Jang B, Han SW, et al. Expression of class III beta-tubulin correlates with unfavorable survival outcome in patients with resected non-small cell lung cancer. J Thorac Oncol. Mar. 2010;5(3):320-325. [pmid: 20087230].
83 Liu HP, Isaac Wu HD, Chang JW, et al. Prognostic implications of epidermal growth factor receptor and KRAS gene mutations and epidermal growth factor receptor gene copy numbers in patients with surgically resectable non-small cell lung cancer in Taiwan. J Thorac Oncol. Aug. 2010;5(8):1175-1184. [pmid: 20559151].
84 Mak RH, Doran E, Muzikansky A, et al. Outcomes after combined modality therapy for EGFR-mutant and wild-type locally advanced NSCLC. Oncologist. 2011;16(6):886-895. [pmid: 21632451].
85 Matsumoto S, Iwakawa R, Kohno T, et al. Frequent EGFR mutations in noninvasive bronchioloalveolar carcinoma. Int J Cancer. May. 15. 2006;118(10):2498-2504. [pmid: 16353158].
86 Rouquette I, Lauwers-Cances V, Allera C, et al. Characteristics of lung cancer in women: Importance of hormonal and growth factors. Lung Cancer. 2012;76(3):280-285. [pmid: 22197614].
87 Scoccianti C, Vesin A, Martel G, et al. Prognostic value of TP53, KRAS and EGFR mutations in nonsmall cell lung cancer: The EUELC cohort. Eur Respir J. 2012;40(1):177-184. [pmid: 22267755].
88 Kim YT, Seong YW, Jung YJ, et al. The presence of mutations in epidermal growth factor receptor gene is not a prognostic factor for long-term outcome after surgical resection of non-small-cell lung cancer. J Thorac Oncol. Feb. 2013;8(2):171-178. [pmid: 23287850].
89 Tsao MS, Sakurada A, Ding K, et al. Prognostic and predictive value of epidermal growth factor receptor tyrosine kinase domain mutation status and gene copy number for adjuvant chemotherapy in non-small cell lung cancer. J Thorac Oncol. 2011;6(1):139-147. [pmid: 21107284].
90 Woo T, Okudela K, Yazawa T, et al. Prognostic value of KRAS mutations and Ki-67 expression in stage I lung adenocarcinomas. Lung Cancer. Sep. 2009;65(3):355-362. [pmid: 19162366].
91 Guan JL, Zhong WZ, An SJ, et al. KRAS mutation in patients with lung cancer: a predictor for poor prognosis but not for EGFR-TKIs or chemotherapy. Ann Surg Oncol. Apr. 2013;20(4):1381-1388. [pmid: 23208128].
92 Farina-Sarasqueta A, van Lijnschoten G, Moerland E, et al. The BRAF V600E mutation is an independent prognostic factor for survival in stage II and stage III colon cancer patients. Ann Oncol. Dec. 2010;21(12):2396-2402. [pmid: 20501503].
93 Kakar S, Deng G, Sahai V, et al. Clinicopathologic characteristics, CpG island methylator phenotype, and BRAF mutations in microsatellite-stable colorectal cancers without chromosomal instability. Arch Pathol Lab Med. Jun. 2008;132(6):958-964. [pmid: 18517279].
94 Kalady MF, Dejulius KL, Sanchez JA, et al. BRAF mutations in colorectal cancer are associated with distinct clinical characteristics and worse prognosis. Dis Colon Rectum. Feb. 2012;55(2):128-133. [pmid: 22228154].
95 Liou JM, Wu MS, Shun CT, et al. Mutations in BRAF correlate with poor survival of colorectal cancers in Chinese population. Int J Colorectal Dis. Nov. 2011;26(11):1387-1395. [pmid: 21553007].
96 Maestro ML, Vidaurreta M, Sanz-Casla MT, et al. Role of the BRAF mutations in the microsatellite instability genetic pathway in sporadic colorectal cancer. Ann Surg Oncol. Mar. 2007;14(3):1229-1236. [pmid: 17195912].
97 Ogino S, Shima K, Meyerhardt JA, et al. Predictive and prognostic roles of BRAF mutation in stage III colon cancer: results from intergroup trial CALGB 89803. Clin Cancer Res. Feb. 1. 2012;18(3):890-900. [pmid: 22147942].
98 Pai RK, Jayachandran P, Koong AC, et al. BRAF-mutated, microsatellite-stable adenocarcinoma of the proximal colon: an aggressive adenocarcinoma with poor survival, mucinous differentiation, and adverse morphologic features. Am J Surg Pathol. May. 2012;36(5):744-752. [pmid: 22314188].
99 Phipps AI, Buchanan DD, Makar KW, et al. BRAF mutation status and survival after colorectal cancer diagnosis according to patient and tumor characteristics. Cancer Epidemiol Biomarkers Prev. Oct. 2012;21(10):1792-1798. [pmid: 22899730].
100 Roth AD, Tejpar S, Delorenzi M, et al. Prognostic role of KRAS and BRAF in stage II and III resected colon cancer: results of the translational study on the PETACC-3, EORTC 40993, SAKK 60-00 trial. J Clin Oncol. Jan. 20. 2010;28(3):466-474. [pmid: 20008640].
101 Samowitz WS, Sweeney C, Herrick J, et al. Poor survival associated with the BRAF V600E mutation in microsatellite-stable colon cancers. Cancer Res. Jul. 15. 2005;65(14):6063-6069. [pmid: 16024606].
102 Shaukat A, Arain M, Thaygarajan B, et al. Is BRAF mutation associated with interval colorectal cancers?. Dig Dis Sci. Aug. 2010;55(8):2352-2356. [pmid: 20300843].
103 Tie J, Gibbs P, Lipton L, et al. Optimizing targeted therapeutic development: analysis of a colorectal cancer patient population with the BRAF(V600E) mutation. Int J Cancer. May. 1. 2011;128(9):2075-2084. [pmid: 20635392].
104 Zlobec I, Bihl MP, Schwarb H, et al. Clinicopathological and protein characterization of BRAF- and K-RAS-mutated colorectal cancer and implications for prognosis. Int J Cancer. Jul. 15. 2010;127(2):367-380. [pmid: 19908233].
105 Lochhead P, Kuchiba A, Imamura Y, et al. Microsatellite instability and BRAF mutation testing in colorectal cancer prognostication. J Natl Cancer Inst. Aug. 7. 2013;105(15):1151-1156. [pmid: 23878352].
106 Samadder NJ, Vierkant RA, Tillmans LS, et al. Associations between colorectal cancer molecular markers and pathways with clinicopathologic features in older women. Gastroenterology. Aug. 2013;145(2):348-356. e1. e2. [pmid: 23665275].
107 Roth AD, Delorenzi M, Tejpar S, et al. Integrated analysis of molecular and clinical prognostic factors in stage II/III colon cancer. J Natl Cancer Inst. Nov. 7. 2012;104(21):1635-1646. [pmid: 23104212].
108 Eklof V, Wikberg ML, Edin S, et al. The prognostic role of KRAS, BRAF, PIK3CA and PTEN in colorectal cancer. Br J Cancer. May. 28. 2013;108(10):2153-2163. [pmid: 23660947].
109 Bazan V, Agnese V, Corsale S, et al. Specific TP53 and/or Ki-ras mutations as independent predictors of clinical outcome in sporadic colorectal adenocarcinomas: results of a 5-year Gruppo Oncologico dell'Italia Meridionale (GOIM) prospective study. Ann Oncol. May. Suppl 4. 2005;16:iv50-iv55. [pmid: 15923430].
110 Deschoolmeester V, Boeckx C, Baay M, et al. KRAS mutation detection and prognostic potential in sporadic colorectal cancer using high-resolution melting analysis. Br J Cancer. 2010;103(10):1627-1636. [pmid: 20959826].
111 Geido E, Sciutto A, Rubagotti A, et al. Combined DNA flow cytometry and sorting with k-ras2 mutation spectrum analysis and the prognosis of human sporadic colorectal cancer. Cytometry. Aug. 15. 2002;50(4):216-224. [pmid: 12210601].
112 Imamura Y, Morikawa T, Liao X, et al. Specific mutations in KRAS codons 12 and 13, and patient prognosis in 1075 BRAF wild-type colorectal cancers. Clin Cancer Res. 2012;18(17):4753-4763. [pmid: 22753589].
113 Ogino S, Meyerhardt JA, Irahara N, et al. KRAS mutation in stage III colon cancer and clinical outcome following intergroup trial CALGB 89803. Clin Cancer Res. Dec. 1. 2009;15(23):7322-7329. [pmid: 19934290].
114 Li Z, Chen Y, Wang D, et al. Detection of KRAS mutations and their associations with clinicopathological features and survival in Chinese colorectal cancer patients. J Int Med Res. 2012;40(4):1589-1598. [pmid: 22971512].
115 Chang SC, Lin JK, Yang SH, et al. Relationship between genetic alterations and prognosis in sporadic colorectal cancer. Int J Cancer. Apr. 1. 2006;118(7):1721-1727. [pmid: 16231316].
116 Donada M, Bonin S, Nardon E, et al. Thymidilate synthase expression predicts longer survival in patients with stage II colon cancer treated with 5-flurouracil independently of microsatellite instability. J Cancer Res Clin Oncol. Feb. 2011;137(2):201-210. [pmid: 20387074].
117 Guidoboni M, Gafa R, Viel A, et al. Microsatellite instability and high content of activated cytotoxic lymphocytes identify colon cancer patients with a favorable prognosis. Am J Pathol. Jul. 2001;159(1):297-304. [pmid: 11438476].
118 Gryfe R, Kim H, Hsieh ET, et al. Tumor microsatellite instability and clinical outcome in young patients with colorectal cancer. N Engl J Med. Jan. 13. 2000;342(2):69-77. [pmid: 10631274].
119 Hong SP, Min BS, Kim TI, et al. The differential impact of microsatellite instability as a marker of prognosis and tumour response between colon cancer and rectal cancer. Eur J Cancer. May. 2012;48(8):1235-1243. [pmid: 22071131].
120 Jensen SA, Vainer B, Kruhoffer M, et al. Microsatellite instability in colorectal cancer and association with thymidylate synthase and dihydropyrimidine dehydrogenase expression. BMC Cancer. 2009;9:25. [pmid: 19154585].
121 Kim GP, Colangelo LH, Wieand HS, et al. Prognostic and predictive roles of high-degree microsatellite instability in colon cancer: a National Cancer Institute-National Surgical Adjuvant Breast and Bowel Project Collaborative Study. J Clin Oncol. Mar. 1. 2007;25(7):767-772. [pmid: 17228023].
122 Lin CC, Lai YL, Lin TC, et al. Clinicopathologic features and prognostic analysis of MSI-high colon cancer. Int J Colorectal Dis. Mar. 2012;27(3):277-286. [pmid: 22076610].
123 Shia J, Klimstra DS, Nitzkorski JR, et al. Immunohistochemical expression of folate receptor alpha in colorectal carcinoma: patterns and biological significance. Hum Pathol. Apr. 2008;39(4):498-505. [pmid: 18342661].
124 Soreide K, Slewa A, Stokkeland PJ, et al. Microsatellite instability and DNA ploidy in colorectal cancer: potential implications for patients undergoing systematic surveillance after resection. Cancer. Jan. 15. 2009;115(2):271-282. [pmid: 19109816].
125 Yoon YS, Yu CS, Kim TW, et al. Mismatch repair status in sporadic colorectal cancer: immunohistochemistry and microsatellite instability analyses. J Gastroenterol Hepatol. Dec. 2011;26(12):1733-1739. [pmid: 21615788].
126 Venook AP, Niedzwiecki D, Lopatin M, et al. Biologic Determinants of Tumor Recurrence in Stage II Colon Cancer: Validation Study of the 12-Gene Recurrence Score in Cancer and Leukemia Group B (CALGB) 9581. J Clin Oncol. 2013. Mar. 25. [pmid: 23530100].
127 Kamat AM, Dickstein RJ, Messetti F, et al. Use of fluorescence in situ hybridization to predict response to bacillus Calmette-Guerin therapy for bladder cancer: results of a prospective trial. J Urol. Mar. 2012;187(3):862-867. [pmid: 22245325].
128 Whitson J, Berry A, Carroll P, et al. A multicolour fluorescence in situ hybridization test predicts recurrence in patients with high-risk superficial bladder tumours undergoing intravesical therapy. BJU Int. Aug. 2009;104(3):336-339. [pmid: 19220253].
129 Zellweger T, Benz G, Cathomas G, et al. Multi-target fluorescence in situ hybridization in bladder washings for prediction of recurrent bladder cancer. Int J Cancer. Oct. 1. 2006;119(7):1660-1665. [pmid: 16646074].
130 Gligorov J, Pivot XB, Naman HL, et al. Prospective study of the impact of using the 21-gene recurrence score assay on clinical decision making in women with estrogen receptor-positive, HER2-negative, early-stage breast cancer in France. ASCO. 2012.
131 Davidson JA, Croomwell I, Ellard S, et al. A prospective clinical utility study of the impact of the 21-gene recurrence score assay (Oncotype DX) in estrogen receptor positive (ER+) node negative (pN0) breast cancer in academic Canadian centers. ASCO. 2012.
132 Ademuyiwa FO, Miller A, O'Connor T, et al. The effects of oncotype DX recurrence scores on chemotherapy utilization in a multi-institutional breast cancer cohort. Breast Cancer Res Treat. Apr. 2011;126(3):797-802. [pmid: 21197567].
133 Albanell J, Gonzalez A, Ruiz-Borrego M, et al. Prospective transGEICAM study of the impact of the 21-gene Recurrence Score assay and traditional clinicopathological factors on adjuvant clinical decision making in women with estrogen receptor-positive (ER+) node-negative breast cancer. Ann Oncol. Mar. 2012;23(3):625-631. [pmid: 21652577].
134 Bargallo JER, Lara F, Shaw Dulin RJ, et al. A study of the impact of the 21-gene breast cancer assay on the use of adjuvant chemotherapy in women with breast cancer in a Mexican public hospital. European Society for Medical Oncology Congress. 2012. September. Vienna, Austria.
135 Davidson JA, Cromwell I, Ellard SL, et al. A prospective clinical utility and pharmacoeconomic study of the impact of the 21-gene Recurrence Score(R) assay in oestrogen receptor positive node negative breast cancer. Eur J Cancer. 2013. Apr. 20. [pmid: 23611660].
136 de Boer RH, Baker C, Speakman D, et al. The impact of a genomic assay (Oncotype DX) on adjuvant treatment recommendations in early breast cancer. Med J Aust. Aug. 5. 2013;199(3):205-208. [pmid: 23909545].
137 Eiermann W, Rezai M, Kummel S, et al. The 21-gene recurrence score assay impacts adjuvant therapy recommendations for ER-positive, node-negative and node-positive early breast cancer resulting in a risk-adapted change in chemotherapy use. Ann Oncol. Mar. 2013;24(3):618-624. [pmid: 23136233].
138 Geffen DB, Abu-Ghanem S, Sion-Vardy N, et al. The impact of the 21-gene recurrence score assay on decision making about adjuvant chemotherapy in early-stage estrogen-receptor-positive breast cancer in an oncology practice with a unified treatment policy. Ann Oncol. Nov. 2011;22(11):2381-2386. [pmid: 21363879].
139 Henry LR, Stojadinovic A, Swain SM, et al. The influence of a gene expression profile on breast cancer decisions. J Surg Oncol. May. 1. 2009;99(6):319-323. [pmid: 19204954].
140 Holt S, Bertelli G, Humphreys I, et al. A decision impact, decision conflict and economic assessment of routine Oncotype DX testing of 146 women with node-negative or pNImi, ER-positive breast cancer in the U.K. Br J Cancer. Jun. 11. 2013;108(11):2250-2258. [pmid: 23695023].
141 Joh JE, Esposito NN, Kiluk JV, et al. The effect of Oncotype DX recurrence score on treatment recommendations for patients with estrogen receptor-positive early stage breast cancer and correlation with estimation of recurrence risk by breast cancer specialists. Oncologist. 2011;16(11):1520-1526. [pmid: 22016474].
142 Kamal AH, Loprinzi CL, Reynolds C, et al. Breast medical oncologists' use of standard prognostic factors to predict a 21-gene recurrence score. Oncologist. 2011;16(10):1359-1366. [pmid: 21934103].
143 Klang SH, Hammerman A, Liebermann N, et al. Economic implications of 21-gene breast cancer risk assay from the perspective of an Israeli-managed health-care organization. Value Health. Jun-Jul. 2010;13(4):381-387. [pmid: 20412544].
144 Lo SS, Mumby PB, Norton J, et al. Prospective multicenter study of the impact of the 21-gene recurrence score assay on medical oncologist and patient adjuvant breast cancer treatment selection. J Clin Oncol. Apr. 1. 2010;28(10):1671-1676. [pmid: 20065191].
145 Rayhanabad JA, Difronzo LA, Haigh PI, et al. Changing paradigms in breast cancer management: introducing molecular genetics into the treatment algorithm. Am Surg. Oct. 2008;74(10):887-890. [pmid: 18942607].
146 Schneider JG, Khalil DN. Why does Oncotype DX recurrence score reduce adjuvant chemotherapy use?. Breast Cancer Res Treat. Aug. 2012;134(3):1125-1132. [pmid: 22723033].
147 Yamauchi H, Nakagawa C, Takei H, et al. Prospective Study of the Effect of the 21-Gene Assay on Adjuvant Clinical Decision-Making in Japanese Women With Estrogen Receptor-Positive, Node-Negative, and Node-Positive Breast Cancer. Clin Breast Cancer. 2013. Oct. 26. [pmid: 24321102].
148 Bueno-de-Mesquita JM, van Harten WH, Retel VP, et al. Use of 70-gene signature to predict prognosis of patients with node-negative breast cancer: a prospective community-based feasibility study (RASTER). Lancet Oncol. Dec. 2007;8(12):1079-1087. [pmid: 18042430].
149 Cartwright T, Chao C, Lee M, et al. Effect of the 12-gene colon cancer assay results on adjuvant treatment recommendations in patients with stage II colon cancer. Curr Med Res Opin. 2013. Nov. 7. [pmid: 24127781].
150 Srivastava G, Renfro LA, Behrens RJ, et al. Prospective evaluation of a 12-gene assay on treatment recommendations in patients with stage II colon cancer. ASCO Gastrointestinal Symposium. 2013. January. San Francisco, CA.
151 Brenner B, Lopatin M, Lee M, et al. Impact of the 12-gene colon cancer recurrence score assay on clinical decision-making for adjuvant therapy in stage II colon cancer patients in Israel. European Cancer Congress. 2013. September. Amsterdam, Netherlands.
152 Katkoori VR, Jia X, Shanmugam C, et al. Prognostic significance of p53 codon 72 polymorphism differs with race in colorectal adenocarcinoma. Clin Cancer Res. Apr. 1. 2009;15(7):2406-2416. [pmid: 19339276].
153 Manne U, Weiss HL, Myers RB, et al. Nuclear accumulation of p53 in colorectal adenocarcinoma: prognostic importance differs with race and location of the tumor. Cancer. Dec. 15. 1998;83(12):2456-2467. [pmid: 9874449].