# Results

## Overall Literature Yield

Our searches identified a total of 1462 abstracts, of which we screened 227 in full text and included 135 in the horizon scan for Key Question 1 (Figure 4). Twenty-five studies were included for Key Questions 2 and 3: 16 studies addressed Key Question 2,^67–82^ and 10 studies addressed Key Question 3,^49,75,83–90^ with 1 study75 providing data for both of these key questions. One study was in Chinese84; the others were all published in English. No studies addressed Key Question 4. The 110 studies from the horizon scan that were excluded for Key Questions 2 through 4 are listed, along with the reason for exclusion, in Appendix B.

Figure 5 Literature Flow Diagram

Studies could have had more than one reason for exclusion but only one reason for each is listed here.

FISH=fluorescence in situ hybridization; HPV=human papillomavirus; ISH=in situ hybridization; KQ=Key Question; MYC=myelocytomatosis oncogene; PCR=polymerase chain reaction; TERC=telomerase RNA component.

Figure 5 is a literature flow diagram illustrating the number of studies identified in the initial search (1462) through the final numbers of studies included for each of the four key questions: 134 studies were in for Key Question 1, which was a horizon scan; 16 studies were in for Key Question 2 about analytic validity of in situ hybridization (ISH) testing, 10 studies were in for Key Question 3 about clinical validity of ISH testing, and 0 studies were in for Key Question 4 about clinical utility and harms of ISH testing. The main reasons for rejection of articles reviewed in full text were that the ISH test did not use the probes of interest (in 19 studies), there was no analytic validity data (in 7 studies), there was no analytic validity data and also no cytologic specimens (in 69 studies), and ISH results were not reported for cytologic classification according to histologic classification (in 16 studies).

## Key Question 1 (Horizon Scan)

### Key Question 1 What ISH Tests Have Been Used in Cervical Cytology or Histology Specimens?

#### Initial Review

Key Question 1 asked what ISH tests have been examined, with what frequency, in studies of cervical cytology or histology. A horizon scan of the literature was performed, identifying 135 articles that described the use of an ISH probe on cervical cytology or histology samples. The probes most commonly used were TERC (31 studies), MYC (7 studies, all of which also used a TERC probe), HPV 16 (91 studies), and HPV 18 (used in 87 of the 91 studies with an HPV probe) (see Appendix Figures C1 and C2). (Probes for chromosome 7 and chromosome 3 were not considered for narrowing our review. Chromosomal probes are used as controls for polyploidy in combination with other probes that target a more specific genetic region of interest.)

#### Focused Review

We focused the subsequent detailed evidence review (i.e., Key Questions 2–4) on the 116 studies using one or more of these four most common ISH probes: a probe for TERC, MYC, or HPV 16 or 18; the remaining 19 studies did not use these probes and were not reviewed further.

Appendix Tables C1 and C2 provide data on the 116 studies according to whether they used a TERC probe (31 studies [27 percent]) or either HPV probe (91 studies [78 percent]) (5 studies [4 percent] used probes of both types). Most studies were conducted in Europe (54 percent) and the United States (21 percent), but there were also studies from China, Japan, Brazil, Mexico, Egypt, India, Israel, and New Zealand (see Appendix Figures C3 and C4).

Fifty-four percent of the studies involved cytology specimens, and 73 percent involved histology specimens (studies could involve both). A total of 93 percent of the studies used convenience samples (the rest were not specified [4 percent] or used systematic [2 percent] or random sampling [1 percent]). Nine percent of studies included less than 30 patients.

None of the studies examined only patients 65 years of age or older. Although the mean or median age in most studies was less than 50 years, the age ranges were wide (range across all studies, 14 to 93 years) (data not shown). The majority of studies (75 percent) were cross-sectional (72 percent, with the rest being longitudinal [25 percent] or not specified [2 percent]).

Focusing the detailed evidence review on ISH tests for TERC (with or without MYC) was supported by the frequency of their use in the literature and by our narrative review of microarray studies, which suggest that gain of TERC is linked to high-grade cervical cancer (see the Background section). Including ISH probes for HPV 16 (with or without HPV 18) was supported by the findings of a large amount of literature on these tests and because HPV 16 and HPV 18 are well characterized as the two high-risk types most strongly associated with cancer development.

## Key Question 2

### Key Question 2a (Analytic Validity): For ISH tests for TERC or MYC or HPV 16 or HPV 18, what are the associations between ISH test results and reference test results? What thresholds were used? What reference standards were used?

#### Agreement Between ISH for TERC or MYC and Reference Tests

No studies provided data on the association between ISH for TERC or MYC and a DNA-based reference test with measurement on the same samples.

#### Agreement Between ISH for HPV 16 or 18 and Reference Tests

Fourteen studies compared ISH tests that included HPV 16 or HPV 18 with another HPV test in a total of 852 patients.67–79,81 The studies were heterogeneous with regard to the types of tissue, ISH test, and reference test; the HPV genotype; and the number of probes in either the ISH test or the reference test (see Table 4). Study characteristics and results for agreement between FISH test and reference test are given in Table 5. Of the 14 studies, 4 used ISH on cytologic samples and 11 used ISH on histologic specimens (1 study72 tested both types of sample). The studies varied in terms of sampling strategy and country; only 4 of the 14 were conducted in the United States.

The ISH tests used were specifically ISH in 10 studies, FISH in 1 study, catalyzed signal amplified colorimetric (CSAC) ISH in 1 study, catalyzed reporter deposition amplified (CARD) ISH in 1 study, and nonisotopic ISH in 1 study. For purposes of summary, we considered all these ISH variations as equivalent. ISH assays tested for variable combinations of HPV genotypes; some tested for a panel of high-risk HPV, some tested for specific genotypes. Studies did not clearly identify the specific probes of a positive test. The reference tests were PCR in 11 studies (1 of which used both PCR and real-time PCR 68), Hybrid Capture 2 in 2 studies (1 of which also used PCR72), and in situ PCR in 2 studies. The ISH test and the reference tests conspicuously varied in the HPV genotypes captured, both within and across studies.

The percent agreement between the ISH test and the reference test in each study is shown in Figure 6. (The percent agreement is the sum of concordant results over the total number of test comparisons, expressed as percentage.) Three studies compared tests only in samples that were negative by ISH69–71 but they were still included in the analysis of overall agreement. Overall, agreement was variable, as was the precision of the estimates. The agreement ranged between 35 percent (95 percent CI, 15.4 to 59.2) to 100 percent (95 percent CI, 91.6 to 100). Among the 11 studies using PCR as the reference tests, agreement ranged from 48.5 percent (95 percent CI, 36.2 to 61.0) to 100 percent (95 percent CI, 73.5 to 100.0). The numbers of studies using another shared reference test were too small for meaningful summary. Because of the across-study heterogeneity and clinical variability seen in the studies reviewed for Key Question 2, we refrained from meta-analysis of the results.

This variability in agreement was expected given the true heterogeneity from comparison of tests with different principles of measurement and different target DNA. ISH tests specifically for nuclear HPV DNA; other tests do not. In situ PCR, for example, quantifies messenger RNA and not DNA (thus looking at gene expression, not the actual number of copies of the gene). Other PCR-based tests cannot distinguish between HPV DNA in the nucleus and HPV DNA in the cytosol. Hybrid Capture 2 tests for HPV test for DNA of high-risk HPV types, but it cannot determine the specific HPV types. The HPV probe sets used by ISH and by the reference test in each study often did not overlap. Given the substantial disagreement between tests across studies, is possible that index and reference tests provide complementary information and that combining these tests could increase diagnostic or prognostic accuracy.

Table 4 Patient and Study Characteristics in the 14 Studies Involving FISH Using HPV 16 or 18 Probes Included for Key Question 2

Author Year Country PMID | Patient Population Age | Index Test and Probes [*Bold type indicates probes not included in reference probe set] | Index Test (ISH) Details | Index Test Definition of Positive Result | Reference Test and Probes [*Bold type indicates also included in FISH probe set] | Reference Test Details
Alameda 2011 Spain 21302019 | 80 Women with ASCUS or LSIL cytologic samples Age range, 19–62 yr | ISH Probes for high- risk HPV: 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, 68, 70 pooled | Automated detection system Ventana INFORM HPV (Atom, Ventana, Ventana Medical Systems, Tucson, AZ) | At least 1 positive cell (staining could be diffuse [episomal], multipunctate [integrated], or both) | PCR Probes for HPV 6,11, 16,18, 26, 31, 33, 35, 39,40, 42, 43, 44, 45, 51, 52, 53, 54, 56, 58, 59, 61,62, 66, 68, 70, 71, 72, 73, 81, 82, 83, 84, 85, and 89 | Direct sequencing by BigDye v.3.1 kit (Applied Biosystems, Foster City, CA) and (for multiple genotypes in one sample) CLART HPV2 Kit (Genomica)
Andersson 2009 Sweden 19880826 | 78 Women with histologic specimens (7 and 16 women did not have data for comparison with PCR and real-time PCR, respectively) [Two nonindependent populations] Mean age, 35.3 yr (median, 33; range, 23–60) | FISH Probes for HPV 6, 18, 26, 30, 31, 33, 35, 39, 45, 51, 52, 53, 56, 58, 59. 66, 82 pooled | Probes from Abbott Molecular Inc. | All nuclei on slide evaluated using the Spectrum Green filter; positive results scored as episomal, episomal and integrated, or integrated pattern | PCR Probes for low-risk and high-risk HPV: 6, 11, 16, 18, 26,31, 33, 35, 39, 40, 42, 45, 51, 52, 53, 54, 55, 56, 58, 59, 61, 62, 64, 66–73, 81, 82, 83, 84, 89 | LineBlot (Roche)
Andersson 2009 Sweden 19880826 | | FISH Probes for HPV 6, 18, 26, 30, 31, 33, 35, 39, 45, 51, 52, 53, 56, 58, 59. 66, 82 pooled | Probes from Abbott Molecular Inc. | All nuclei on slide evaluated using the Spectrum Green filter; positive results scored as episomal, episomal and integrated, or integrated pattern | Real-time PCR Probes for high-risk HPV: 16, 18, 31, 33, 35, 39, 45, 52, 58, 67 | Quantovir
Ansari-Lari 2004 US 15043304 | 19 Women with endocervical adenocarcinoma in histologic specimens Age NR | ISH Probes for HPV 16 and 18 individually as well as 6, 11, 16, 18, 31, 33, 45, 51 pooled | Probe set from Dako Corp. | NR | PCR For “more than 35 HPV probes” | LineBlot (Roche)
Bernard 1994 France 7877628 | 20 Women with cervical lesions on biopsy that were ISH-negative Age NR | ISH Probes for HPV 6, 11, 16, 18, 31, 33, 51 pooled | NR | Staining in epithelial cells but not in any underlying connective tissue and repeat positivity on duplicate testing | In situ PCR Probes for HPV 6, 11, 16, 18, 31, 33, 35, 39, 45, 51, 52 | NR
Bertelsen 1996 Norway 9048869 | 71 Women with CIN on biopsy specimens that were HPV-negative on ISH (some samples not accounted for) Age NR | ISH Probes for HPV 6, 11, 16, 18, 31, 33, 35, 42, 43, 44, 45, 51, 52, 56 pooled | Digene Tissue Hybridization Kit and HPV Omniprobe (Digene Diagnostics, Inc.) | Staining | PCR Probes for HPV 6, 11, 13, 16, 18, 30, 31, 32, 33, 35, 39, 40, 43, 45, 51, 52, 54–56, 58, 59, 66 | NR
Birner 2001 Austria 11455003 | 86 Women with CIN3, HPV-positive cervical cancer biopsy specimens Age NR | CSAC-ISH Probes for HPV 16, 18, 31, and 33 individually as well as 6, 11, 16, 18, 30, 31, 33, 45, 51, 52 pooled | Probes from DAKO | Patchy signal unevenly distributed across nuclei (episomal HPV DNA) or a dot-like signal in nuclei (integrated HPV DNA) | PCR Probes for HPV 16, 18, 31, 33, 35, 45 | NR
Birner 2001 Austria 11455003 | 21 Women with known high-risk HPV and cytologic and histologic specimens [independent of the 86 women above] Age NR | CSAC-ISH Probes for HPV 16, 18, 31, and 33 individually as well as 6, 11, 16, 18, 30, 31, 33, 45, 51, 52 pooled | Probes from DAKO | Patchy signal unevenly distributed across nuclei (episomal HPV DNA) or a dot-like signal in nuclei (integrated HPV DNA) | Hybrid Capture 2 Probes for low-risk HPV 6, 11, 42, 43, 44 and high-risk HPV 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, 68 | Digene Corp.
Bulten 2002 Netherlands 12375262 | 56 Women with biopsy samples (5 normal, 11 CIN1, 13 CIN2, 18 CIN3, and 9 invasive carcinomas) Age NR | CARD-ISH Probes for HPV 16, 18 pooled | Probes from BRL | NR | PCR Probes for HPV 6, 11, 16, 18, 31, 33, 34, 35, 39, 40, 42, 43, 44, 45, 51, 52, 53, 54, 56, 58, 59, 66, 68, 70, and 74 | Short-fragment PCR hybridization line probe assay for detection and genotyping
Cavalcanti 1996 Brazil 9070405 | 12 biopsy specimens pretested with Southern blotting (3 with “reactive changes” [“histologically normal tissues presenting only reactive/reparative changes”], 4 LSIL, 4 HSIL, and 1 SCC) Range of mean ages given by histologic grade, 31.5–46.9 yr | Nonisotopic ISH Probes for HPV 6, 11, 16, 18, 31, 33, 35 pooled | Probes home brewed or from Digene Corp. | Strong staining in upper epithelial cell nuclei | PCR Probes for HPV 6, 11, 16, 18, 31, 33, 35 | Probes home brewed or from Digene Corp.
Hesselink 2004 Netherlands 14968413 | 76 Women with cytologic samples (normal or borderline, mild, moderate, or severe dysplasia) Mean age, 35 yr (range, 19–63) | ISH Probes for HPV 16, 18, 31, 33, 35, 45, 51, 52, 56, 58, 59, 68, 70 pooled | Ventana HPV lipopolysaccharide-binding protein test | Distinct nuclear staining in at least 1 cell | Hybrid Capture 2] For HPV 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, and 68 | Digene Corp.
Kong 2007 US 17197917 | 25 Women with atypical squamous metaplasia on biopsy (n=28 but 3 did not have data for both tests) Mean age, 32.7 yr (median, 20; range, 20–63) | ISH Probes for HPV 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 66 pooled | Ventana HPVII test | Staining scored as strong or weak and also punctate, diffuse, or mixed | PCR Probes for HPV 6, 11, 16, 18, 30, 31, 33, 35, 39, 42–45, 51, 52, 53–56, 58, 59, 66, 68, 72, 83, 86, 87, 90, and 91 | NR
Lie 1997 Norway 9113073 | 203 Women with CIN2 or CIN3 biopsy specimens Median age, 32 yr (range, 21–76) | ISH Probes for HPV 6, 11, 16, 18, 31, 33, 35 pooled | Vira-Type In Situ Kit (Digene Diagnostics Inc., Silver Spring MD) | NR | PCR Probes for “many types” of HPV (NR) | NR
Masumoto 2003 Japan 14506638 | 10 biopsy specimens for small-cell carcinoma of the cervix Mean age, 42.7 yr (range, 27–69) | ISH Probes for HPV 16, 18, 31, 33 individually as well as “wide spectrum” pooled | GenPoint kit (DakoCytomation, Kyoto, Japan) | Staining (also scored as diffuse, punctate, or both) | PCR Probes for “a broad range of genital HPVs” | Genotyping done through direct sequencing
Qureshi 2005 US 15839613 | 90 LSIL cytologic specimens by ThinPrep (n=47) or SurePath kit (n=43) Age NR | ISH Probes for HPV 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, 72 pooled | INFORM HPV High Risk kit (Ventana Medical Systems Inc., Tucson AZ) | NR except that pattern could be diffuse or punctate | PCR Probes for HPV 6, 11, 16, 18, 30, 31, 33, 35, 39, 42–45, 51, 52, 53–56, 58, 59, 66, 68, 72, 74, 83, 86, 87, 90, 91 | HPV genotyped by Big Dye Terminator kit (Applied Biosystems)
Walker 1996 France 8727101 | 30 Women with biopsy samples Median age, 29 yr (range, 21–40) | ISH Probes for “a mix of HPV” types including 6, 11, 16, 18, 31, 33 | Probes from Biohit, Finland, or Dakopatts, Denmark | NR | In situ PCR Probes for 40 HPV types including 6, 11, 16, 18, 31, 33, 35, 39, 40, 42, 45, 52, 53, 54, and 59 | NR

ASCUS=atypical squamous cells of undetermined significance; CARD=catalyzed reporter deposition amplified; CI=confidence interval; CIN=cervical intraepithelial neoplasia; CSAC=catalyzed signal amplified colorimetric DNA; FISH=fluorescence in situ hybridization; HPV=human papillomavirus; HSIL=high-grade squamous intraepithelial lesion; ISH=in situ hybridization; LSIL=low-grade squamous intraepithelial lesion; NR=not reported; PCR=polymerase chain reaction; SCC=squamous-cell carcinoma; yr=year(s).

Table 5 Results for Analytic Validity in the 14 Studies Involving ISH Using HPV 16 or 18 Probes Included for Key Question 2

Author Year Country PMID | Sample Classification and Size | Tissue Preparation | Index Test Reference Test | Index Test ISH Result | No. + on Ref. Test | No. − on Ref. Test
Alameda 2011 Spain 21302019 | ASCUS or LSIL (n=80) | Cytologic | ISH PCR | ISH + | 32 | 0
Alameda 2011 Spain 21302019 | ASCUS or LSIL (n=80) | Cytologic | ISH PCR | ISH - | 7 | 41
Andersson 2009 Sweden 19880826 | Any classification (n=71, with overlap with the 62 below) | Histologic | FISH PCR | ISH + | 45 | 4
Andersson 2009 Sweden 19880826 | Any classification (n=71, with overlap with the 62 below) | Histologic | FISH PCR | ISH - | 14 | 8
Andersson 2009 Sweden 19880826 | Any classification (n=62, with overlap with the 71 above) | Histologic | FISH Real-time PCR | ISH + | 30 | 14
Andersson 2009 Sweden 19880826 | Any classification (n=62, with overlap with the 71 above) | Histologic | FISH Real-time PCR | ISH - | 6 | 12
Ansari-Lari 2004 US 15043304 | Endocervical adenocarcinoma (n=5) | Histologic | ISH PCR | ISH + | NR | NR
Ansari-Lari 2004 US 15043304 | Endocervical adenocarcinoma (n=5) | Histologic | ISH PCR | ISH - | 1 | 4
Bernard 1994 France 7877628 | Any classification (n=20) | Histologic | ISH In situ PCR | ISH + | NR | NR
Bernard 1994 France 7877628 | Any classification (n=20) | Histologic | ISH In situ PCR | ISH - | 13 | 7
Bertelsen 1996 Norway 9048869 | Any class (n=68) | Histologic | ISH PCR | ISH + | NR | NR
Bertelsen 1996 Norway 9048869 | Any class (n=68) | Histologic | ISH PCR | ISH - | 35 | 33
Birner 2001 Austria 11455003 | CIN3 (n=86, independent of the 21 below) | Histologic | CSAC-ISH PCR | ISH + | 66 | 1
Birner 2001 Austria 11455003 | CIN3 (n=86, independent of the 21 below) | Histologic | CSAC-ISH PCR | ISH - | 10 | 9
Birner 2001 Austria 11455003 | CIN3, cytologic specimen (n=21, independent of the 86 above) | Cytologic | CSAC-ISH Hybrid Capture 2 | ISH + | 20 | 0
Birner 2001 Austria 11455003 | CIN3, cytologic specimen (n=21, independent of the 86 above) | Cytologic | CSAC-ISH Hybrid Capture 2 | ISH - | 1 | 0
Birner 2001 Austria 11455003 | CIN3, histologic specimen (n=21, same as the 21 above) | Histologic | CSAC-ISH Hybrid Capture 2 | ISH + | 21 | 0
Birner 2001 Austria 11455003 | CIN3, histologic specimen (n=21, same as the 21 above) | Histologic | CSAC-ISH Hybrid Capture 2 | ISH - | 0 | 0
Bulten 2002 Netherlands 12375262 | Any classification (n=56) | Histologic | CARD-ISH PCR | ISH + | 28 | 5
Bulten 2002 Netherlands 12375262 | Any classification (n=56) | Histologic | CARD-ISH PCR | ISH - | 3 | 20
Cavalcanti 1996 Brazil 9070405 | Any classification (n=12) | Histologic | Nonisotopic ISH PCR | ISH + | 9 | 0
Cavalcanti 1996 Brazil 9070405 | Any classification (n=12) | Histologic | Nonisotopic ISH PCR | ISH - | 0 | 3
Hesselink 2004 Netherlands 14968413 | Any classification (n=75)^*^ | Cytologic | ISH Hybrid Capture 2 | ISH + | 46 | 0
Hesselink 2004 Netherlands 14968413 | Any classification (n=75)^*^ | Cytologic | ISH Hybrid Capture 2 | ISH - | 28 | 1
Kong 2007 US 17197917 | Atypical squamous metaplasia (n=25) | Histologic | ISH PCR | ISH+ | 4 | 0
Kong 2007 US 17197917 | Atypical squamous metaplasia (n=25) | Histologic | ISH PCR | ISH - | 8 | 13
Lie 1997^†^ Norway 9113073 | CIN2 or CIN3 (n=203) | Histologic | ISH PCR | ISH+ | 86 | 83
Lie 1997^†^ Norway 9113073 | CIN2 or CIN3 (n=203) | Histologic | ISH PCR | ISH - | 12 | 22
Masumoto 2003 Japan 14506638 | Small-cell carcinoma of the cervix (n=10) | Histologic | ISH PCR | ISH+ | 6 | 0
Masumoto 2003 Japan 14506638 | Small-cell carcinoma of the cervix (n=10) | Histologic | ISH PCR | ISH - | 4 | 0
Qureshi 2005^‡^ US 15839613 | Any classification (n=90) | Cytology | ISH PCR | ISH+ | 52 | 13
Qureshi 2005^‡^ US 15839613 | Any classification (n=90) | Cytology | ISH PCR | ISH - | 8 | 17
Walker 1996 France 8727101 | Any classification (n=30) | Histologic | ISH In situ PCR | ISH+ | 13 | 0
Walker 1996 France 8727101 | Any classification (n=30) | Histologic | ISH In situ PCR | ISH - | 6 | 11

ASCUS=atypical squamous cells of undetermined significance; CARD=catalyzed reporter deposition amplified; CI=confidence interval; CSAC=catalyzed signal amplified colorimetric DNA; FISH=fluorescence in situ hybridization; HPV=human papillomavirus; ISH=in situ hybridization; LSIL=low-grade squamous intraepithelial lesion; NR=not reported; PCR=polymerase chain reaction.

* The study was of 76 samples but for 1 we could not ascertain both the index and reference test result.

† Counts were derived from sensitivity and specificity reported for ISH: sensitivity=0.51, specificity 0.65.

‡ For ISH: sensitivity (95% CI) 0.87 (0.75,0.94), specificity 0.57 (0.37,0.75).

Figure 6 Percent Agreement Between ISH (Index) Test Using HPV 16 or 18 Probes and Reference Test in the 14 Studies with Analytic Validity Data.*

This forest plot shows the percent agreement between the in situ hybridization (ISH) test (called the “index” test above) and the reference test for studies of ISH testing for human papillomavirus (HPV). Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. The PubMed identifier is listed in square brackets for each study. See Tables 4 and 5 for details for each study. The studies are ordered by the reference test (last column), then by index test (type of ISH), and finally by year of publication.

* Denotes overlapping patient populations between each of the two test pairs. Andersson 2009 reported data for two nonindependent samples for which FISH was compared with two separate reference tests (PCR and real-time PCR). Birner 2011 reported data for three comparisons, two of which were from the same population but one sample set was cytologic (cyto.) and the other was histologic (histo.).

CARD=catalyzed reporter deposition amplified; CSAC=catalyzed signal amplified colorimetric DNA; CI=confidence interval; HC2=Hybrid Capture 2; IS PCR=in situ PCR; NISH=nonisotopic in situ hybridization; PCR=polymerase chain reaction; PCR (RT)=PCR (real-time).

Figure 6 is a forest plot showing the percent agreement between the in situ hybridization (ISH) test and the reference test in each of 14 studies using ISH with a probe for human papillomavirus (HPV). Point estimates and 95 percent confidence intervals are shown for each test pair. The percent agreement was quite variable across the studies (range, 35.0 percent to 100 percent agreement).

#### Assessment of Risk of Bias and Completeness of Reporting

Figure 7 summarizes our assessment of quality and reporting for the 14 studies reviewed for Key Question 2a. All studies used HPV probes. The assessment was based on 11 questions relevant to assay performance and reporting thereof (see Appendix D for scoring for each study). In general, study reporting was variable across questions. All studies described the performance of the index tests in sufficient detail to permit replication (Q1). Fifty-seven percent included the use of both positive and negative samples (Q2), and all 57 percent used the same type of tissue for those controls (Q3). Blinding of testers and interpreters was not reported in any study (Q4, Q5). Some criteria for scoring test results were established a priori in the majority of studies (Q6). Only two studies provided information on cross-reactivity (Q7). Reproducibility on testing of the same specimen multiple times was not reported (Q8). Reproducibility across operators, instruments, reagent lots, different days of the week, and different laboratories was not described either (Q9), and no studies clearly described the numbers of samples with usable test results (Q10). There was no information on whether testing was performed with multisite collaborative, proficiency testing, or interlaboratory exchange programs (Q11).

Our assessment shows deficiencies in reporting, likely because most of the studies were not designed to specifically address analytic validity. Studies also did not explicitly describe laboratory procedures in detail because ISH testing and its reference standards (most often PCR assays) are well established in general (if not in particular for cervical specimens). Many of the reference tests were commercially available kits that probably included positive and negative controls, but we could not assume that this was the case and rarely was it reported.

Figure 7 Quality of Studies on Analytic Validity of In Situ Hybridization (ISH) with HPV 16 or 18 Probes.*

*Or other HPV types. The denominator for each question includes all 14 studies.

The 11 quality questions (Qs), adapted from Sun et al. 201157were scored as yes (considered to reflect low risk of bias), no (high risk of bias), or not reported (including not applicable for a corollary questions that followed a question with an “not reported” score). No studies had a high risk of bias; thus this category is not represented in the key. The items are as follows:

Q1=Was the execution of the assay described in sufficient detail to permit replication?

Q2=Were both positive and negative control samples tested?

Q3=Were negative control materials from the same type of tissue, and collected, stored, and processed in the same way that sample materials used clinically for testing will be?

Q4=Were the tests performed with positive or negative control samples being blinded to the testers?

Q5=Were the testing results interpreted with positive or negative control samples being blinded to the interpreters?

Q6=Were criteria for determining a testing result as positive, negative, indeterminate, and uninterpretable set a priori?

Q7=Was any information on cross-reactivity of the test reported?

Q8=Was the reproducibility of the test when performed multiple times on a single specimen established?

Q9=Was the reproducibility of the test adequately established (across operators, instruments, reagent lots, different days of the week, different laboratories)?

Q10=Was the rate of yield [numbers] of usable (interpretable) results reported?

Q11=Were the study data from a multisite collaborative, proficiency testing, or interlaboratory exchange programs?

Figure 7 is a horizontal bar chart showing the percentages of the 14 studies using in situ hybridization (ISH) with a probe for human papillomavirus (HPV) that were scored as having a low risk of bias or did not report data sufficient to address each of 11 questions addressing the risk of bias. None of the studies reported information pertaining to 5 of the questions; all studies reported the details of performing the ISH test in sufficient detail to permit replication; and for the remaining 5 questions, the studies varied in whether they had a low risk of bias or had not reported data that would permit ascertainment of the question.

#### Thresholds Used for Positive, Indeterminate, and Negative Results of the ISH Tests

To describe the thresholds used for positive, indeterminate, and negative results of the FISH tests, we reviewed information from the 14 articles using ISH with HPV probes as well as 10 studies reviewed for Key Question 3 (8 reporting on FISH for TERC and 3 reporting on FISH for HPV) (Tables4 above and Tables 6, and 7 below).

Specific thresholds were expected to be given in the studies of FISH with probes for TERC or MYC, since the 3q and 8p chromosome arms are normally present; in this case FISH is used to detect an abnormality in the numbers of copies of the gene. An abnormal test is determined based on the number of ISH signals in relationship to the number of chromosomes or the average percentage of positive cells visualized, not merely the presence or absence of any signal. Most of the studies of FISH with a TERC or MYC probe defined test result positivity by the presence of additional signals in two or three or more cells, often in combination with a threshold for cellular positivity (typically a ratio of the TERC or MYC probe and the chromosomal control probe) (Table 6). However, there were no standard thresholds for test positivity.

Two studies of FISH for TERC not included for detailed review for Key Question 2 or 3 (data not shown) established the threshold for positivity for TERC gain by assaying cervical cytology samples from 20 women with normal Pap results and negative for HPV infection. One study used a single group of 20 women82; the other used three different groups of 20, one each at the three study centers.80 Both studies established thresholds based on the mean plus 3 times the standard deviation for the percentage of cells with abnormal signals. The thresholds were 5.3 percent in the single-center study and 5.2 percent, 5.6 percent, and 6.4 percent in the three-center study. No statistical comparisons were performed.

For HPV 16 or 18 (and the other types tested for), test positivity was usually defined simply by staining indicating the presence of HPV DNA in the nucleus of at least one cell (Table 4 and Table 7), except in one study in which 30 or more cells had to have had staining for HPV for the sample to be deemed positive (for episomal infection). 90

#### Reference Standards Used to Assess the Presence or Absence of the Genetic Marker

In the articles we reviewed, the reference tests for HPV 16 or 18 were PCR or Hybrid Capture 2 (see Tables 4 and 5 for details). Staining on ISH tests identifies episomal or nuclear HPV DNA. Most HPV PCR assays detect viral DNA, but PCR does not differentiate between episomal or nuclear DNA. Hybrid Capture 2 tests for DNA of high-risk HPV types, but it cannot determine the specific HPV types. Neither can be considered a true reference standard for FISH tests.

### Key Questions 2b–2f b) What is known about reliability and reproducibility of FISH tests? What factors affect FISH test results? c) Are there some conditions for which a FISH test is not useable? d) What are the sample criteria s? e) What are the sample storage or preservation requirements? f) What variation occurs across laboratories?

To address Key Questions 2b through 2f, we looked at the 14 articles describing FISH with HPV probes as well as the 10 studies reviewed in detail for Key Question 3. Overall, the studies varied widely in terms of the information reported about the technical aspects of performing a FISH test.

None of the studies reported on the true reliability of FISH results within a study or the genetic, environmental, or other factors and their impact on FISH results or addressed whether there are some conditions for which a FISH test is not able to give a clinically useable result. None of the studies addressed variation in ISH results across multiple laboratories.

Regarding sample acceptance and rejection criteria for FISH tests, we would expect that typical laboratory techniques of sample storage and preservation would be required for a reliable FISH result, since the test involves DNA detection. In one study of ISH for HPV detection,69 the authors noted that the four true negative samples identified were suspect because they were the oldest samples in the study and used a different fixative than the rest; they believe the DNA was degraded. This was supported by a negative or weak result on beta-globin testing, indicating poor quality DNA; this test was also used by three other studies72,74,75 to ascertain whether the samples were satisfactory for FISH testing. One of these studies explicitly stated that all samples had a positive signal for beta-globin75; the other two presumably excluded any poor samples but did not report this. One other study77 reported that specimens with poor-quality DNA after testing by another means (amplification of a known genetic region) were excluded from index testing. Regarding the impact of sample storage or preservation requirements, we found a single study of 99 consecutive LSIL cytologic samples that were prepared at one of two centers (about half at each), one using ThinPrep and the other, SurePath. The authors reported that the method of preparation did not significantly affect positivity or negativity of FISH using probes for HPV.79

None of the studies included in our review addressed variations occurring in ISH results if performed in multiple laboratories. The two studies described above by Tu 2009 80 and Jin 2011^82^ show that thresholds established for normal specimens varied only slightly (from 5.2 to 6.4 percent) across different labs (no statistical comparisons were performed). According to the College of American Pathologists and American College of Medical Genetics proficiency testing program, the FISH test generally has been found to be reliable across labs.37 However, its proficiency was not tested for the chromosomal or HPV aberrations of interest in our review. One group suggested that incomplete sampling of the cervix by the cervical/endocervical brush can yield apparently negative FISH results owing to insufficient sampling of the lesion present90; this highlights the importance of operator care in obtaining cytologic samples.

Overall, for questions related to preanalytic issues impacting analytic validity, the data were sparse and highlighted a lack of commonly agreed upon test and validation standards.

### Key Question 2g What is the prevalence of the genetic marker(s) detected by the reference standards in Medicare beneficiaries by age or race/ethnicity?

We conducted a focused search for literature on the prevalence of the markers detected by ISH (i.e., TERC, MYC, HPV 16, and HPV 18) in Medicare beneficiaries by age or race/ethnicity. We did not find direct evidence.

## Key Question 3

For Key Question 3, we reviewed studies that examined the sensitivity or specificity of ISH tests in cytology samples for the diagnosis of high-grade CIN. We examined the role of ISH for add-on testing in 1) women who have a Pap test showing LSIL or ASCUS without a HPV test, and 2) in women who have a Pap test showing normal cytology or ASCUS as well as a positive HPV test.

### Eligible Studies

Ten studies were included into the systematic review for Key Question 3, all using FISH specifically (not another type of ISH test). Eight studies of 8,800 patients examined FISH testing for TERC gain.1,3,4,6–9,11 One of these studies, with 235 women (Sokolova 2007), provided results for FISH for TERC and separately for FISH for HPV. Five of the eight TERC studies used only TERC probes, whereas three reported results for the combined use of FISH for TERC and MYC, with one of these also reporting results for FISH for TERC, MYC, and HPV.90 All eight studies provided data for CIN2+ as an outcome; six had data for CIN3+ as well. There were 860 patients with ASCUS and 1033 patients with LSIL in these studies. In one study (Li 2010) all patients were HPV positive (type not specified) by Hybrid Capture 2; in the others the HPV status was not clear.

Three studies examined FISH for HPV detection in a total of 503 patients. 75,83,88 All had CIN2+ as an outcome, with CIN3+ also an outcome in two of these. Twenty-seven patients had ASCUS; 171 had LSIL. All patients were HPV positive, two by PCR and the third by FISH only.

Two of the eight TERC studies also compared the performance of FISH versus, or in combination with, Hybrid Capture 2for histologic outcomes. 49,90They investigated several test combinations. Voss 2010 compared three test strategies: FISH for TERC or MYC, FISH for TERC or MYC or HPV, and Hybrid Capture 2 for high-risk HPV for the outcome of CIN2+ in 115 LSIL patients. Jiang 2010 compared FISH for TERC, Hybrid Capture 2 for high-risk HPV, and a combination of the two) in both 660 ASCUS patients and 601 LSIL patients, for the outcomes of CIN2+ and CIN3+.

#### Key Question 3a (Clinical Validity): What is the association between FISH test results on cytology and CIN or cervical cancer on histopathology? What thresholds were used?

The eight studies using FISH tests for TERC, MYC, or HPV 16 or 18 are described in Table 6. The three studies of FISH using a probe for HPV are described in Table 7.

Table 6 Patient and Study Characteristics in the Eight Studies Involving FISH Using TERC or MYC Probes Included for Key Question 3

Author Year Country PMID | Patient Population | Age | FISH Probe(s) [Manufacturer, Location] | Thresholds | Cytology Description | HPV Test Description
Huang 2009 China NR | Women (20 controls, 100 with abnormal cytologic findings) who had cytologic smear and biopsy | NR | TERC or MYC [Beijing GP Medical] | NR | ThinPrep | NR
Jalali 2010 US 20171606 | Archival thin-layer cytologic slides of 31 women with LSIL | Range, 14–67 yr | TERC, CEP7 [Abbott Molecular, Des Plaines, IL] | Positive for TERC gain if ≥2 cells with ≥5 3q-FISH signals | NR | NR
Jiang 2010 China 20864639 | 7786 patients who underwent routine screening or were returning after abnormal cervical cytology result, HPV result, or symptoms of increased leukorrhea discharge or postcoital bleeding | Mean, 39.7 ± 9.7 yr (range, 18–93) | TERC, CSP3 [GP Medical Technologies Ltd., Beijing, China] | Abnormal signal if ratio of CSP3 to TERC was 2:3, 2:4, 2:5, 3:3, 4:4, etc.; positive if >2 TERC signals were observed | ThinPrep or Autocyte | “High risk” by Hybrid Capture 2
Kokalj-Vokac 2009 Slovenia 19837263 | Prospective data for150 women | Mean, 37.3 ± 10.1 yr (range, 20–75) | TERC, CEP7 [Cancer Genetics, Rutherford, NJ] | For each sample, 30 abnormal nuclei were checked; 2 signals for CEP7 and >2 signals for TERC constituted an abnormal FISH pattern. Positive if ≥5 cells with abnormal FISH pattern | Cervical smears | NR
Li 2011 China 21035173 | 300 women with mild cytologic abnormality and positive HR-HPV DNA test. | Mean, 39.3 yr (range, 20–71) | TERC, CEP3 [GP Medical, Ltd. Beijing, China] | TERC signals in >6.5 nuclei. | ThinPrep | HPV 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, 68 by Hybrid Capture 2
Sokolova 2007 US 17975027 | 235 women with cytologic smear and concurrent biopsy | NR | TERC or MYC [Abbott Molecular, Des Plaines, IL] | ≥3 TERC or MYC signals | ThinPrep | HPV 16, 18, 30, 45, 51, 58 by FISH
Sui 2010 China 20882876 | 63 women undergoing routine cytology screening | Mean, 42 yr (range 23–63) | TERC, CEP3 [China Medical Technologies Inc., Beijing China] | Positive for TERC if ratio >1.0 between the TERC and CEP3 copy number | SurePath | NR
Voss 2010 US 20701064 | 115 women with LSIL who underwent a same-day colposcopy-directed biopsy or had a follow-up biopsy within 1 yr after cytology specimen | Median, 24 yr; mean, 29 yr (range, 18–73) | TERC or MYC or HPV (16, 18, 30, 45, 51, or 58) [Abbott Molecular Inc., Des Plaines IL] | Positive gain of TERC or MYC if ≥3 positive cells. HPV positivity, ≥30 cells | ThinPrep | HPV 16, 18, 30, 45, 51, 58 by Hybrid Capture 2

CEP or CSP=centromere protein of the chromosome number specified; DNA=deoxyribonucleic acid; FISH=fluorescence in situ hybridization; HPV=human papillomavirus; HR-HPV=high-risk HPV; HSIL=high-grade squamous intraepithelial lesion; LSIL=low-grade squamous intraepithelial lesion; MYC=myelocytomatosis oncogene (on chromosome 8q24); NR=not reported; TERC=telomerase RNA component; US=United States; yr=year(s)

Table 7 Results for Clinical Validity in the Three Studies Involving FISH Using HPV Probes Alone Included for Key Question 3

Author Year Country PMID | Patient Population | Age | HPV Probe(s) [Manufacturer, Location] | Thresholds | Cytology Description
Fujii 2008 Japan 18936966 | 153 specimens from patients visiting Keio University Hospital, Tokyo, Japan. The population consisted of a mixture of asymptomatic women and those who were being followed up for previous atypical smears or were under treatment for previously diagnosed as CIN. All patients with HPV+ on PCR. | Median, 37 yr (range, 21–80) | HPV 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, 68 [NR] | Punctate pattern of at least 1 signal in the nucleus indicated HPV integration Diffuse nuclear pattern represented multiple copies of episomal HPV (viral replication) | ThinPrep
Hesselink 2004 Netherlands 14968413 | 115 women during a 3-month period in a routine gynecologic setting at the Department of Obstetrics and Gynecology, VU University Medical Center. Indications for visiting a gynecologist included having an abnormal cervical smear in the population-based screening program and monitoring after treatment for CIN3. All patients with HPV+ on PCR. | Mean, 35 yr (range, 19–63) | HPV 16, 18, 31, 33, 35, 45, 51, 52, 56, 58, 59, 68, 70 [Ventana Medical Systems, Tucson AZ] | NR | Cervical samples
Sokolova 2007 US 17975027 | 235 women with a concurrent biopsy. All patients with HPV+ by FISH. | NR | HPV 16, 18 [American Type Culture Collection, Manassas, VA] HPV 30, 45 [homebrew in lab in Heidelberg, Germany] HPV 51, 58 [Abbott Molecular, Inc., Des Plaines, IL] | Punctate staining, suggestive of integrated HPV state, was defined as at least 1 spot of staining Diffuse staining was suggestive of episomal HPV state | ThinPrep

CIN=cervical intraepithelial neoplasia; HPV=human papillomavirus; ISH=in situ hybridization; NR=not reported; PCR=polymerase chain reaction; US=United States; yr=year(s).

### Summary of Findings on Clinical Validity

#### LSIL

##### FISH for TERC or MYC

Seven studies compared the clinical validity of TERC in LSIL for CIN2+.3,4,6–9,11 Two of them, Sokolova 2007 and Voss 2010, examined FISH for TERC or MYC. Only one study tested patients who were all positive for HPV. 87 In these studies, the sensitivity ranged from 0.24 to 1.00, and specificity ranged from 0.38 to 1.00 (Figure 8). For the CIN2+ outcome, Sui 2010 had the highest sensitivity (1.00) and Kokalj-Vokac 2009 had the highest specificity (1.00).

Figure 8 Sensitivity and Specificity of FISH Testing for TERC in LSIL Patients for an Outcome of CIN2+

This forest plot shows the sensitivity (left plot) and specificity (right plot) of fluorescence in situ hybridization (FISH) testing for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2 or CIN3 or cervical cancer) in low-grade squamous intraepithelial lesion (LSIL) specimens. Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. The PubMed identifier is listed in square brackets for each study. See Table 6 for details for each study.

TERC=telomerase RNA component gene.

Figure 8 is a forest plot showing the sensitivity and specificity of fluorescence in situ hybridization (FISH) testing for TERC in patients with low-grade squamous intraepithelial lesion (LSIL) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2, CIN3, or cervical cancer). Point estimates for the seven studies are shown as black circles; horizontal lines denote 95 percent confidence intervals. The range of sensitivity estimates was 0.24 to 1.00 and for specificity estimates was 0.38 to 1.00.

The corresponding meta-analysis for FISH for TERC or MYC in LSIL patients for the outcome of CIN2+ is shown in Figure 9. We used a bivariate random effects model that allows for threshold effects (i.e., the trade-off between sensitivity and specificity across studies) and accounts for unexplained between-study heterogeneity. The summary receiver-operator-characteristic (ROC) curve derived from the model is shown, with each study plotted as a circle whose size is proportional to the number of study participants. The overall summary sensitivity was 0.76 (95 percent confidence interval [CI] 0.60, 0.86); the summary specificity was 0.79 (95 percent CI 0.50, 0.93). The largest study (Jiang 2010) is closest to the overall summary estimate, but the summary line fits to all the study estimates fairly well. The between-study correlation of sensitivity and specificity was negative, supporting an inverse relationship.

Figure 9 Summary ROC Curve for the Sensitivity and Specificity of FISH Testing for TERC or MYC in LSIL Patients for an Outcome of CIN2+

This receiver-operating-characteristic (ROC) curve plots the sensitivity (y axis) and specificity (x axis) of fluorescence in situ hybridization (FISH) testing for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2 or CIN3 or cervical cancer) in low-grade squamous intraepithelial lesion (LSIL) specimens. The summary estimate is represented by a black square, with each study plotted as a circle whose size is proportional to the number of study participants.

MYC=myelocytomatosis oncogene, TERC=telomerase RNA component gene.

Figure 9 is a receiver-operating-characteristic (ROC) curve plotting the sensitivity against the specificity of fluorescence in situ hybridization (FISH) testing for TERC in patients with low-grade squamous intraepithelial lesion (LSIL) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2, CIN3, or cervical cancer). Point estimates for the seven studies are shown as circles proportional in size to the number of participants. The overall summary estimate for the curve was 0.76 (95percent confidence interval [CI] 0.60, 0.86) for sensitivity and 0.79 (95 percent CI 0.50, 0.93) for specificity. The range of sensitivity estimates was 0.24 to 1.00 and for specificity estimates was 0.38 to 1.00.

Five studies compared the clinical validity of TERC in LSIL for CIN3+.2-6 Sokolova 2007 and Voss 2010 tested FISH for TERC or MYC. Again, only one study tested patients who were positive for HPV.87 In these studies, the sensitivity ranged from 0.45 to 0.93, with Li 2011 showing the highest sensitivity. Specificities ranged from 0.42 to 1.00, with Kokalj-Vokac 2009 reporting the highest estimate (Figure 10).

Figure 10 Sensitivity and Specificity of FISH Testing for TERC or MYC in LSIL Patients for an Outcome of CIN3+

This forest plot shows the sensitivity (left plot) and specificity (right plot) of fluorescence in situ hybridization (FISH) testing for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2 or CIN3 or cervical cancer) in low-grade squamous intraepithelial lesion (LSIL) specimens. Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. The PubMed identifier is listed in square brackets for each study. See Table 6 for details for each study.

MYC=myelocytomatosis oncogene, TERC=telomerase RNA component gene.

Figure 10 is a forest plot showing the sensitivity and specificity of fluorescence in situ hybridization (FISH) testing for TERC in patients with low-grade squamous intraepithelial lesion (LSIL) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 3+ (i.e., CIN3 or cervical cancer). Point estimates for the five studies are shown as black circles; horizontal lines denote 95 percent confidence intervals. The range of sensitivity estimates was 0.45 to 0.93 and for specificity estimates was 0.42 to 1.00.

The corresponding meta-analysis for FISH for TERC or MYC in LSIL patients for the outcome of CIN3+ is shown in Figure 11. The overall summary sensitivity was 0.78 (95 percent CI 0.65, 0.87) and the summary specificity was 0.79 (95 percent CI 0.51, 0.93). The between-study correlation of sensitivity and specificity was also negative. Visually, the curves in Figure 9 and Figure 11 appear to be similar, although the small number of studies in Figure 11 precludes conclusive findings.

Figure 11 Summary ROC Curve for the Sensitivity and Specificity of FISH Testing for TERC or MYC in LSIL Patients for an Outcome of CIN3+

This receiver-operating-characteristic (ROC) curve plots the sensitivity (y axis) and specificity (x axis) of fluorescence in situ hybridization (FISH) testing for an outcome of cervical intraepithelial neoplasia (CIN) 3+ (i.e., CIN3 or cervical cancer) in low-grade squamous intraepithelial lesion (LSIL) specimens. The summary estimate is represented by a black square, with each study plotted as a circle whose size is proportional to the number of study participants.

MYC=myelocytomatosis oncogene, TERC=telomerase RNA component gene.

Figure 11 is a receiver-operating-characteristic (ROC) curve plotting the sensitivity against the specificity of fluorescence in situ hybridization (FISH) testing for TERC in patients with low-grade squamous intraepithelial lesion (LSIL) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 3+ (i.e., CIN3 or cervical cancer). Point estimates for the five studies are shown as circles proportional in size to the number of participants. The overall summary estimate for the curve was 0.78 (95 percent confidence interval [CI] 0.65, 0.87) for sensitivity and 0.79 (95 percent CI 0.51, 0.93) for specificity. The between-study correlation of sensitivity and specificity was estimated to be -0.157.

##### FISH for TERC or MYC versus Other Tests

Two studies compared the performance of different tests or combinations of tests and their clinical validity in LSIL patients. One study compared FISH testing for TERC or MYC, FISH for TERC or MYC or high-risk HPV, and Hybrid Capture 2 for high-risk HPV.90 Using ROC curves to determine the optimum cutoff for producing the highest sensitivity without a great loss in specificity for the detection of CIN2+, Voss 2010 found the most favorable cutoff to be three or more cells with chromosomal gains or 30 or more cells with episomal HPV infection. These were cutoffs for positivity for testing FISH for TERC or MYC and FISH for TERC or MYC or HPV. For the diagnosis of CIN2+, testing with Hybrid Capture 2 for HPV was the most sensitive, whereas FISH for TERC or MYC was the most specific (Figure 12).

Figure 12 Sensitivity and Specificity of FISH Testing for TERC or MYC, FISH for TERC or MYC or High-Risk HPV, and Hybrid Capture 2 for High-Risk HPV for the Outcome of CIN2+ in LSIL Patients from Voss 2010

This forest plot shows, for the Voss 2010 study (PMID 20701064), the sensitivity (left plot) and specificity (right plot) of fluorescence in situ hybridization (FISH) testing for TERC, Hybrid Capture 2 (HC2) for human papillomavirus (HPV), and the combination of both results for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2 or CIN3 or cervical cancer) in low-grade squamous intraepithelial lesion (LSIL) specimens. Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. The See Table 6 for details of the study.

MYC=myelocytomatosis oncogene, TERC=telomerase RNA component gene.

Figure 12 is a forest plot showing the sensitivity and specificity of fluorescence in situ hybridization (FISH) testing for TERC or MYC, FISH testing for TERC or MYC or human papillomavirus (HPV), and Hybrid Capture 2 testing for HPV in patients with low-grade squamous intraepithelial lesion (LSIL) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2, CIN3, or cervical cancer). Point estimates are for one study--Voss 2010--for each of the three test combinations; horizontal lines denote 95 percent confidence intervals. The sensitivity was similar across all three (range, 0.83 to 1.00); the specificity estimates were more spread out (range, 0.28 to 0.53), with the highest specificity for FISH for TERC or MYC.

The other study compared FISH for TERC, Hybrid Capture 2 for HPV, and a combination of the two. Given the consistent pattern of higher sensitivity and lower specificity from the combined test compared to either test alone, we presumed that the combined test was considered positive if either FISH or Hybrid Capture 2 was positive; the study is unclear in this regard. For the outcome of CIN2+, the combination of FISH and Hybrid Capture 2 appears to be the most sensitive test while FISH alone was the most specific (Figure 13). These results also held for the outcome of CIN3+ (Figure 14). This combination provides a small gain in sensitivity as compared to FISH alone, but at the cost of much lower specificity.

Figure 13 Sensitivity and Specificity of FISH Testing for TERC, Hybrid Capture 2 for High-Risk HPV, and FISH for TERC or Hybrid Capture 2 for High-Risk HPV for the Outcome of CIN2+ in LSIL Patients from Jiang 2010

This forest plot shows, for Jiang 2010 (PMID 20864639), the sensitivity (left plot) and specificity (right plot) of fluorescence in situ hybridization (FISH) testing for TERC, Hybrid Capture 2 (HC2) for human papillomavirus (HPV), and a combination of both results for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2 or CIN3 or cervical cancer) in low-grade squamous intraepithelial lesion (LSIL) specimens. Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. See Table 6 for details of the study.

TERC=telomerase RNA component gene.

Figure 13 is a forest plot showing the sensitivity and specificity of fluorescence in situ hybridization (FISH) testing for TERC versus Hybrid Capture 2 for human papillomavirus (HPV) versus FISH + Hybrid Capture 2 in patients with low-grade squamous intraepithelial lesion (LSIL) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2, CIN3, or cervical cancer). Point estimates are for another study--Jiang 2010--for each of the three test combinations; horizontal lines denote 95 percent confidence intervals. With FISH testing alone, the sensitivity appears to be significantly lower than for the other two test combinations (0.76 vs. 0.95 and 0.99) and the specificity appears to be significantly higher (0.79 vs. 0.21 and 0.23).

Figure 14 Sensitivity and Specificity of FISH Testing for TERC, Hybrid Capture 2 for High-Risk HPV, and FISH for TERC or Hybrid Capture 2 for High-Risk HPV for the Outcome of CIN3+ in LSIL Patients from Jiang 2010

This forest plot shows, for Jiang 2010 (PMID 20864639), the sensitivity (left plot) and specificity (right plot) of fluorescence in situ hybridization (FISH) testing for TERC, Hybrid Capture 2 (HC2) for human papillomavirus (HPV), or a combination of both results for an outcome of cervical intraepithelial neoplasia (CIN) 3+ (i.e., CIN3 or cervical cancer) in low-grade squamous intraepithelial lesion (LSIL) specimens. Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. See Table 6 for details of the study.

MYC=myelocytomatosis oncogene, TERC=telomerase RNA component gene.

Figure 14 is a forest plot showing the sensitivity and specificity of fluorescence in situ hybridization (FISH) testing for TERC versus Hybrid Capture 2 for human papillomavirus (HPV) versus FISH + Hybrid Capture 2 in patients with low-grade squamous intraepithelial lesion (LSIL) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 3+ (i.e., CIN3 or cervical cancer). Point estimates are again for the Jiang 2010 study, for each of the three test combinations; horizontal lines denote 95 percent confidence intervals. With FISH testing alone, the sensitivity was lower than for the other two test combinations (0.83 vs. 0.96 and 1.00) and the specificity appears to be significantly higher (0.77 vs. 0.16 and 0.19).

#### ASCUS

##### FISH for TERC or MYC

The data on FISH for TERC in women with ASCUS were too sparse to pool for purposes of a meta-analysis. There were only three studies, one of which included patients positive for HPV.87

Only two of these three studies, both testing for TERC only (not MYC), provided data for the outcome of CIN2+.49,87 The sensitivity and specificity in these studies is plotted in Figure 15. Li 2011 demonstrated the higher sensitivity and specificity (0.82 and 0.93, respectively) with Jiang 2010 showing similar results with overlapping confidence intervals.

Figure 15 Sensitivity and Specificity of FISH Testing for TERC in ASCUS Patients for an Outcome of CIN2+

This forest plot shows the sensitivity (left plot) and specificity (right plot) of fluorescence in situ hybridization (FISH) testing for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2 or CIN3 or cervical cancer) in atypical squamous cells of undetermined significance (ASCUS) specimens. Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. The PubMed identifier is listed in square brackets for each study. See Table 6 for details for each study.

TERC=telomerase RNA component gene.

Figure 15 is a forest plot showing the sensitivity and specificity of fluorescence in situ hybridization (FISH) testing for TERC in patients with atypical squamous cells of undetermined significance (ASCUS) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2, CIN3, or cervical cancer). Point estimates for the two studies are shown as black circles; horizontal lines denote 95 percent confidence intervals. The range of sensitivity estimates was 0.75 to 0.82 and for specificity estimates was 0.87 to 0.93.

All three studies provided data for the CIN3+ outcome.49,87,88 Sokolova 2007 examined TERC or MYC. Sensitivities ranged from 0.25 (in Sokolova 2007) to 0.87 (in Li 2011) (Figure 16). The estimates for Sokolova 2007 were imprecise, which may reflect the small sample size (N=14). Point estimates for specificities fell into a more narrow range from 0.67 to 0.89 percent, with Li 2011 reporting the highest estimate.

Figure 16 Sensitivity and Specificity of FISH Testing for TERC or MYC in ASCUS Patients for an Outcome of CIN3+

This forest plot shows the sensitivity (left plot) and specificity (right plot) of fluorescence in situ hybridization (FISH) testing for an outcome of cervical intraepithelial neoplasia (CIN) 3+ (i.e., CIN3 or cervical cancer) in atypical squamous cells of undetermined significance (ASCUS) specimens. Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. The PubMed identifier is listed in square brackets for each study. See Table 6 for details for each study.

MYC=myelocytomatosis oncogene, TERC=telomerase RNA component gene.

Figure 16 is a forest plot showing the sensitivity and specificity of fluorescence in situ hybridization (FISH) testing for TERC in patients with atypical squamous cells of undetermined significance (ASCUS) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 3+ (i.e., CIN3 or cervical cancer). Point estimates for the three studies are shown as black circles; horizontal lines denote 95 percent confidence intervals. The range of sensitivity estimates was 0.25 to 0.87 and for specificity estimates was 0.67 to 0.89.

##### FISH for TERC versus Other Tests

Jiang 2010 also provided comparative information on test performance in ASCUS patients by comparing sensitivity and specificity for FISH testing and Hybrid Capture 2 testing alone versus in combination (presumably with a positivity defined as a positive result on either FISH or Hybrid Capture 2) in ASCUS patients for CIN2+ and CIN3+.49 The results (Figure 17 and 18) were similar to the corresponding findings in LSIL patients (Figures 13 and 14), in that the combination of tests was most sensitive for both CIN2+ and CIN3+ and FISH testing alone was the most specific. (Again we presumed that the combined test was considered positive if either FISH or Hybrid Capture 2 was positive, although the study is not entirely clear in this regard.) As expected, estimates of sensitivity were generally more precise (i.e., had narrower CIs) for the CIN2+ outcome because more patients are classified as being affected using this broader definition of disease as compared with the narrower CIN3+ definition.

Figure 17 Sensitivity and Specificity of FISH Testing for TERC, Hybrid Capture 2 for High-Risk HPV, and FISH for TERC or Hybrid Capture 2 for High-Risk HPV for the Outcome of CIN2+ in ASCUS Patients from Jiang 2010

This forest plot shows, for Jiang 2010 (PMID 20864639),. the sensitivity (left plot) and specificity (right plot) of fluorescence in situ hybridization (FISH) testing for TERC, Hybrid Capture 2 (HC2) for human papillomavirus (HPV), or a combination of both results for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2 or CIN3 or cervical cancer) in atypical squamous cells of undetermined significance (ASCUS) specimens. Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. See Table 6 for details of the study.

TERC=telomerase RNA component gene.

Figure 17 is a forest plot showing the sensitivity and specificity of fluorescence in situ hybridization (FISH) testing for TERC versus Hybrid Capture 2 for human papillomavirus (HPV) versus FISH + Hybrid Capture 2 in patients with atypical squamous cells of undetermined significance (ASCUS) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2, CIN3, or cervical cancer). Point estimates are for the Jiang 2010 study, for each of the three test combinations; horizontal lines denote 95 percent confidence intervals. With FISH testing alone, the sensitivity was lower than for the other two test combinations (0.75 vs. 0.89 and 0.96) and the specificity appears to be significantly higher (0.87 vs. 0.42 and 0.45).

Figure 18 Sensitivity and Specificity of FISH Testing for TERC, Hybrid Capture 2 for High-Risk HPV, and FISH for TERC or Hybrid Capture 2 for High-Risk HPV for the Outcome of CIN3+ in ASCUS Patients from Jiang 2010

This forest plot shows the sensitivity (left plot) and specificity (right plot) of fluorescence in situ hybridization (FISH) testing for TERC, Hybrid Capture 2 (HC2) for human papillomavirus (HPV), or a combination of both results for an outcome of cervical intraepithelial neoplasia (CIN) 3+ (i.e., CIN3 or cervical cancer) in atypical squamous cells of undetermined significance (ASCUS) specimens. Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. See Table 6 for details of the study.

TERC=telomerase RNA component gene.

Figure 18 is a forest plot showing the sensitivity and specificity of fluorescence in situ hybridization (FISH) testing for TERC versus Hybrid Capture 2 for human papillomavirus (HPV) versus FISH + Hybrid Capture 2 in patients with atypical squamous cells of undetermined significance (ASCUS) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 3+ (i.e., CIN3 or cervical cancer). Point estimates are again for the Jiang 2010 study, for each of the three test combinations; horizontal lines denote 95 percent confidence intervals. With FISH testing alone, the sensitivity was lower than for the other two test combinations (0.82 vs. 0.93 and 0.99) and the specificity appears to be significantly higher (0.77 vs. 0.35 and 0.40).

#### HPV 16 or 18

The data on FISH for HPV 16 or 18 in women with LSIL or ASCUS were too sparse to pool for purposes of meta-analysis; there were only three studies.75,83,88

##### LSIL

All three studies provided data for the sensitivity and specificity of FISH for HPV 16 or 18 in LSIL patients for the CIN2+ outcome (Figure 19). The sensitivities ranged from 0.75 to 0.81 percent, with Sokolova 2007 reporting the highest estimate. The specificities ranged from 0.00, in Hesselink 2004, to 0.88, in Fujii 2008. The CIs were overlapping because of imprecise estimates and the point estimates of specificity were very heterogeneous, possibly reflecting nonoverlapping HPV probes being detected.

Figure 19 Sensitivity and Specificity of FISH Testing for HPV 16 or 18 in LSIL Patients for an Outcome of CIN2+

This forest plot shows the sensitivity (left plot) and specificity (right plot) of fluorescence in situ hybridization (FISH) testing for human papillomavirus (HPV) 16 or 18 for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2 or CIN3 or cervical cancer) in low-grade squamous intraepithelial lesion (LSIL) specimens. Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. The PubMed identifier is listed in square brackets for each study. See Table 6 for details for each study.

Figure 19 is a forest plot showing the sensitivity and specificity of fluorescence in situ hybridization (FISH) testing for human papillomavirus (HPV) in patients with low-grade squamous intraepithelial lesion (LSIL) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2, CIN3, or cervical cancer). Point estimates for the three studies are shown as black circles; horizontal lines denote 95 percent confidence intervals. The range of sensitivity estimates was 0.75 to 0.81 and for specificity estimates was 0.00 to 0.88.

For the outcome of CIN3+, reported in two studies, Hesselink 2004 and Sokolova 2007 reported similar sensitivities (0.83 and 0.80, respectively) with wide, overlapping CIs (Figure 20). The specificity data were less congruent, with 0.42 specificity in Sokolova 2007 but only 0.17 specificity in Hesselink 2004. However, the 0.17 estimate had a wide CI that included the 0.42 estimate.

Figure 20 Sensitivity and Specificity of FISH Testing for HPV 16 or 18 in LSIL Patients for the Outcome of CIN3+

This forest plot shows the sensitivity (left plot) and specificity (right plot) of fluorescence in situ hybridization (FISH) testing for human papillomavirus (HPV) 16 or 18 for an outcome of cervical intraepithelial neoplasia (CIN) 2+ (i.e., CIN2 or CIN3 or cervical cancer) in low-grade squamous intraepithelial lesion (LSIL) specimens. Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. The PubMed identifier is listed in square brackets for each study. See Table 6 for details for each study.

Figure 20 is a forest plot showing the sensitivity and specificity of fluorescence in situ hybridization (FISH) testing for human papillomavirus (HPV) in patients with low-grade squamous intraepithelial lesion (LSIL) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 3+ (i.e., CIN3 or cervical cancer). Point estimates for the two studies are shown as black circles; horizontal lines denote 95 percent confidence intervals. The range of sensitivity estimates was 0.80 to 0.83 and for specificity estimates was 0.17 to 0.42.

##### ASCUS

One study examined FISH for HPV 16 or 18 in ASCUS patients for the CIN2+ outcome.75,88 Hesselink 2004 demonstrated a sensitivity of 1.00 (95% CI 0.48, 1.00), and reported 0.50 specificity (95% CI 0.18, 0.90).

Two studies examined FISH for HPV 16 or 18 for the outcome of CIN3+ (Figure 21). Again Hesselink 2004 showed the higher sensitivity with CIs overlapping those of the Sokolova 2007 estimate. For specificity, however, the Sokolova 2007 estimate was higher. The CIs were overlapping and wide.

Figure 21 Sensitivity and Specificity of FISH Testing for HPV 16 or 18 in ASCUS Patients for an Outcome of CIN3+

This forest plot shows the sensitivity (left plot) and specificity (right plot) of fluorescence in situ hybridization (FISH) testing for human papillomavirus (HPV) 16 or 18 for an outcome of cervical intraepithelial neoplasia (CIN) 3+ (i.e., CIN2 or CIN3 or cervical cancer) in atypical squamous cells of undetermined significance (ASCUS) specimens. Point estimates are shown as black circles and are listed to the right of the plot; horizontal lines denote 95% confidence intervals, which are listed in parentheses to the right of the plot after the point estimate. The PubMed identifier is listed in square brackets for each study. See Table 6 for details for each study.

Figure 21 is a forest plot showing the sensitivity and specificity of fluorescence in situ hybridization (FISH) testing for human papillomavirus (HPV) in patients with atypical squamous cells of undetermined significance (ASCUS) on cytology, for an outcome of cervical intraepithelial neoplasia (CIN) 3+ (i.e., CIN3 or cervical cancer). Point estimates for the two studies are shown as black circles; horizontal lines denote 95 percent confidence intervals. The range of sensitivity estimates was 0.25 to 1.00 and for specificity estimates was 0.44 to 0.67.

### Clinical Validity in HPV-Positive Normal Cytology Samples

We found no relevant data in groups of women who were HPV test positive but had normal cytology.

### Assessment of Risk of Bias and Completeness of Reporting for Individual Studies

Our assessment of study quality and reporting for Key Question 3 studies of clinical validity was based on 18 questions related to assay performance and reporting thereof. Appendix E shows scoring of each of the 10 studies for each item, and Figure 22 shows the aggregated results. In general, study reporting was fair at best. Few studies reported information of recruitment and study design (questions S1–S3 in Appendix E, question B1 in Figure 22), although reporting of information on the index tests and references standards was generally adequate (questions S4–S5, and S6–S7 in Appendix E, questions B2 and B3 in Figure 22). Data on flow and timing was sparsely reported (questions S8 and S9 in Appendix E). All patient received the same reference standard (question S10 in Appendix E), but inclusion of all patients was complete only in 50 percent of studies (question S11 in Appendix E), resulting in variable clarity and bias resulting from patient flow (question B4, Figure 22).

Overall, the reporting was frequently unclear, impeding the assessment of the risk of bias (Figure 22). In contrast, concern regarding the applicability of studies to Key Question 3 was uniformly low, given the inclusion criteria for these studies.

Figure 22 Risk of Bias and Applicability of All 10 Studies of Clinical Validity of FISH Testing with TERC, MYC, or HPV 16 or 18 Probes

The items are as follows:

B1=Risk of bias: Could the selection of patients have introduced bias?

B2=Risk of bias: Could the conduct or interpretation of the index test have introduced bias?

B3=Risk of bias: Could the reference standard, its conduct, or its interpretation have introduced bias?

B4=Risk of bias: Could the patient flow have introduced bias?

A1=Concerns about applicability: Concerns that the included patients do not match the review question?

A2=Concerns about applicability: Concerns that the index test, its conduct, or its interpretation differ from the review question?

A3=Concerns about applicability: Are there concerns that the target condition as defined by the reference standard does not match the review question?

FISH=fluorescence in situ hybridization, HPV=human papillomavirus, MYC=myelocytomatosis oncogene, TERC=telomerase RNA component gene.

Figure 22 is a horizontal bar chart showing the percentages of the 10 studies using fluorescence in situ hybridization (FISH) with a probe for TERC or human papillomavirus (HPV) that were scored as having a low, high, or unclear risk of bias for each three questions and as having low, high, or unclear applicability for each of three other questions. The questions were modified from the QUADAS (Quality Assessment of Diagnostic Accuracy Studies) 2 instrument. All studies were judged to have low applicability; most were scored as having unclear risk of bias.

### Strength of Evidence

The strength of evidence for the studies on clinical validity reviewed for Key Question 3a was rated as low. The studies were generally small. The number of comparisons for each pair test–outcome pair was low. Reporting on items used for quality assessment was often unclear, yielding overall low methodological quality. Point estimates were heterogeneous. The CIs were often overlapping because of imprecise estimates. Across studies of FISH tests for HPV 16 or 18 (among other types), the panels of HPV probes used did not overlap, resulting in clinical heterogeneity.

Overall, the lower 95 percent confidence limit for sensitivity and specificity spanned 0.5 in a high proportion of studies, indicating that the test results may not distinguish between the presence or absence of FISH signals beyond chance. Thus, overall we have low confidence that the estimated clinical validity of the FISH test represents its true validity. The evidence was considered to be direct for clinical validity since the studies examined CIN2 or 3, which are meaningful outcomes for decisionmaking.

#### Key Question 3b How similar are the spectrum and prevalence of the histopathological abnormalities and cervical cancers between the studies and Medicare beneficiaries?

To address this question, we conducted a focused review for information on population-based prevalence of CIN2+ and CIN3+, stratified for LSIL or ASCUS in Medicare beneficiaries. We did not find any evidence. Further, the primary studies did not provide any unbiased estimates.

#### Key Question 4 What are the clinical utility and harms for ISH tests in cervical cytology?

No studies compared patient care strategies resulting from different test thresholds or different combinations of ISH or non-ISH tests. This is not surprising, since ISH testing is not currently used in practice. Potential harms associated with colposcopy and biopsy include transient cervical bleeding and discharge or infection with fever and moderate-to-severe pain. Treatment with cervical conization can be complicated by cervical incompetence, resulting in fetal prematurity or infertility. An ablative procedure can also complicate subsequent testing for cervical cancer, as it makes it more difficult to visualize any lesions.

Harms from false positive findings are anxiety and unnecessary procedures. Harms from false negative findings are the missed opportunity for early and potentially curative treatment. These potential harms highlight the need for enhancing diagnostic accuracy.