# Methods

The methods for this TA follow the methods suggested in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews52 (hereafter referred to as the Methods Guide; available at www.effectivehealthcare.ahrq.gov/methodsguide.cfm). We also referred to AHRQ’s Methods Guide for Medical Test Reviews.53

## Literature Search Strategy

### Key Question 1 (Horizon Scan) and Scope Refinement

The four Key Questions and the guiding analytic frameworks are described in the Background section above. Briefly, Key Question 1 asked what ISH tests have been examined with what frequency in studies of cervical cytology or histology. This horizon scan served to focus the subsequent detailed evidence review on the most commonly studied ISH tests, namely ISH tests for TERC, MYC, or HPV 16 or 18. Key Question 2 examined analytic validity of these ISH tests, that is, the associations between ISH tests and reference tests for the corresponding chromosomal abnormality. Key Question 3 examined clinical validity of these ISH tests, specifically the clinical validity of these ISH tests on cervical cytology for high-grade CIN or cervical cancer. Key Question 4 examined the comparative effectiveness of ISH testing on clinical utility and possible harms.

### Search Strategy

The search was conducted in MEDLINE^®^, SciVerse Scopus (including Embase) (Elsevier), and the Cochrane Central Register of Controlled Trials and had no language restrictions (Appendix A). Key words included terms related to the test of interest (in situ hybridization) and terms related to cervical cancer or abnormalities (cervical, precancerous, neoplasm, and cervical intraepithelial neoplasia). The first search was performed on November 7, 2011; the update search was conducted on July 12, 2012. We also searched the sections on gynecologic cancer for the past 2 years of proceedings of major gynecology and oncology conferences (e.g., ACOG, the American Society of Clinical Oncology, and the past year of the ASCCP) to identify recent but not yet published studies. We asked our technical experts to inform us of any potentially relevant articles. We did not contact authors for additional data.

### Eligibility Criteria

The population of interest was women eligible for cervical cancer screening. The context was evaluation for cervical cancer after an abnormal screening test. Studies were eligible if they provided relevant data on cervical tissue samples from at least 10 women examined with ISH tests in a clinical or research setting

For Key Question 1, we included studies that described any ISH testing and mentioned cervical cytologic grade (e.g., ASCUS, LSIL, or normal cytology in combination with a positive HPV test) or cervical histologic grade or cancer stage (e.g., CIN or SCC). We excluded studies of cervical cell lines and reviews without primary data. We tabulated the frequency of studies for all ISH test probes examined in cervical cytology or histology specimens to identify those probes most frequently studied.

For Key Question 2a, we included any study that examined an ISH test for TERC, MYC, HPV 16 or HPV 18 (with or without additional probes) in cervical cytology or histology specimens and compared these ISH tests with a non-ISH reference test. We included studies that applied both ISH and reference test in the same cervical specimen, either cytologic or histologic, regardless of classification.

For TERC or MYC ISH tests, we looked for a DNA-based reference test for the same chromosomal abnormality. For HPV 16 or 18 ISH tests, we did not restrict the reference test to only those detecting nuclear DNA and instead accepted any “reference” test for HPV, including polymerase-chain-reaction (PCR) or Hybrid Capture 2 tests. Neither ISH tests nor reference tests for HPV were restricted to only HPV 16 or 18. Instead, they could test for panels of high-risk HPV genotypes. Further, there could be variability between the specific HPV genotypes targeted by ISH and reference tests. Studies had to provide data that allowed for the reconstruction of 2×2 tables for the results of index and reference tests.

Given the imperfection of HPV reference tests in terms of lack of specificity for intranuclear DNA and the variable overlap of HPV genotypes between ISH and reference tests, we described the agreement between tests as the percent of those with concordant results (both positive or both negative) divided by the number of all samples tested.

For Key Questions 2b–f, we reviewed studies eligible for Key Questions 2a, 3, or 4 for pertinent narrative or quantitative information on reliability and reproducibility of ISH tests and possible factors interfering with analytic test performance.

For Key Question 2g, we conducted a focused search for literature on the prevalence of the markers detected by ISH by age or race/ethnicity in the United States. PCR and Hybrid Capture 2 for HPV were the reference tests identified in studies reviewed for Key Question 2a. For Key Question 3a, we included any study that examined ISH testing for TERC, MYC, HPV 16, or HPV 18 (alone or in combination with other probes) in cervical cytology samples to detect high-grade CIN or cervical cancer (or related clinical outcomes). Cervical cytology had to be stratified by cytologic classification, and we extracted ISH findings for each of the following groups: ASCUS, LSIL, ASCUS and LSIL along with HPV status, and normal cytology if HPV positive. While the Bethesda nomenclature has evolved to divide ASCUS into ASC-US and ASC-H, we were limited to using ASCUS as the term was defined in the studies. If the study differentiated ASC-US and ASC-H, we included results for ASCUS only.

Histology outcomes had to be classified as CIN according to the Bethesda classification system and had to be expressible as either CIN3+ (i.e., CIN3 or cervical cancer) or CIN2+ (i.e., CIN2, CIN3, or cervical cancer). Studies included in this review had not uniformly adopted the recently published LAST nomenclature to categorize histology into HSIL or LSIL. Studies had to provide data that allowed for tabulation of 2×2 tables showing the relation of ISH test results and histologic results (CIN2+ or CIN3+) to calculate measures of clinical validity, including sensitivity and specificity. We also looked within each study for comparisons of clinical validity for different test combinations that included ISH tests.

For Key Question 3b, we conducted a focused review for information on the population-based prevalence of CIN2+ and CIN3+ stratified for LSIL or ASCUS in Medicare beneficiaries. We also looked for prevalence in subgroups by age, and race/ethnicity.

For Key Question 4, we searched for studies that compared patient management strategies using different screening or testing algorithms. We considered strategies that compare different test thresholds or different combinations of ISH and/or non-ISH tests. Outcomes of interest were impacts on diagnostic thinking, evaluation, and management and clinical outcomes.

### Study Selection

For Key Question 1, each abstract was screened using Abstrackr,54 singly by one of three reviewers, and queries were addressed at group meetings. For Key Questions 2 through 4, we further screened studies identified in the horizon scan based on their eligibility for these questions.

Full-text articles were retrieved for all potentially relevant abstracts. Studies excluded during full-text screening for Key Questions 2 through 4 and reasons for rejection are given in Appendix B. We ran an updated literature search using the same search strategy, on July 12, 2012, and added new eligible studies to the report.

### Data Extraction

Data extracted by one reviewer were confirmed by at least one other reviewer, and queries or disagreements were resolved at meetings of the entire project team. Data were extracted into data tables in Excel or Microsoft Word that were customized for the question and piloted on several studies, with revision as necessary. For all studies we extracted the author, year of publication, journal, PMID, and country. For Key Question 1, we extracted data on study design. For each cohort or study group, we captured the number of women tested with ISH and the type of the specimen (cytologic or histologic). The sampling strategy was categorized as random, systematic (e.g., inclusion of every third patient), stratified (by any factor), convenience (i.e., using available specimens), or not described. Setting was described as screening, testing/diagnosis (i.e., followup for abnormal screening result), “mixed” (screening and/or testing/diagnosis), or not described. We captured the mean or median age and range. We categorized the probes as non-HPV or HPV and extracted the probe composition or kit name and manufacturer name and location. Finally, we described whether the study contained information on associations of probe results with cytologic grade, histologic grade, clinical outcomes, or reference tests for non-HPV or HPV (for analytic validity).

For Key Question 2, we further extracted information on the ISH assay methods, the reference standard, and the probe(s) used. We looked for information on thresholds or quantitation methods used for ascertaining positive, negative, and indeterminate results; blinding; and information on quality control, reproducibility, and factors affecting test performance, such as tissue sampling, sample handling, or variability due to operator or laboratory. Results from ISH testing compared with the reference test were captured in 2×2 tables or as sensitivity and specificity with 95 percent confidence intervals.

For Key Question 3, we extracted information on ASCUS and LSIL samples and recorded any information on HPV status in these cohorts. We also extracted data from samples of normal cytology with a positive HPV test. Results from ISH testing compared with high-grade CIN outcomes were captured in 2×2 tables or as sensitivity and specificity with 95 percent confidence intervals. For clinical outcomes we planned to record what clinical end points were examined, the mode of ascertainment, and measurements of association or risk. We recorded whether assessors were blinded to ISH result and grading scale used. We extracted information on study design, including power or estimated effect size, and time period between index test and reference test or duration of followup period.

For Key Question 4, we planned to extract information on populations, inclusion and exclusion criteria, description of testing and management strategies, study design, outcome definition, and results.

## Assessment of Risk of Bias and Completeness of Reporting for Individual Studies

Each included study was assessed for study quality according to methods for evaluating study quality within the EPC Program.52,55,56 For Key Question 2, we graded each study according to 11 items, based on an approach for assessing quality and reporting for studies on analytic validity recently proposed by Sun et al.57 in an AHRQ Methods Report. We adapted the questions to those pertinent to the project. We showed the aggregate of responses across studies for each question (as low risk of bias, high risk of bias, or not reported).

For Key Question 3, study quality was assessed according to the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) 2 instrument, 58 which builds on the validated QUADAS-2 list of quality items59–61 for systematic reviews of medical tests. Briefly, the tool assesses four domains for risk of bias related to 1) patient selection, 2) index test, 3) reference standard test (outcome), and 4) flow and timing. After scoring each item, a summary risk-of-bias assessment is performed for each of the four domains. We show the aggregate of responses to each methodological quality item (as Yes, No, or Unclear) across studies. For Key Question 4, we planned to use the Cochrane risk of bias tool.62,62 For all risk of bias assessment, we scored items as “unclear” or “not reported” if they were not clearly addressed in the article.

## Data Synthesis

For Key Question 1, we summarized the included studies graphically and narratively. For Key Questions 2, 3, and 4, we presented summary tables that tabulate the important features of the study populations, design, index and reference tests or outcome, and results. We performed meta-analysis of sensitivity and specificity if the data were sufficiently clinically homogeneous and amenable to statistical pooling.

For Key Question 2, we calculated agreement between the tests used in each study. Percent agreement is the percentage of all concordant test pairs (both positive and negative) divided by all test pairs. For Key Question 3, we calculated sensitivity and specificity of ISH for CIN2+ or CIN3+. We adjudicated ISH results related to “polyploidy” found with a control probe. A result of polyploidy for the centromere of chromosome 3, which is sometimes used as a control for TERC, was considered a negative ISH test. Similarly, when the control was the centromere of chromosome 7, polyploidy was considered negative. In contrast, since studies in other malignancies have shown that one mechanism of MYC amplification is duplication of the whole chromosome rather than the MYC region alone,63 we counted a ISH result of polyploidy of centromere 8 as positive for ISH tests for MYC.

We also reviewed all studies included for Key Question 3 for within-study comparisons of clinical validity with various combinations of ISH and non-ISH tests, to address Key Question 4.

Whenever possible, we present exact (binomial) 95 percent confidence intervals (CIs) for proportions (e.g., sensitivity, specificity, percent agreement). When at least five studies reported information on the clinical validity of a test for the same diagnostic outcome, we performed meta-analysis to quantitatively synthesize findings. We used a bivariate random effects model with the exact binomial likelihood to account for potential negative correlation of sensitivity and specificity across studies(e.g., due to threshold effects).64,65 All analyses were performed using Stata IC, version 12.1 (Stata Corp., College Station, TX).

## Grading the Strength of Evidence

For our survey of the literature on the most commonly used ISH probes in Key Question 1, no grading was performed. Neither did we assess strength of evidence for Key Question 2, because technical test performance does not directly inform medical decisions (it is, however, a prerequisite for the clinical use of tests).55 Instead, we summarized our observations on the state of the literature, and in particular its limitations, in narrative form.

For Key Question 3, we followed the Methods Guide 52,66 to evaluate the strength of evidence with respect to four domains: risk of bias, consistency, directness, and precision. Risk of bias relied on the overall summary of the quality and reporting assessed with the QUADAS-2 tool. It was summarized as low, high, or unclear. We rated the consistency of the data as no inconsistency, inconsistency present, or not applicable (if there is only one study available). We did not use rigid counts of studies as standards of evaluation (e.g., four of five studies agree, therefore the data are consistent); instead, we assessed the direction, magnitude, and statistical significance of all studies and made a determination. We planned to describe our logic where studies were not unanimous. We assessed the directness of the evidence as direct (rather than indirect) for clinical validity given the choice of high-grade CIN or invasive cancer as the outcome of interest. This is an intermediate outcome with clinical significance in the evaluation for cervical cancer as the finding of high-grade CIN results in the recommendation for colposcopy, even though it is still only indirectly related to subsequent clinical outcomes, such as cancer related morbidity and mortality. Finally, we assessed the precision of the evidence as precise or imprecise on the basis of the degree of certainty surrounding each effect estimate. A precise estimate is one that allows for a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions (e.g., both clinically important superiority and inferiority—a situation in which the direction of effect is unknown) and that therefore precludes a conclusion.

In addition, for Key Question 3, we also rated the body of evidence on the basis of four strength of evidence levels: high, moderate, low, and insufficient. 52,66 These indicate our level of confidence that the evidence reflects the true effect for the major comparisons of interest.

For Key Question 4, we planned to rate the body of evidence based on risk of bias, consistency, directness, and precision for comparative studies.52,66 However, we found no comparative studies.

## Applicability

We did not assess applicability of studies reviewed for Key Question 2 for analytic validity because they addressed technical test performance, which is not pertinent to the issue of applicability to a patient population.

We did appraise the applicability of studies reviewed for Key Question 3 using the QUADAS-2 applicability items. We also considered how the study characteristics, for example study county, might impact applicability to the general U.S. population of screened women.