# Discussion

## Key Findings and Strength of Evidence

Cervical cancer screening remains an evolving field with ongoing reevaluation of Pap screening practices and the role of HPV testing, as well as development of new technologies, including ISH testing for genetic abnormalities. The key findings of this review and the strength of evidence are summarized in Table 8.

Table 8 Key Findings and Strength of Evidence

Key Question | Population | Test/Assay | Outcome | Strength of Evidence Summary and Comments
1. Horizon scan | Women screened or tested for cervical cancer | Any ISH test | NA | SOE=NA 135 Articles described use of an ISH probe on cervical cytology or histology samples; - 31 Studies used ISH for TERC; 7 of these examined both TERC and MYC; - 91 Studies used ISH for HPV 16; 87 of these studies examined both HPV 16 and 18; - On the basis of these findings, we focused of the subsequent review on ISH for TERC, MYC, HPV 16, or HPV 18
2. Analytic validity | Women screened or tested for cervical cancer | Any ISH test for TERC, MYC, HPV 16, or HPV 18 | Agreement with reference test | SOE=NA No studies compared ISH test for TERC or MYC with DNA-based reference test 14 Studies compared ISH tests for HPV 16 or 18 (among other types) with various reference tests (mostly PCR and Hybrid Capture 2). Agreement was variable, indicating differences in measurement techniques between ISH and reference tests, as well as nonoverlapping panels of HPV probes. Assessment of study quality shows deficiencies in reporting, which may indicate low study quality. Overall, evidence for analytic validity of various ISH assays was limited.
| | | Thresholds | SOE=NA 14 Studies included for KQ2 and 10 studies included for KQ3 were examined for information on thresholds of positivity on ISH testing.; - Thresholds for ISH tests with TERC or MYC probes consisted of variable counts of signal-positive cells (three or more) and a range of different control probes for centromere or chromosome numbers.; - Test positivity for HPV DNA was dichotomized as detection versus no detection in most studies (except for one, which used a cutoff of 30 cells as positivity for episomal infection).; Two other studies provided information on threshold determination of FISH for TERC in samples from normal women across four laboratories (one in 1 study and three in the other); the value for a positive result ranged from 5.2–6.4 percent of cells with an abnormal signal (statistical comparison ND).
| | | Other preanalytic issues | SOE=NA For questions related to preanalytic issues impacting analytic validity, the data were sparse or not informative.
| | | Prevalence of genetic marker | SOE=NA No direct evidence for prevalence of the markers detected by ISH (i.e., TERC, MYC, HPV 16, and HPV 18) in US Medicare beneficiaries.
3a. Clinical validity | Women screened or tested for cervical cancer with finding of LSIL or ASCUS on cytology, with or without HPV infection | Any ISH test for TERC, MYC, HPV 16, or HPV 18 | CIN2+ or CIN3+ | SOE=low 10 Studies provided information on clinical validity of FISH tests for CIN2+ or CIN3+. Of these, 8 provided results for FISH on TERC (3 tested for TERC or MYC) and 3 studies provided results for FISH for HPV 16 or 18 (1 study tested both probe types, separately). In one study all women were HPV positive (type not reported); HPV status in the other studies was not known. Meta-analysis of 7 studies of TERC or MYC in LSIL for CIN2+ found summary sensitivity of 0.76 (95% CI 0.60, 0.86) and summary specificity of 0.79 (95% CI 0.50, 0.93). Meta-analysis of 5 studies of TERC or MYC in LSIL for CIN3+ found summary sensitivity of 0.78 (95% CI 0.65, 0.87) and summary specificity of 0.79 (95% CI 0.51, 0.93). 2 Studies compared different test combinations.; - One compared results of FISH for TERC, Hybrid Capture 2 for high-risk HPV, and either test. FISH for TERC alone showed lower sensitivity but higher specificity than the combination of FISH or Hybrid Capture 2.; - The other study compared three test strategies: FISH for TERC or MYC, Hybrid Capture 2 for high-risk HPV, and FISH for TERC, MYC, or HPV. FISH for TERC or MYC alone showed lower sensitivity but higher specificity than either other test strategy.; For other cytology classifications and tests, the numbers of studies was limited. 3 Studies had data on FISH for TERC (without MYC) in women with ASCUS. One included only samples positive for HPV. There were also only 3 studies with data on FISH for HPV in women with LSIL or ASCUS. Across all studies and tests, there was a trade-off between sensitivity and specificity, which may indicate a threshold effect. However, there was also great clinical heterogeneity across populations and test probes, Assessment of risk of bias showed low study quality or incomplete reporting. There was inconsistency in effect estimates and many were imprecise. The evidence was considered direct for clinical validity. Overall, the strength of evidence was graded as low, failing to show consistently better sensitivity or specificity with FISH testing for identification of CIN2+ or CIN3+ than would be expected by chance.
3a. Clinical validity | Women screened for cervical cancer with finding of LSIL or ASCUS, with or without HPV infection | Any ISH test for TERC, MYC, HPV 16, or HPV 18 | Clinical outcome | SOE=insufficient No studies examined the association of ISH test results with clinical outcomes.
3b. Prevalence of the outcome in comparison to the Medicare population | | NA | Prevalence of disease (CIN2+ or 3+) | SOE=NA No direct evidence for prevalence of CIN2+ or 3+ in US Medicare beneficiaries
4. Clinical utility | Women screened for cervical cancer | Any ISH test for TERC, MYC, HPV 16, or HPV 18 | All clinical outcomes | SOE=insufficient No studies compared patient care strategies among various tests, thresholds, or combinations of ISH or non-ISH tests. Potential harms associated with colposcopy and biopsy are transient cervical bleeding and discharge or infection with fever and moderate-to-severe pain. Cervical conization can be complicated by cervical stenosis or incompetence resulting in fetal prematurity or infertility. An ablative procedure can also complicate subsequent testing for cervical cancer, as it makes it more difficult to visualize any lesions. Harms from false positive findings are anxiety and unnecessary procedures. Harms from false negative findings are the missed opportunity for early and potentially curative treatment.

ASCUS=atypical squamous cells of undetermined significance, CI=confidence interval; CIN=cervical intraepithelial neoplasia, FISH=fluorescence in situ hybridization, HPV=human papillomavirus, ISH=in situ hybridization, KQ=key question, MYC=myelocytomatosis oncogene, NA=not applicable; LSIL=low-grade squamous intraepithelial lesion, NHANES=National Health and Nutrition Examination Survey; PCR=polymerase chain reaction, SOE=strength of evidence, TERC=telomerase RNA component gene, US=United States.

The horizon scan conducted for Key Question 1 led to the subsequent focus on ISH tests for TERC, MYC, HPV 16, or HPV 18 as tests for cervical abnormalities or cancer.

Our review of data on analytic validity for Key Question 2 revealed a paucity of evidence. We found no studies examining the association between ISH for TERC or MYC and another genetic test in cytology or histology samples. For HPV, we identified some studies for which we could examine the correlation between ISH and reference tests, namely PCR and Hybrid Capture 2. However, these tests measure different biological parameters since, unlike ISH, the reference HPV tests are not restricted to detecting nuclear episomal or integrated HPV. (In situ ISH testing for HPV, which is the only ISH that can identify integration into the genome, may add information beyond the most common ISH testing for 13 or 14 types of HPV or ISH for HPV 16 and 18, which only indicate HPV infection, not integration.)

Further, the panels of HPV genotypes tested for by ISH and the reference tests varied and were not completely overlapping. This heterogeneity limits the conclusions that can be drawn about analytic validity. Not surprisingly, the agreement between ISH tests and reference tests was inconsistent across the studies.

Risk of bias assessment of analytic validity studies showed variable detail of reporting, which was particularly poor for the reference tests. Review of the evidence on thresholds for ISH tests also showed incomplete reporting as well as variable thresholds of positivity and chromosomal control probes used. Information on other preanalytic issues was sparse or not informative. The lack of data on reproducibility is a major deficiency in the evidence base. This suggests a need for research to explore thresholds and standardize test procedures.

For Key Question 3 on clinical validity, the strength of evidence for ISH testing was graded as low, failing to show that the addition of ISH tests resulted in better clinical validity. Clinical practice guidelines suggest that ISH is a potential add-on test after initial Pap testing, with subsequent HPV testing, or after initial Pap and HPV cotesting. In this context, it is more desirable for ISH to show high specificity than high sensitivity. In our review, FISH testing did not show consistently increased sensitivity for the identification of CIN2+ or CIN3+ on histology, although it was more specific than other tests or test combinations. However, we cannot conclude that ISH testing would increase clinical validity of an overall screening strategy. As compared with FISH or Hybrid Capture 2 testing for HPV, FISH for TERC or MYC alone was more specific and less sensitive than the test combinations.

Regarding Key Question 4, we found no studies examining the association of ISH test results with clinical outcomes. There were also no comparative studies of strategies that include ISH tests that examined clinical utility, which would be of particular interest for colposcopy rates and histology results.

### Comparison with Current Knowledge

ISH tests are not used routinely used in screening for cervical cancer at this point. However, there is a need to improve the clinical validity of screening for cervical cancer. Thus there is a potential role for tests such as ISH. HPV tests for panels of high-risk genotypes have been shown to have a higher sensitivit, but lower specificity that what we found for ISH tests.91 Thus when cotesting is used, add-on tests with greater specificity may be useful. However, HPV testing is evolving, and new reference tests for HPV testing will change the performance of add-on tests. ISH may need to be examined as an alternative to tests that can identify HPV 16 and 18 individually. Further, the recent launch of HPV vaccination in adolescents is expected to change the natural history of HPV associated cervical carcinoma going forward.

### Applicability

Formal appraisal of applicability of the Key Question 3 studies on clinical validity with the QUADAS-2 tool showed no major concern regarding applicability. However, studies included populations from around the world, with variable prevalence of HPV infections, CIN classes, and cervical cancer.

CMS has a particular interest in the Medicare population, whose core beneficiaries are 65 years of age or older. On the basis of the lower incidence of HPV infection and cervical cancer among older women who have undergone adequate screening than among younger women, the 2012 guidelines recommend cessation of screening after the age of 65 years (so long as screening tests were negative in the prior 10 years). Since a notable proportion of Medicare beneficiaries are younger than 65, the findings of the report are still relevant for CMS.

### Implications for Clinical and Policy Decisionmaking

The current evidence base is insufficient to consider routine ISH testing in the clinical scenarios analyzed in the report. Specifically the evidence is insufficient to recommend routine ISH testing for TERC, MYC, HPV 16 or 18 in women screened or tested for cervical cancer with a finding of LSIL or ASCUS on cytology, with or without HPV infection.

### Limitations

Our review is limited to published reports, which usually do not allow for detailed analysis of individual patient data for subgroups of interest. Studies evaluating more than one test approach did not include cross-tabulation of positive and negative test results across all tests. Our review addresses a limited scope based on what was determined to be the most meaningful clinical questions. Given our stringent inclusion criteria for articles, requiring the mention of cytologic or histologic sampling in the abstract, we may have missed studies that could have contributed additional data for the review of analytic validity.

Regarding Key Question 3 on clinical validity of ISH in particular, the identified evidence base was limited. Studies were generally small and those that we could meta-analyze yielded imprecise effect estimates. Study samples often were from sample banks or databanks, limiting the applicability to the screening population. With one exception, the included studies did not unequivocally report or stratify by HPV status. Studies conducted before the Bethesda terminology change that divided ASCUS into ASC-US and ASC-H may have included a mix of ASC-US and ASC-H in their ASCUS group. There was clinical heterogeneity among the results, given the variety of ISH probe panels used across studies and differences between ISH and the DNA-based reference tests. In addition, the reporting of study quality items was deficient. No studies examined risk prediction with ISH or the test’s clinical utility or addressed screening for cervical adenocarcinoma in particular.

### Research Gaps

Our review reveals four major research gaps. First, the assessment of the analytic validity of ISH (Key Question 2) highlights a need to establish common thresholds, probe sets, controls, and procedures. An expert conference may be helpful to agree on common measurement guidelines, a path that was successfully pursued to arrive at the consensus Bethesda classification for cytological abnormalities in cervical cancer. Scoring of ISH slides can be time-consuming. Automated approaches are promising, but in order for ISH to become a routine test, the evaluation of test results needs to be standardized and accelerated.

Second, bigger studies with larger numbers of patients with HSIL are needed to yield more precise estimates.

Third, future research should reflect changes in clinical practice. On the basis of the current guidelines, it can be expected that Pap with reflexive HPV testing or Pap–HPV cotesting will become more widely used. This will require study of the clinical validity of ISH as an add-on test in groups of women characterized as having a normal Pap or ASCUS or LSIL along with a positive or negative HPV test. It is also expected that HPV testing will eventually be able to routinely identify not only high-risk HPV genotypes broadly but also HPV 16 and 18 individually, with the use of either sequential or combined tests. This will require reevaluation of the role of ISH, which we in this review considered as a hypothetical alternative to testing for HPV 16 or HPV 18. Development of automated HPV testing may provide an incentive to explore the performance of up-front HPV testing rather than Pap testing, since testing of cervical cytologic specimens requires a trained human operator. This would generate another constellation in which to study the value of ISH testing added to HPV genotyping.

Fourth, changes in terminology should be followed in future studies, specifically the differentiation between ASC-US and ASC-H and the use of LAST terminology, including p16 staining in ambiguous cases for classifying histology as LSIL or HSIL.

Fifth, further evaluation of clinical validity of ISH should be better designed to achieve this aim. Studies could examine ISH testing for not only a single probe (such as TERC) but also panels of probes, for example for both TERC and HPV. Ideally, large studies would allow for the comparison of multiple tests in order to make it possible to select tests with best analytic validity as well as clinical validity for CIN. However, to measure false negative rates, colposcopy would need to be performed in patients with negative screening tests. Such studies should therefore identify the tests, thresholds, and combinations that are most promising for further evaluation of clinical utility. Efficient exploration of the correct test use (i.e., the testing with the best performance) would again be conducted with several promising tests, thresholds, and test combinations studied simultaneously in a sufficiently large sample on the same specimens and follow patients with routine or test-directed care to assess impacts on diagnostic thinking, evaluation, management, and clinical outcomes. Projecting the clinical utility of different tests may entail modeling of data from different studies in decision analyses.

Lastly, the role ISH testing for detection of adenocarcinoma should be examined. The variability in chromosomal aberrations between squamous-cell cancer and adenocarcinoma suggests that a panel of ISH probes, rather than a single probe, would capture a greater variety of chromosomal changes.

### Conclusions

Our report shows an emerging body of literature on ISH testing for cervical cancer. Although ISH tests are marketed by some laboratories for triaging women with abnormal screening tests, there is a lack of standardization of probes and procedures that needs to be addressed. The role of add-on ISH testing has not been adequately examined in current screening contexts, that is, after HPV and Pap testing. Further, HPV testing is likely to evolve, for example with primary screening for 13 or 14 HPV genotypes or with wider availability of HPV16/18 testing. This will again require reexamination of the role of add-on tests such as ISH and its impact not only on diagnostic utility but also on clinical utility (in particular colposcopy) and on clinical outcomes. Thus, the evidence is currently too immature to suggest the ISH testing for routine practice.