# Background

## Overview

Cervical cancer is a highly preventable disease. Most cases are related to infection with human papillomavirus (HPV).1 Persistent cervical infection with high-risk, oncogenic HPV genotypes is necessary for the development of cervical cancer and its immediate precursor lesion, high-grade cervical intraepithelial neoplasia (CIN).2 Progression is generally slow and screening has the potential to detect precancerous lesions and cancers in early stages, which can be effectively treated. Thus, in the United States, regular screening is recommended for all women between the ages of 21 and 65 years.3

Incidence and mortality rates for cervical cancer vary globally, depending on the availability of cervical screening and prevention programs. In the United States, which has widespread screening practices, there were more than 12,000 new cases of cervical cancer and 4,220 related deaths in 2011. 1,4

The screening tests currently used in the United States on cervical cell samples include the Papanicolaou (Pap) test to detect cellular changes, as well as tests for high-risk HPV genotypes. Although both tests identify a large proportion of women who harbor high-grade CIN, in a large number of women abnormalities detected on cytology will spontaneously resolve or will not be confirmed on histologic examination by colposcopy. A particular challenge is the management of women with test results of atypical squamous cells of undetermined significance (ASCUS) or low-grade squamous intraepithelial lesions (LSIL) on cytology or those with a normal Pap test but a positive test for high-risk HPV genotypes, since only a fraction of these women will have a finding on colposcopically directed tissue biopsy that warrants treatment. The median percentage of all Pap tests reported by various U.S. laboratories in 2009 for ASCUS ranged from 2.9 to 4.8 percent and for LSIL, from 1.2 to 2.8 percent, depending on the cytology preparation method (according to the College of American Pathologists Laboratory Accreditation Program). 5 Less than one-fifth of women with these findings will have a finding on colposcopically directed biopsy that warrants treatment.6 Colposcopy incurs expense and may be associated with adverse events.7,8Another complication of an ablative procedure is that on subsequent cervical cancer screening, if a screening test comes back abnormal, it can be difficult to visualize the lesion and allow the lesion to be optimally treated.

Thus, testing strategies that can more accurately triage patients to colposcopy are needed, to minimize overtreatment. Tests being marketed and offered by some laboratories include in situ hybridization (ISH) tests to detect chromosomal abnormalities or HPV DNA. This Technology Assessment (TA) examines the role of in situ hybridization (ISH) tests, including fluorescence ISH (FISH), to detect chromosomal abnormalities or HPV DNA on cervical cytologic specimens and their clinical validity for identification of precancerous lesions or cervical cancer.

## Terminology for Cervical Lesions

In the United States, most laboratories use the Bethesda system for reporting cervical cytology (Table 1). The classification system was first developed in 1988 and has been revised several times since, most recently in 2001.^9^ Squamous-cell abnormalities are the most common, although abnormal glandular cells can also be found.

Table 1 The 2001 Bethesda System for Reporting Cervical Cytology10

Specimen Type Indicate: conventional test (Pap test), liquid-based preparation, or other
Specimen Adequacy; - Satisfactory for evaluation (describe presence/absence or endocervical/transformation zone component and any other quality indicators, e.g., partially obscuring blood inflammation, etc.); - Unsatisfactory for evaluation (specify reason); - Specimen rejected/not processed (specify reason); - Specimen processed and examined, but unsatisfactory for evaluation of epithelial abnormality because of (specify reason)
General Categorization (Optional); - Negative for intraepithelial lesion or malignancy; - Other: see Interpretation/Result (e.g., endometrial cells in a woman aged 40 years or older); - Epithelial cell abnormality: See interpretation/Result (specify “squamous” or “glandular” as appropriate)
Interpretation/Result; - Negative for intraepithelial lesion or malignancy (when there is no cellular evidence of neoplasia, state this in the General Categorization above, in the Interpretation/Result section of the report, or both-whether or not there are organisms or other nonneoplastic findings); - Organisms; - Trichomonas vaginalis; - Fungal organisms morphologically consistent with Candida species; - Shift in flora suggestive of bacterial vaginosis; - Bacteria morphologically consistent with Actinomyces species; - Cellular changes consistent with herpes simplex virus; - Other nonneoplastic findings (optional to report; list not inclusive); - Reactive cellular changes associated with; - Inflammation (includes typical repair); - Radiation; - Intrauterine device; - Glandular cells status posthysterectomy; - Atrophy; - Other (list not comprehensive); - Endometrial cells (in a woman aged 40 years or older) (specify if negative for squamous intraepithelial lesion); - Epithelial cell abnormalities; - Squamous cell; - Atypical squamous cells (ASC); - Of undetermined significance (ASC-US); - Cannot exclude HSIL (ASC-H); - Low-grade squamous intraepithelial lesion (LSIL) (encompassing: human papillomavirus/mild dysplasia/cervical intraepithelial neoplasia (CIN) 1; - High-grade squamous intraepithelial lesion (HSIL) (encompassing: moderate and severe dysplasia, carcinoma in situ; CIN2 and CIN3); - With features suspicious for invasion (if invasion is suspected); - Squamous cell carcinoma; - Glandular cell; - Atypical; - Endocervical cells (not otherwise specified or specify in comments); - Endometrial cells (not otherwise specified or specify in comments); - Glandular cells (not otherwise specified or specify in comments); - Atypical; - Endocervical cells, favor neoplastic; - Glandular cells, favor neoplastic; - Endocervical adenocarcinoma in situ (AIS); - Adenocarcinoma; - Endocervical; - Endometrial; - Extrauterine; - Not otherwise specified; - Other malignant neoplasms (specify)
Ancillary Testing Provide a brief description of the test method(s) and report the result so that it is easily understood by the clinician. Automated Review If case examined by automated device, specify device and result
Educational Notes and Suggestions (Optional) Suggestions should be concise and consistent with clinical followup guidelines published by professional organizations (references to relevant publications may be included)

Table 2 Recommendations for Lower Anogenital Squamous Terminology (LAST) for HPV-Associated Lesions).2

Squamous Intraepithelial Lesions
Recommendation:
1. A unified histopathologic nomenclature with a single set of diagnostic terms is recommended for all HPV-associated preinvasive squamous lesions of the lower anogenital tract (LAT)
2. A two-tiered nomenclature is recommended for noninvasive HPV-associated squamous proliferationsof the LAT, which may be further qualified with the appropriate –IN terminology–IN refers to the generic intraepithelial neoplasia terminology without specifying the location. For a specific location, the appropriate complete term should be used. Thus, for an –IN 3 lesion: cervix = CIN3, vagina =VaIN 3, vulva =VIN 3, anus = AIN 3, perianus = PAIN 3, and penis =PeIN
3. The recommended terminology for HPV-associated squamous lesions of the LAT is LSIL and HSIL, which may be further classified by the applicable –IN subcategorization

Histologic changes (those detected on biopsy) are described as cervical intraepithelial neoplasia (CIN). CIN is categorized according to the depth of involvement and the atypicality of the cell into three degrees of severity. CIN1 is considered a low-grade lesion. It refers to mildly atypical cellular changes in the lower third of the epithelium (formerly called mild dysplasia). HPV-induced cytopathic effects (koilocytotic atypia) are often present. CIN2 is considered a high-grade lesion. It refers to moderately atypical cellular changes confined to the basal two-thirds of the epithelium (formerly called moderate dysplasia) with preservation of epithelial maturation. CIN3 is also considered a high-grade lesion, but it refers to severely atypical cellular changes encompassing greater than two-thirds of the epithelial thickness and includes full-thickness lesions (formerly called severe dysplasia or carcinoma in situ). Invasive cancer may also be diagnosed on histology.

Recent consensus recommendations by the LAST initiative aim to unify the terminology for HPV-associated lower anogenital lesions (Table 2).2. This new terminology classifies into a two-tiered system of low-grade squamous intraepithelial lesions (LSIL) and high-grade intraepithelial lesion (HSIL), similar to the Pap testing classification. The pathologist must still determine the CIN category on the basis of what proportion of the epithelium is involved (lower one-third, lower wo-thirds, or full thickness) and then stratify to LSIL or HSIL. CIN1 under the old classification maps to LSIL, and CIN3 maps to HSIL. CIN2 is a biologically equivocal lesion and if this diagnosis is entertained by a pathologist, LAST recommends stratification to high-grade or low-grade disease on the basis of p16 immunohistochemistry. The LAST terminology is not yet broadly used.

Generally, a higher grade of cytology indicates a greater risk for higher-grade histology but cytology may also be associated with both more or less severe histologic findings.

## Natural History of Cervical Cancer

The cervix is the lower narrow portion of the uterus that consists of an ectocervix, lined by squamous epithelium and an endocervix, lined by glandular epithelium. The ectocervix transitions to the vagina inferiorly. The endocervix is superior to the ectocervix and transitions to the endometrial cavity of the uterus. The transition from ectocervical lining to endocervical lining is called the transformation zone.

Infection with sexually transmitted HPV can cause genital warts as well as cervical cancer. HPV infection can be acute or persistent. Acute infection can disappear within 1 to 2 years, most likely because of eradication by the woman’s immune system. Persistent infection can occur in a small number of women who then are at increased risk of developing cancer.11 The risk factors for persistent HPV infection include smoking, a compromised immune system, and possibly coinfection with other sexually transmitted viruses (e.g., herpesvirus).12 Low socioeconomic status is also associated with an increased risk of cervical cancer.13

HPV infection and precancer do not cause symptoms but early genetic and morphologic changes can be seen in cervical cells with various tests. Early detection permits early treatment, which is more likely to be successful than treatment at later stages. Morphologic signs of precancer show up as abnormal-looking cells that can be seen under a microscope in a Pap smear or biopsy sample of cervical tissue. Genetic signs of precancer and HPV infection take the form of chromosomal changes (e.g., extra copies or too few copies of human genes) and the presence of HPV DNA, respectively, both of which can be detected by genetic tests such as ISH and PCR that involve probes (certain molecules) that bind to the DNA of interest. Other co-factors for cancer given infection are multiparity and long-term oral contraceptive use, but so far it is unclear in what stages in the carcinogenic process the co-factors act.

## Epidemiology of Cervical Cancer

### Incidence and Mortality

The incidence of and mortality from cervical cancer have decreased over time in the United States and in other developed countries, as screening has increased.11 In 2012, there were more than 12,000 new cases and 4,220 deaths.1,4 The age-adjusted incidence rate in the U.S. was approximately 15 cases per 100,000 women in 1975 and declined consistently over the next two decades to less than 7 cases per 100,000 women in 2009.^14^ The corresponding rates of death have similarly decreased, with an estimated mortality of more than 5 women per 100,000 in 1975 to just over 2 women per 100,000 in 2009. The incidence remains high in developing countries, however, which carry more than 85 percent of the burden of disease1,15; and cervical cancer remains the second most common cause of cancer deaths among women worldwide.3

Squamous-cell carcinoma (SCC) accounts for about 80 to 90 percent of cases of cervical cancer, with adenocarcinoma accounting for the rest.16 Although adenocarcinoma currently is diagnosed in fewer cases than SCC, its incidence is increasing and it can be harder to detect on Pap testing because distinguishing features for glandular lesions are more subtle and challenging to interpret. Limited sampling may also play a role.

Incidence and mortality from cervical cancer are known to vary among racial/ethnic groups and among age groups in the United States. The incidence and mortality are lower among white women than among nonwhite women.3,11 Hispanic women are most likely to get cervical cancer, followed by blacks, American Indians and Alaskan natives, whites, and Asians and Pacific Islanders.14

Cervical cancer tends to occur in midlife; the median age at diagnosis is 48 years. 14 Most cases are found in women younger than 50 years; few occur in women younger than 20.^11^ Older women still have a risk of developing cervical cancer. More than 20 percent of cases of cervical cancer are found in women over 65 years of age. However, these cases are typically in women who had not been screened regularly for cervical cancer earlier in life.17

Precancer or localized cancer can be treated to prevent progression to cancer or metastasis. Although 91.5 percent of women will survive 5 years when the cancer is localized, only 12.6 percent will survive distant disease. 14

## Role of Human Papillomavirus Infection in Cervical Cancer

### Pathogenesis

HPV testing detects the presence of HPV DNA. Infection with specific high-risk genotypes of HPV is associated with risk for precancer or cancer. Using modern HPV detection methods, 95 to 100 percent of squamous-cell cervical cancer and 75 to 95 percent of high-grade CIN lesions have detectable HPV DNA.18 Many of the more than 150 genotypes of HPV can be divided into “high-risk” and “low-risk” categories on the basis of their association with cervical cancer (Table 3).

Table 3 High-Risk HPV Types. 19

Risk Group | HPV Types
High | 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, 66, 68, 73, 82

HPV=human papillomavirus.

Of the approximately 30 to 40 HPV genotypes that infect the mucosa of the genital tract, 8 (types 16, 18, 31, 33, 35, 45, 52, and 58) are responsible for over 90 percent of cervical cancers and are therefore called “high-risk” genotypes.20–22 Two of these genotypes (16 and 18) are alone responsible for about 70 percent of cervical cancers.22 In the United States, 20 to 44 percent of women are infected with one of the approximately 150 HPV genotypes23 (high risk or other), which may either be cleared by the body or may persist and over time cause precancerous lesions and ultimately malignancy. Recent work (in 2012) has linked HPV-related cervical cancers to abnormalities in a small, discrete population of cells located at the transformation zone of the cervix.24

### Epidemiology of HPV Infection

The Centers for Disease Control and Prevention estimate that nearly 5.5 million new genital HPV cases occur each year in the United States.25 It is estimated that more than 20 million people in the U.S. are infected with HPV at any given time.26

Genital HPV is acquired through sexual and genital skin-to-skin contact. Prevalence generally is greatest within a few years after the median age of first sexual intercourse (which is at 17 years in the United States).3 About 90 percent of HPV infections become undetectable within a year or two.3 Persistence beyond this time period is predictive of CIN3 or more severe disease in the subsequent years. High-risk HPV 16 or 18 causes a greater proportion of adenocarcinomas (about 85 percent of cases) than SCCs (about 70 percent of cases).27(Note that virtually 100 percent of cases of cervical cancer are caused by infection with one of the high-risk HPV genotypes.)

## Cytologic Screening for Cervical Cancer

Screening tests are performed on a sample of cervical cells obtained from scraping the cervix during a speculum examination, called a Pap test. Conventional cervical samples are prepared by smearing the specimen on a slide. Liquid-based preparation involves placing the specimen into a liquid fixative solution (e.g., ThinPrep or SurePath). Both of these preparations are a form of cytologic sample (i.e., the cells are separated from adjoining cells, either spread across the slide or suspended in solution). (This is in contrast with histologic specimens, which are pieces of tissue in which the cells remain intact; histologic tests are not done at the screening stage.)

### Papanicolaou (Pap) Testing

The Pap test is widely performed to screen for precancerous or cancerous changes in cervical cells and is usually reported in the United States according to the Bethesda system (see Table 1 above). LSIL, especially in young women, is generally associated with a transient HPV infection, whereas a finding of high-grade squamous intraepithelial lesion (HSIL) is more likely to be associated with persistent HPV infection and a higher risk of progression to cervical cancer.28

### HPV Testing

HPV testing detects the presence of (i.e., infection with) various types of HPV DNA, even though cervical abnormalities may not be present or may not develop. Testing for high-risk HPV has been proposed in combination with Pap testing or as an add-on test to follow up an abnormal Pap result. If liquid-based cytology sampling is performed, there is typically sufficient specimen left over after Pap testing to permit HPV testing as well. Specimens for HPV testing can also be collected from the endocervix and placed in an HPV test transport medium.29

In clinical practice, HPV test results are generally reported as positive or negative for the high-risk HPV types overall (rather than a specific type). A negative test means simply that no oncogenic HPV types are currently detected or that the patient may have been previously infected with a high-risk subtype and cleared the infection.

Currently there are four tests for high-risk HPV approved by the Food and Drug Administration (FDA) for primary screening as a cotest with Pap screening, all of which detect either 13 or 14 HPV types30:

- The Digene Hybrid Capture 2 High-Risk HPV test (the first to receive FDA approval, in 2003), which identifies the presence of any of 13 high-risk HPV types (HPV 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, and 68) but cannot identify specific types.
- The Cervista™ HPV HR test (approved in 2009), which identifies the presence of any of 14 high-risk HPV types (HPV 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, 66, and 68).
- The Cobas HPV test (approved in April 2011), which detects the presence of HPV 16 or HPV 18 as well as a pooled result for an additional 12 high-risk types (HPV types 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, 66 and 68).
- The APTIMA® HPV assay (approved in October 2011), which detects the presence of any of 14 high-risk HPV types (HPV 16, 18, 31, 33, 35, 39, 45, 51, 52, 56, 58, 59, 66, and 68) by identifying its messenger RNA.

One other FDA-approved test is the Cervista™ HPV 16/18 test. It identifies the presence of the high-risk HPV 16 or HPV 18, the two types that cause most HPV-associated cancers and the most aggressive types of cancer. This test was approved in 2009 only for use in women 30 years of age and older, in whom it is intended as a follow-up test after a less-specific positive HPV screen for the 14 high-risk types and adjunctively with cytology. At the present this test is not widely adopted or available. However, as it is a more specific test than the HPV tests currently used to detect any of 13 or 14 HPV types, it could be a reflex test in some circumstances (see Figures 2–4) and therefore a theoretically credible alternative to non–ISH-based HPV 16/18 testing.

Generally data suggest that the prevalence of HPV infection in cytologic specimens increases with increasing severity of cytologic classification. In the United States in 2007, the prevalence of HPV infection was approximately 13 percent among women with normal cytology, 79 percent among women with low-grade lesions, 85 percent among women with high-grade lesions, and 87 percent among women with cervical cancer.31 Another source claims that 85 to 95 percent of women with LSIL will be positive for HPV.32 Therefore, it adds little to risk stratification in this group. However, HPV testing in individuals with ASCUS is helpful, as the risk of developing high-grade CIN would be considered to be the same in a patient with LSIL as in a patient with ASCUS and HPV positivity.

## Management of Abnormal Screening Results

If abnormal cells are detected on Pap testing, then further evaluation is conducted with a colposcopy, a procedure in which the cervix is viewed at high magnification, and colposcopically directed cervical biopsy.33

Histology allows for triage to either a low or a high-grade lesion, with the latter requiring ablative therapy. Histologic examination is useful because it decreases the number of unnecessary ablative procedures, since some equivocal lesions on cytology will regress spontaneously or be so small that they cannot be identified on colposcopic sampling and presumably do not pose an immediate threat warranting definitive ablative therapies. On the other hand, high-grade lesions diagnosed by cytology have a low false positive rate. Therefore, a “see and treat” approach for patients with HSIL findings on cytology is acceptable. “See and treat” allows an ablation to take place upon the first colposcopic visit and avoids the cost of an additional colposcopic exam and histologic confirmation.

Ablative treatments use loop electrosurgical excision procedure (LEEP), laser therapy, or cryotherapy to remove or destroy the surface layers of the cervix and confirm that no invasive disease is present. More aggressive treatments for cancer include radical hysterectomy with pelvic lymph node dissection or radiation and chemotherapy.

Colposcopy and ablative treatments have adverse outcomes including discomfort, anxiety, risk of subsequent cervical incontinence with fetal loss or prematurity, and financial cost.7,8 Thus, the goal of cervical-cancer screening is to enhance sensitivity and specificity for detecting high-grade CIN (i.e., CIN2 or CIN3) on histopathology in order to maximize the true positive results and minimize the false positive ones.

## Current Guidelines for Cervical Cancer Screening and Treatment

In March 2012, the U.S. Preventive Services Task Force (USPSTF) released new recommendations for screening women for cervical cancer.18 At the same time, the American Cancer Society (ACS), the American Society for Colposcopy and Cervical Pathology (ASCCP), and the American Society for Clinical Pathology (ASCP) jointly published another set of screening recommendations.3

Guidelines issued by the USPSTF suggest screening with a Pap test every 3 years for all healthy women ages 21 through 65 years. The 2012 guidelines by ACS/ASCCP/ASCP 3 recommend cytology testing alone every 3 years, but in women aged 30–65 years, state a preference for HPV and cytology cotesting every 5 years. The guidelines by the ACS, ASCCP, and ASCP give preference to Pap and HPV cotesting, on the basis of evidence from randomized trials showing that cotesting results in earlier detection of high-grade CIN or invasive cancer, and women who have undergone cotesting have a lower risk of high-grade CIN and invasive cancer after the first screening round allowing for screening at less frequent intervals34–36 Because few studies have sufficient numbers of cancer cases to assess cancer risk directly, the guidelines considered the absolute risk of CIN3, including the rare cases of cancer (CIN3+) prior to or at the visit after a given visit, as the best measure of the risk of incident cervical cancer. In addition, cotesting offers greater risk reduction for adenocarcinoma of the cervix and its precursors.

Screening by HPV testing alone (without concurrent or subsequent Pap testing) is not currently recommended in the United States, but several clinical trials outside the United States in resource poor settings have documented the value of “primary HPV screening”—that is, if the HPV test is negative, no other testing is needed, and if the test is positive, cytologic Pap testing is effective for triage because of the high specificity of Pap test findings. Genotype-specific testing for HPV 16 or HPV 16/18 is only recommended as an option in one particular clinical setting: for women who have a normal Pap result and a positive HPV test. In these women, both tests should be repeated at an interval, or alternatively they can undergo genotyping to determine whether they have infection with HPV16 and/or HPV 18. If positive on HPV16/18 testing, then colposcopy is recommended. If negative, then retesting after 1 year is recommended.

Recent guidelines by ACOG19 specify that women with ASCUS on Pap testing and a negative HPV test continue with routine screening as indicated for their age.

All guidelines recommend against screening for cervical cancer in women over the age of 65 years who have had negative results on an adequate number of previous screening tests (with “adequate number” defined as three consecutive negative Pap results or two negative Pap and HPV tests in the prior 10 years, with the most recent within the previous 5 years). Finally, women who have been vaccinated against HPV should follow age specific recommendations as unvaccinated women (i.e., starting at 21 years).

## Principles of ISH

ISH is a technique that is used to detect and localize the presence or absence of a specific genetic sequence in cells using a complementary polynucleotide sequence, the probe. The probe is either directly tagged with a fluorescent compound such as Texas Red (in FISH) or indirectly tagged with biotin (historically) or digoxigenin or dinitrophenol (more recently). After binding to the complementary sequences in the cell, the probes are either visualized under ultraviolet (UV) light (in FISH) or located using antibodies to the chemical tag and visualized using direct light (in chromogenic in situ hybridization [CISH]). Gains of a region are seen as additional spots in the cell, while deletions are seen as a loss of spots. The majority of probes in use are “cocktails” that combine the region of interest with a control probe, and loss or gain is determined with respect to the number of control signals. The technique is used to detect recurrent diagnostic changes in hematological malignancies (such as a deletion in the long arm of chromosome 5 in myelodysplastic syndrome), to look for gene amplification (e.g., HER2/neu gene in breast cancer), and to detect specific gene rearrangements that can be treated with particular drugs (e.g., ALK gene rearrangement in non-small cell lung cancer, translocation 9 and 22 in chronic myeloid leukemia).

The resolution of ISH is limited by the size of the probe available for a region. The majority of commercially available ISH probes range in size from ~100 Kb to ~900 KB and will detect genetic sequence of this size. Smaller sequences will not be detected. Scoring of ISH tests can be automated, reducing the potential for operator errors such as the evaluation of the wrong cell population or the incorrect area of a tumor section. Any ISH final interpretation must be rendered by a pathologist. The technique is reliable but requires appropriate specimen preparation for consistent results.37 Differentiating signals from experimental background can be problematic with CISH, but not with FISH.

The most common tags are nonisotopic (do not involve a radioactive isotope). Nonisotopic ISH (NISH) tests include FISH and chromogenic ISH (one test of which is colorimetric signal-amplified ISH [CSAC-ISH]). ISH tests can be made more sensitive by combination with other techniques such as catalyzed reporter deposition (CARD). Isotopic ISH is not commonly used because the chemical tag is radioactive and requires additional safety and handling procedures.

In the case of ISH involving probes for HPV, the HPV infection can be seen to be episomal, when a uniform HPV signal pattern is observed (contained within and covering the entire nucleus, suggesting the presence of HPV DNA in the nucleus but not yet integrated into the human chromosomes) or integrated, when a punctate signal pattern (consisting of discrete dots) is seen.

## Potential for ISH Tests for Cervical Cancer Screening

ISH has been proposed as an additional noninvasive test on cervical smears to detect chromosomal abnormalities (markers of chromosomal damage) or HPV DNA. ISH testing on cervical specimens is not yet widely established, but some laboratories have developed their own tests, and manufacturers are starting to promote the use of ISH testing to triage women to colposcopy based on their cytology, HPV result, and ISH test finding (e.g., www.cervicaldnadtextest.com/casestudies.php). Quest Diagnostics, a commercial laboratory vendor, now advertises FISH testing for TERC, noting that “women with LSIL or ASC-H Pap results” are appropriate candidates (ASC-H is a category related to and generally less prevalent than ASCUS and stands for atypical squamous cells, cannot exclude HSIL) (http://www.questdiagnostics.com/testcenter/testguide.action?fn=HematOnc/Cervix/TS_CervicalCancer_TERC_FISH.htm).

Human chromosomal abnormalities have been observed in cervical cancers and premalignant stages on DNA-based microarrays. The microarray literature demonstrates that gain of 3q or loss of 3p are frequent changes in cervical cancer.38–48 This is particularly the case for squamous-cell carcinoma, whereas for adenocarcinoma the linkage to chromosomal abnormalities is less strong and if present it is more likely to be associated with gains of 1p, 1q and loss of 4q and 13q.

Chromosome 3 is the site of the telomerase RNA component (TERC) gene, located at band 3q26, which encodes the telomerase RNA component. Telomerase is activated relatively early in the progression to cervical cancer,49 making it a logical target for ISH probes in cervical cancer screening. Another gene of interest implicated in cervical cancer is the myelocytomatosis oncogene (MYC), located on chromosome 8 (band 8q24). MYC has been shown to be a common site of HPV DNA integration,50 specifically by a high-risk type of HPV (HPV 18).51 Thus MYC also is of interest in using ISH testing for chromosomal changes associated with cervical cancer.

Given the prominent role of high-risk HPV infections for cervical cancer development, HPV DNA it is also a potentially informative target for ISH testing. HPV 16 and HPV 18 are the most studied types. This raises the question about the role of ISH as add-on tests when prior screening tests have yielded abnormal results.

## Aim of the Technology Assessment

The objectives of this TA were to examine how ISH testing for either human chromosomal abnormalities or for HPV DNA in addition to Pap and HPV testing of cervical cells affects the detection of cervical cancer and related clinical outcomes. A finding of CIN3 carries a high risk of progression to cancer. Indeed, CIN3 on histopathology, combined with the rare cases of cancer as CIN3+, is considered the best surrogate measure of incident cervical cancer risk.

The specific aims were to: 1) conduct a “horizon scan” to identify studies that have used any ISH tests on cervical cytologic or histologic samples and to identify the ISH probes most frequently studied; 2) examine the analytic validity (technical performance) of the most frequently studied ISH tests for detection of markers of chromosomal damage or oncogenic HPV DNA; 3) examine the clinical validity of ISH tests for detection of high-grade CIN or for prediction of cancer related clinical outcomes; and 4) examine the clinical utility of ISH testing (i.e., how ISH testing impacts presumptive diagnosis, patient evaluation, management, and ultimately patients’ clinical outcomes). The Centers for Medicare and Medicaid Services (CMS) has requested this TA to inform its decisionmaking about the coverage of this technology.

## Key Questions

The four Key Questions in this TA, drafted by CMS and refined by the Evidence-based Practice Center (EPC) through discussions with Agency for Healthcare Research and Quality (AHRQ) Task Order Officer and CMS experts, broadly follow the first three domains of the ACCE framework for evaluating genetic tests—[underlined: A]nalytic validity, [underlined: C]linical validity, and [underlined: C]linical utility—but did not directly address the associated [underlined: E]thical, legal and social implications (www.cdc.gov/genomics/gtesting/ACCE/acce_proj.htm#T1).

### Key Question 1 What ISH tests have been used in cervical cytology or histology specimens?

To refine the scope for the detailed evidence review, we conducted a horizon scan of the literature to better understand the extent of the use of ISH tests for cervical abnormalities or cancer. On the basis of the findings of the horizon scan, we focused the subsequent review on ISH tests including probes for TERC (the telomerase RNA component gene, on chromosome 3, band 3q26), MYC (the myelocytomatosis oncogene, on chromosome 8, band 8q24), HPV 16, or HPV 18.

### Key Question 2 For ISH tests for TERC or MYC or HPV 16 or HPV 18 in cervical cytology or cervical histology

a. What are the associations between ISH test results and reference test results? What thresholds were used for positive, indeterminate, and negative results of the ISH tests? What reference tests were used to assess the presence or absence of the genetic marker (TERC, MYC, or HPV 16 or 18)?
b. What is known about reliability and reproducibility of ISH tests? What genetic, environmental, or other factors are known to affect ISH test results (e.g., the presence of more than a certain proportion of necrotic tumor tissue in the sample or the presence of infection)?
c. Are there some conditions for which an ISH test is not able to give a clinically useable result?
d. What are the sample acceptance and rejection criteria for ISH tests?
e. What sample storage or preservation requirements are needed for a reliable ISH test result?
f. What variation occurs in results of the ISH test if performed in multiple laboratories?
g. What is the prevalence of the genetic marker(s) detected by the reference standards in Medicare beneficiaries by age or race/ethnicity?

### Key Question 3 For ISH tests for TERC or MYC or HPV 16 or HPV 18

a. What is the association between ISH tests on cytology for high-grade CIN or cervical cancer on histopathology or for clinical outcomes related to cervical cancer morbidity and mortality? What thresholds were used for positive, indeterminate, and negative results on the ISH tests?
b. How similar are the spectrum and prevalence of the histopathological abnormalities and cervical cancers found in the studies to the spectrum and prevalence in Medicare beneficiaries? How is diagnostic accuracy modulated by age, race, and ethnicity?

### Key Question 4 For ISH tests for TERC or MYC or HPV 16 or HPV 18 in cervical cytology, what is the published evidence about the test’s clinical utility and harms?

a. In comparative studies of ISH testing versus alternative testing (with similar or equivalent tests) or no testing, what is the effect on diagnostic thinking, evaluation, management, or clinical outcomes?
b. What are the clinical inclusion criteria in the studies? How similar are the populations to the core Medicare population (i.e., persons ≥65 years of age) overall as well as according to race/ethnicity?
c. How similar are the spectrum and prevalence of the cancers in these studies to the spectrum and prevalence in the core Medicare population?

## Analytic Framework

The overarching analytic framework for the report is shown in Figure 1. Key Question 1 relates to a horizon scan of the literature to identify the most relevant ISH tests for subsequent detailed evidence review. Key Question 2 pertains to analytic validity, Key Question 3 to clinical validity, and Key Question 4 to clinical utility.

Key Question 3 was further focused on specific clinical scenarios according to currently recommended screening options in 2012 clinical practice guidelines (Figures 2–4).3,18 In these clinical scenarios, the unshaded options show guideline-directed care, and the shaded options represent hypothetical choices for add-on testing with ISH or add-on testing for HPV 16 or HPV 18. Screening is recommended for women between 21 and 65 years of age.

Figure 2 starts with Pap testing which is followed by reflexive testing for HPV (13 or 14 types); this approach is currently recommended for women over 21 years of age. Figure 3 starts with cotesting for Pap and HPV (13 or 14 types), which is recommended as an alternative for women over 30 years of age. Finally, Figure 4 starts with HPV testing for 13 or 14 types. This is not currently recommended care.

Figures 2 through 4 show the test options in sequence; after the initial test, each test choice is contingent on the results of the prior test(s). All tests may be done on the same specimen, obviating repeated specimen acquisition and averting the need for repeated visits. An alternative to reflexive testing would be to do all testing simultaneously, but this would require increased resources.

These figures show that a woman whose Pap results show HSIL or ASC-H would be referred to colposcopy; whereas a woman with normal Pap or with a normal Pap and a normal HPV results would be retested after a certain period. This leaves women with ASCUS or LSIL on Pap testing and those with a positive test for high-risk HPV, for whom additional testing with ISH might have a role as an add-on test instead of directly proceeding to colposcopy and as an alternative to non–ISH-based HPV 16/18 testing.

Figure 1 Analytic Framework

The key questions (KQs) are shown within the context of the population, tests, and outcomes. KQ1 reviews the existing literature on what in situ hybridization (ISH) test has been used in women tested for cervical cancer; KQ2 addresses the analytic validity of ISH testing to detect genetic abnormalities; KQ3 addresses the clinical validity of ISH testing to detect cervical dysplasia or malignancy; and KQ4 addresses the clinical utility of ISH testing to predict clinical outcomes, to affect diagnostic thinking, evaluation, and management, and to ascertain harms.

Figure 1 shows the analytic framework for the report as a flow diagram. The key questions (KQs) are shown within the context of the PICO (population, intervention, comparators, and outcomes) criteria. KQ1 addresses the existing literature describing the use of fluorescence in situ hybridization (FISH) testing in the context of cervical cancer screening; KQ2, the analytic validity of FISH testing to detect genetic abnormalities; KQ3, the clinical validity of FISH testing to detect cervical dysplasia or malignancy; and KQ4, the clinical utility of FISH testing to predict clinical outcomes, to affect diagnostic thinking, evaluation, and management, and to ascertain harms.

Figure 2 Testing Scenarios for Women Older Than 21 Years: Initial Papanicolaou (Pap) Testing Followed by Reflexive Testing for HPV (13 or 14 Types), as Recommended Under Current Guidelines

Test options are shown in sequence; after the initial test, each test choice is contingent on the results of the prior test(s). The dark gray–shaded test options with dashed lines are hypothetical alternatives to the currently recommended evaluation. Plus and minus signs indicate positive and negative results, respectively. “HPV 16/18” indicates HPV types 16 and/or 18 (both high-risk types), whereas “HPV 13 or 14 types” indicates testing for 13 or 14 types (depending on manufacturer of probe), a mix of low-, intermediate-, and high-risk types.

ASC-H= atypical squamous cells, cannot exclude HSIL; ASCUS=atypical squamous cells of undetermined significance; HSIL=high-grade squamous intraepithelial lesion; ISH=in situ hybridization; LSIL=low-grade squamous intraepithelial lesion; yr=years.

Figure 2 is an analytic framework describing the context for our review of the potential clinical validity of in situ hybridization (ISH) testing as part of cervical cancer screening in women older than 21 years. All the scenarios in this figure begin with Papanicolaou testing followed by testing for 13 or 14 types of human papillomavirus (HPV), as recommended under current guidelines for cervical cancer screening. The branches of the diagram most of interest are findings on Pap testing of atypical squamous cells of undetermined significance (ASCUS) or low-grade squamous intraepithelial lesion (LSIL). For these, the current recommendation is to undergo HPV testing for 13 or 14 types (in the case of ASCUS) or undergo colposcopy (in the case of LSIL). Experimental scenarios are for ASCUS patients to undergo testing by ISH for a biomarker of cervical cancer instead of HPV testing, and for LSIL patients to undergo ISH testing or testing for high-risk HPV instead of referral to colposcopy. Other possible scenarios are also shown.

Figure 3 Testing Scenarios for Women Older Than 30 Years: Initial Cotesting with Papanicolaou (Pap) and HPV (13 or 14 Types)

Test options are shown in sequence; after the initial test, each test choice is contingent on the results of the prior test(s). The dark gray–shaded test options with dashed lines are hypothetical alternatives to the currently recommended evaluation. Plus and minus signs indicate positive and negative results, respectively. “HPV 16/18” indicates HPV types 16 and/or 18 (both high-risk types), whereas “HPV 13 or 14 types” indicates testing for 13 or 14 types (depending on manufacturer of probe), a mix of low-, intermediate-, and high-risk types.

ASC-H= atypical squamous cells, cannot exclude HSIL; ASCUS=atypical squamous cells of undetermined significance; HSIL=high-grade squamous intraepithelial lesion; ISH=in situ hybridization; LSIL=low-grade squamous intraepithelial lesion; yr=years.

Figure 3 is an analytic framework describing the context for our review of the potential clinical validity of in situ hybridization (ISH) testing as part of cervical cancer screening in women older than 30 years. All the scenarios in this figure begin with cotesting with Papanicolaou testing plus testing for 13 or 14 types of human papillomavirus (HPV), as recommended under current guidelines for cervical cancer screening. The branches of the diagram most of interest are findings on Pap testing of atypical squamous cells of undetermined significance (ASCUS) and HPV positivity or low-grade squamous intraepithelial lesion (LSIL) and HPV positivity or negativity. For these, the current recommendation is to undergo colposcopy. Experimental scenarios are for either of these patients to undergo testing by ISH for a biomarker of cervical cancer instead of going straight to colposcopy. Other possible scenarios are also shown.

Figure 4 Hypothetical Testing Scenarios with Primary Screening for HPV (13 or 14 Types) for Women 30 Years of Age or Older)

Test options are shown in sequence; after the initial test, each test choice is contingent on the results of the prior test(s). The dark gray–shaded test options with dashed lines are hypothetical alternatives to the currently recommended evaluation. Plus and minus signs indicate positive and negative results, respectively. “HPV 16/18” indicates HPV types 16 and/or 18 (both high-risk types), whereas “HPV 13 or 14 types” indicates testing for 13 or 14 types (depending on manufacturer of probe), a mix of low-, intermediate-, and high-risk types.

ASC-H= atypical squamous cells, cannot exclude HSIL; ASCUS=atypical squamous cells of undetermined significance; HSIL=high-grade squamous intraepithelial lesion; ISH=in situ hybridization; LSIL=low-grade squamous intraepithelial lesion; Pap=Papanicolaou test; yr=years.

Figure 4 is an analytic framework describing an entirely hypothetical (but clinically reasonable) context for our review of the potential clinical validity of in situ hybridization (ISH) testing as part of cervical cancer screening in women older than 21 years. All the hypothetical scenarios in this figure begin with testing for 13 or 14 types of human papillomavirus (HPV), with women who test positive for HPV going on to either Papanicolaou (Pap) testing or testing for high-risk HPV. ISH is introduced as a potential screening test after findings on Pap testing of atypical squamous cells of undetermined significance (ASCUS) or of low-grade squamous intraepithelial lesion (LSIL). For these, the current recommendation is to undergo colposcopy. Other possible scenarios are also shown.