# Prevalence of Histopathologic Abnormalities by CIN Grade and Cytologic Classification

Table F1 Prevalence of CIN2+ from FISH Studies^*^

Author Year Country PMID | Prevalence of CIN2+ in all patients | Prevalence of CIN2+ in LSIL patients | Prevalence of CIN2+ in ASCUS, HPV status unknown | Prevalence of CIN2+ in ASCUS, HPV positive
Jalali 2010 US 20171606 | 23.4% (11/47) | NR | NR | NR
Jiang 2010 China 20864639 | 30.2% (2028/6726) | NR | NR | NR
Kokalj-Vokac 2009 Slovenia 19837263 | 67.6% (69/102) | 10.8% (11/102) | NR | NR
Li 2011 China 21035173 | 36.1% (108/299) [HPV positive patients] | 29.3% (24/82) [HPV positive patients] | NR | 17.2% (22/128)
Sokolova 2007 US 17875027 | 46.9% (97/207) | 25.9% (38/147) | 100% (14/14) | NR
Sui 2010 China 20882876 | 36.5% (23/63) | 7.1% (1/14) | 0% (0/18) | NR
Voss 2010 US 20701064 | 2.6% (3/115) | NR | NR | NR

* Prevalence given as percentage (no. of CIN2+ cases/total no. of patients).

ASCUS=atypical cells of undetermined significance, CIN=cervical intraepithelial neoplasia, FISH=fluorescence in situ hybridization, HPV=human papillomavirus, LSIL low-grade squamous intraepithelial lesion, TERC=human telomerase gene, US=United States.

Table F2 Prevalence of CIN3+ from FISH Studies.^*^

Author Year Country PMID | Prevalence of CIN3+ in all patients | Prevalence of CIN3+ in LSIL patients | Prevalence of CIN2+ in ASCUS, HPV status unknown | Prevalence of CIN3+ in ASCUS, HPV positive
Jiang 2010 China 20864639 | 30.2% (2028/6726) | NR | NR | NR
Kokalj-Vokac 2009 Slovenia 19837263 | 90.2% (92/102) | 21.6% (21/102) | NR | NR
Li 2011 China 21035173 | 32.3% (74/229) [HPV positive patients] | 17.1% (14/82) [HPV positive patients] | NR | 11.7% (15/128) [HPV positive patients]
Sokolova 2007 US 17875027 | 19.8% (41/207) | 3.4% (5/147) | 57.1% (8/14) | NR
Sui 2010 China 20882876 | 30.2% (19/63) | 0% | 0% | NR
Voss 2010 US 20701064 | 2.6% (3/115) | NR | NR | NR

* Prevalence given as percentage (no. of CIN2+ cases/total no. of patients).

ASCUS=atypical cells of undetermined significance, CIN=cervical intraepithelial neoplasia, FISH=fluorescence in situ hybridization, HPV=human papillomavirus, LSIL low-grade squamous intraepithelial lesion, TERC=human telomerase gene, US=United States.