# Assessment of Risk of Bias and Completeness of Reporting of Studies for Key Question 3

Table E1 Risk of Bias and Completeness of Reporting of Studies for Clinical Validity of ISH Using TERC or MYC or HPV 16 or 18 Probes, According to QUADAS-2 Domain^*^

| | Patient Selection | | | | Index Test | | | Reference Standard | | | Flow and Timing | | | | | Patient Selection | Index Test | Reference Standard
Author Year Country PMID | ISH Probe | S1 | S2 | S3 | B1 | S4 | S5 | B2 | S6 | S7 | B3 | S8 | S9 | S10 | S11 | B4 | A1 | A2 | A3
Huang 2009 China NR | TERC | NO | NO | YES | High | NR | NR | Unclear | YES | NR | Unclear | NR | YES | YES | YES | Low | Low | Low | Low
Jalali 2010 US 20171606 | TERC | NR | NO | YES | Unclear | YES | YES | Low | YES | YES | Low | NR | NO | YES | NO | High | Low | Low | Low
Jiang 2010 China 20864639 | TERC | NR | NO | NR | Unclear | YES | YES | Low | YES | NR | Unclear | NR | NO | YES | NO | High | Low | Low | Low
Kokalj-Vokac 2009 Slovenia 9837263 | TERC | NR | NO | YES | Unclear | NR | YES | Unclear | YES | NR | Unclear | NR | YES | YES | NO | Unclear | Low | Low | Low
Li 2011 China 21035173 | TERC | YES | NO | YES | Low | YES | YES | Low | YES | YES | Low | NR | YES | YES | YES | Low | Low | Low | Low
Sui 2010 China 20882876 | TERC | NR | NO | NR | Unclear | YES | YES | Low | YES | YES | Low | NR | YES | YES | YES | Low | Low | Low | Low
Fujii 2008 Japan 18936966 | HPV | NR | NO | NR | Unclear | NR | YES | Unclear | YES | NO | High | YES | NO | YES | NO | High | Low | Low | Low
Hesselink 2004 Netherlands 14968413 | HPV | NO | NR | NR | Unclear | NR | YES | Unclear | YES | NR | Unclear | NR | NO | YES | NO | High | Low | Low | Low
Sokolova 2007 US 17975027 | TERC HPV | YES | NO | YES | Low | YES | NO | High | YES | YES | Low | NR | YES | YES | YES | Low | Low | Low | Low
Voss 2010 US 20701064 | TERC HPV | YES | NO | NR | Unclear | NR | NO | High | YES | NR | Unclear | NR | YES | YES | YES | Low | Low | Low | Low

HPV=human papillomavirus, ISH=in situ hybridization, NR=not reported, QUADAS=Quality Assessment of Diagnostic Accuracy Studies, TERC=human telomerase gene, UK= United Kingdom, US=United States.

* The questions are those of the QUADAS-2 tool. The 11 signaling questions (S) were scored as yes, no, or not reported (NR). The 5 questions about bias (B) were scored as high, low, or unclear risk of bias. The three questions about applicability (A) were scored as high, low, unclear concerns about applicability. The items are as follows:

S1 = Consecutive or random sample of patients enrolled?

S2 = Case-control design avoided?

S3 = Study avoided inappropriate exclusions?

B1 = Risk of bias: Could the selection of patients have introduced bias?

S4 = Index test results interpreted without knowledge of results of reference standard?

S5 = If threshold used, was it prespecified?

B2 = Risk of bias: Could the conduct or interpretation of the index test have introduced bias?

S6 = Reference standard likely to correctly classify the target condition?

S7 = Reference standard results interpreted without knowledge of index test results?

B3 = Risk of bias: Could the reference standard, its conduct, or its interpretation have introduced bias?

S8 = Appropriate interval between index test and reference standard?

S9 = All patients received a reference standard?

S10 = All patients received the same reference standard?

S11 = Were all patients included in the analysis?

B4 = Risk of bias: Could the patient flow have introduced bias?

A1 = Concerns about applicability: Concerns that the included patients do not match the review question?

A2 = Concerns about applicability: Concerns that the index test, its conduct, or its interpretation differ from the review question?

A3 = Concerns about applicability: Are there concerns that the target condition as defined by the reference standard does not match the review question?