# Assessment of Risk of Bias and Completeness of Reporting of Studies for Key Question 2

Table D1 Risk of Bias and Completeness of Reporting of Studies for Analytic Validity of ISH using TERC or MYC or HPV 16 or 18 Probes.*

Author Year Country PMID | ISH Probe | Q1 | Q2 | Q3 | Q4 | Q5 | Q6 | Q7 | Q8 | Q9 | Q10 | Q11
Tu 2009 China 19389503 | TERC | YES | NR | NR | NR | NR | YES | NR | NR | NR | NR | NR
Jin 2011 China 21875260 | TERC | YES | NR | NR | NR | NR | YES | NR | NR | NR | NR | NR
Alameda 2011 Spain 21302019 | HPV | YES | NR | NR | NR | NR | YES | NR | NR | NR | NR | NR
Andersson 2009 Sweden 19880826 | HPV | YES | NR | NR | NR | NR | YES | YES | NR | NR | NR | NR
Ansari-Lari 2004 US 15043304 | HPV | YES | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Bernard 1994 France 7877628 | HPV | YES | YES | YES | NR | NR | YES | YES | NR | NR | NR | NR
Bertelsen 1996 Norway 9048869 | HPV | YES | YES | YES | NR | NR | YES | NR | NR | NR | NR | NR
Birner 2001 Austria 11455003 | HPV | YES | YES | YES | NR | NR | YES | NR | NR | NR | NR | NR
Bulten 2002 Netherlands 12375262 | HPV | YES | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Cavalcanti 1996 Brazil 9070405 | HPV | YES | YES | YES | NR | NR | YES | NR | NR | NR | NR | NR
Hesselink 2004 Netherlands 14968413 | HPV | YES | YES | YES | NR | NR | YES | NR | NR | NR | NR | NR
Kong 2007 US 17197917 | HPV | YES | YES | YES | NR | NR | YES | NR | NR | NR | NR | NR
Lie 1997 Norway 9113073 | HPV | YES | YES | YES | NR | NR | NR | NR | NR | NR | NR | NR
Masumoto 2003 Japan 14506638 | HPV | YES | NR | NR | NR | NR | YES | NR | NR | NR | NR | NR
Quereshi 2005 US 15839613 | HPV | YES | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Walker 1996 France 8727101 | HPV | YES | YES | YES | NR | NR | NR | YES | NR | NR | NR | NR

HPV=human papillomavirus, ISH=in situ hybridization, NR=not reported, TERC=telomerase RNA component, US=United States.

The 11 quality questions (Qs), adapted from Sun et al. 2011, were scored as yes, no, or not reported (NR) (including for a corollary that follows a question with an NR score). The items are as follows:

Q1 = Was the execution of the assay described in sufficient detail to permit replication?

Q2 = Were both positive and negative control samples tested?

Q3 = Were negative control materials from the same type of tissue, and collected, stored, and processed in the same way that sample materials used clinically for testing will be?

Q4 = Were the tests performed with positive or negative control samples being blinded to the testers?

Q5 = Were the testing results interpreted with positive or negative control samples being blinded to the interpreters?

Q6 = Were criteria for determining a testing result as positive, negative, indeterminate, and uninterpretable set a priori?

Q7 = Was any information on cross-reactivity of the test reported?

Q8 = Was the reproducibility of the test when performed multiple times on a single specimen established?

Q9 = Was the reproducibility of the test adequately established (across operators, instruments, reagent lots, different days of the week, different laboratories)?

Q10 = Was the rate of yield [numbers] of usable (interpretable) results reported?

Q11 = Were the study data from a multisite collaborative, proficiency testing, or interlaboratory exchange programs?

Reference: Sun F, Bruening W, Erinoff E, et al. Addressing challenges in genetic test evaluation. Rockville, MD: Agency for Healthcare Research and Quality; 2011. Available at: http://www.effectivehealthcare.ahrq.gov/ehc/products/105/704/Genetic-Test-Evaluation_Final-Report_20110615.pdf. Accessed on November 4, 2011.