# Key Question 1 (Horizon Scan) Figures and Tables

Figure C1 Numbers of the 135 Horizon Scan Studies Using Each Identified Non–HPV ISH Probe

Chr=chromosome(s); CMV=cytomegalovirus; EBV=Epstein–Barr virus; HLA=human leukocyte antigen; MYC= myelocytomatosis oncogene (on chromosome 8q24); TERC=telomerase RNA component (on chromosome 3q26).

Studies could have used more than one type of probe, in which case they are counted once for each probe, such that the total number of studies across the plot is greater than 135.

Probes for whole chromosomes are typically control probes for overall amplification (vs. amplification of a specific gene or region).

Figure C1 is a vertical bar chart showing the number of studies using each identified non-HPV ISH probe. Studies could have used more than one type of probe, in which case they are counted once for each probe, such that the total number of studies across the plot is greater than 135. Probes for whole chromosomes are typically control probes for overall amplification (vs. amplification of a specific gene or region). This is based on these horizon scan results that we decided to focus our review on the probes for TERC and MYC.

Figure C2 Numbers of the 135 Horizon Scan Studies Using Each Identified HPV ISH Probe, According to the Risk of Cancer Associated with the HPV Type

HPV =human papillomavirus.

Studies could have used more than one type of probe, in which case they are counted once for each probe, such that the total number of studies across the plot is greater than 135.

High-risk probes were of greatest interest since they are most associated with a risk of progression to cervical cancer. Low-risk HPV types 6 and 11 are often used as controls.

Figure C2 is a vertical bar chart showing the number of studies using each identified HPV ISH probe. Studies could have used more than one type of probe, in which case they are counted once for each probe, such that the total number of studies across the plot is greater than 135. High-risk probes were of greatest interest since they are most associated with a risk of progression to cervical cancer. Low-risk HPV types 6 and 11 are often used as controls. This is based on these horizon scan results that we decided to focus our review on the probes for HPV16 and HPV18.

Figure C3 Worldwide Distribution of the 116 Horizon Scan Studies with Probes of Interest. For detail on the 63 European studies, see Fig. C4

Figure C3 is a world map showing the number of relevant studies undertaken in each country throughout the world. The research for this topic is largely conducted in Europe, followed by the United States, China, Japan, and Brazil.

Figure C4 Distribution of the 63 European Studies in the Horizon Scan with Probes of Interest

Figure C4 is a map of Europe showing the number of relevant studies undertaken in each indivdual country within the continent. According to the map, most research is coming from France, followed closely by Italy, the Netherlands, and Spain.

Table C1 Description of Probes Used, Outcomes Assessed, and Study Characteristics of the 31 Studies of ISH Using a TERC or MYC (Non-HPV) Probe (and Therefore Eligible for Key Questions 2–4)

Table C.2 Description of Probes Used, Outcomes Assessed, and Study Characteristics of the 91 Studies of ISH Using an HPV 16 or HPV 18 Probe (and Therefore Eligible for Key Questions 2–4)