# Excluded Studies

The 111 studies excluded after full-text review for Key Questions 2, 3, and 4 are listed in alphabetical order by first author under each main reason for exclusion (bold headings): No probes for TERC, MYC, or HPV 16 or 18 (n=19), no analytic validity data and no cytology specimens (just histology) (n=69), no analytic validity data (n=7), and FISH results not reported for cytology classification according to histology classification (n=16). PMIDs are given at the end of each reference, when available.

## No Probes for TERC or MYC or HPV 16 or 18 (n=19)

Cortes-Gutierrez EI, vila-Rodriguez MI, Fernandez JL, et al. DNA damage in women with cervical neoplasia evaluated by DNA breakage detection-fluorescence in situ hybridization. Anal Quant Cytol Histol. Jun. 2011;33(3):175-181. [pmid: 21980621].
Zeng WJ, Li Y, Fei HL, et al. The value of p16ink4a expression by fluorescence in situ hybridization in triage for high risk HPV positive in cervical cancer screening. Gynecol Oncol. Jan. 2011;120(1):84-88. [pmid: 20926123].
Darroudi F, Bergs JW, Bezrookove V, et al. PCC and COBRA-FISH a new tool to characterize primary cervical carcinomas: to assess hall-marks and stage specificity. Cancer Lett. Jan. 1. 2010;287(1):67-74. [pmid: 19553004].
Ng G, Winder D, Muralidhar B, et al. Gain and overexpression of the oncostatin M receptor occur frequently in cervical squamous cell carcinoma and are associated with adverse clinical outcome. J Pathol. Jul. 2007;212(3):325-334. [pmid: 17516585].
Vermeulen CF, Jordanova ES, Zomerdijk-Nooijen YA, et al. Frequent HLA class I loss is an early event in cervical carcinogenesis. Hum Immunol. Nov. 2005;66(11):1167-1173. [pmid: 16571417].
Olaharski AJ, Sotelo R, Solorza-Luna G, et al. Tetraploidy and chromosomal instability are early events during cervical carcinogenesis. Carcinogenesis. Feb. 2006;27(2):337-343. [pmid: 16123119].
Cortes-Gutierrez EI, vila-Rodriguez MI, Muraira-Rodriguez M, et al. Association between the stages of cervical cancer and chromosome 1 aneusomy. Cancer Genet Cytogenet. May. 2005;159(1):44-47. [pmid: 15860356].
Mehes G, Speich N, Bollmann M, et al. Chromosomal aberrations accumulate in polyploid cells of high-grade squamous intraepithelial lesions (HSIL). Pathol Oncol Res. 2004;10(3):142-148. [pmid: 15448749].
Yamal JM, Cox D, Hittelman WN, et al. Quantitative histopathology and chromosome 9 polysomy in a clinical trial of 4-HPR. Gynecol Oncol. Aug. 2004;94(2):296-306. [pmid: 15297165].
Cheung AN, Chiu PM, Tsun KL, et al. Chromosome in situ hybridisation, Ki-67, and telomerase immunocytochemistry in liquid based cervical cytology. J Clin Pathol. Jul. 2004;57(7):721-727. [pmid: 15220365].
Olaharski AJ, Eastmond DA. Elevated levels of tetraploid cervical cells in human papillomavirus-positive Papanicolaou smears diagnosed as atypical squamous cells of undetermined significance. Cancer. Jun. 25. 2004;102(3):192-199. [pmid: 15211479].
Marzano R, Corrado G, Merola R, et al. Analysis of chromosomes 3, 7, X and the EGFR gene in uterine cervical cancer progression. Eur J Cancer. Jul. 2004;40(10):1624-1629. [pmid: 15196550].
Morrison C, Prokorym P, Piquero C, et al. Oral contraceptive pills are associated with artifacts in ThinPrep Pap smears that mimic low-grade squamous intraepithelial lesions. Cancer. Apr. 25. 2003;99(2):75-82. [pmid: 12704686].
Menezes GA, Wakely PE Jr, Stripe DM, et al. Increased incidence of atypical Papanicolaou tests from ThinPreps of postmenopausal women receiving hormone replacement therapy. Cancer. Dec. 25. 2001;93(6):357-363. [pmid: 11748575].
Mian C, Bancher D, Kohlberger P, et al. Fluorescence in situ hybridization in cervical smears: detection of numerical aberrations of chromosomes 7, 3, and X and relationship to HPV infection. Gynecol Oncol. Oct. 1999;75(1):41-46. [pmid: 10502423].
Giovagnoli MR, Mancini R, Pachi A, et al. DNA ploidy and HPV subtypes in cervical smears of HIV-sero-positive and negative patients. Anticancer Res. May. 1997;17(3C):2259-2263. [pmid: 9216698].
Kurtycz D, Nunez M, Arts T, et al. Use of fluorescent in situ hybridization to detect aneuploidy in cervical dysplasia. Diagn Cytopathol. Jul. 1996;15(1):46-51. [pmid: 8807251].
Hariu H, Matsuta M. Cervical cytology by means of fluorescence in situ hybridization with a set of chromosome-specific DNA probes. J Obstet Gynaecol Res. Apr. 1996;22(2):163-170. [pmid: 8697347].
Schon HJ, Schurz B, Marz R, et al. Screening for Epstein-Barr and human cytomegalovirus in normal and abnormal cervical smears by fluorescent in situ cytohybridization. Arch Virol. 1992;125(1–4):205-214. [pmid: 1322652].

## No Analytic Validity Data and No Cytology Specimens (n=69)

Yuan Yl, He CN, Xu Mt, et al. Detection of TERC gene amplification by fluorescence in-situ hybridization in cervical intraepithelial lesions. Zhonghua Bing Li Xue Za Zhi. Mar. 2011;40(3):182-186. [pmid: 21575390].
Policht FA, Song M, Sitailo S, et al. Analysis of genetic copy number changes in cervical disease progression. BMC Cancer. 2010;10:432. [pmid: 20712890].
Sui W, Ou M, Dai Y, et al. Gain of the human telomerase RNA gene TERC at 3q26 is strongly associated with cervical intraepithelial neoplasia and carcinoma. Int J Gynecol Cancer. Nov. 2009;19(8):1303-1306. [pmid: 20009881].
Song M, Ruth A, Policht FA, et al. Dysplastic cells in cytological cervical samples show a high incidence of chromosomal abnormalities. Diagn Cytopathol. Jan. 2010;38(1):28-33. [pmid: 19626623].
Alameda F, Espinet B, Corzo C, et al. 3q26 (hTERC) gain studied by fluorescence in situ hybridization as a persistence-progression indicator in low-grade squamous intraepithelial lesion cases. Hum Pathol. Oct. 2009;40(10):1474-1478. [pmid: 19540557].
Zhang Y, Wang X, Ma L, et al. Clinical significance of hTERC gene amplification detection by FISH in the screening of cervical lesions. J Huazhong Univ Sci Technolog Med Sci. Jun. 2009;29(3):368-371. [pmid: 19513624].
Costa C, Espinet B, Molina MA, et al. Analysis of gene status in cervical dysplastic lesions and squamous cell carcinoma using tissue microarrays. Histol Histopathol. Jul. 2009;24(7):821-829. [pmid: 19475528].
Seppo A, Jalali GR, Babkowski R, et al. Gain of 3q26: a genetic marker in low-grade squamous intraepithelial lesions (LSIL) of the uterine cervix. Gynecol Oncol. Jul. 2009;114(1):80-83. [pmid: 19394683].
Ramsaroop R, Oei P, Ng D, et al. Cervical intraepithelial neoplasia and aneusomy of TERC: assessment of liquid-based cytological preparations. Diagn Cytopathol. Jun. 2009;37(6):411-415. [pmid: 19191295].
de Macedo FC, Nicol AF, Scudeler D, et al. The utility of HPV in situ hybridization and the PAS test in improving the specificity of the diagnosis of CIN 1. Int J Gynecol Pathol. Jan. 2009;28(1):83-89. [pmid: 19047903].
De Marchi TR, Metze K, Zeferino LC, et al. HPV in situ hybridization signal patterns as a marker for cervical intraepithelial neoplasia progression. Gynecol Oncol. Jan. 2009;112(1):114-118. [pmid: 19007972].
Arafa M, Boniver J, Delvenne P. Detection of HPV-induced cervical (pre) neoplastic lesions: a tissue microarray (TMA) study. Appl Immunohistochem Mol Morphol. Oct. 2008;16(5):422-432. [pmid: 18542030].
Samama B, Schaeffer C, Boehm N. P16 expression in relation to human papillomavirus in liquid-based cervical smears. Gynecol Oncol. May. 2008;109(2):285-290. [pmid: 18387664].
Omori M, Hashi A, Nakazawa K, et al. Estimation of prognoses for cervical intraepithelial neoplasia 2 by p16INK4a immunoexpression and high-risk HPV in situ hybridization signal types. Am J Clin Pathol. Aug. 2007;128(2):208-217. [pmid: 17638654].
el-All HS, Refaat A, Dandash K. Prevalence of cervical neoplastic lesions and Human Papilloma Virus infection in Egypt: National Cervical Cancer Screening Project. Infect Agent Cancer. 2007;2:12. [pmid: 17610742].
Hopman AH, Theelen W, Hommelberg PP, et al. Genomic integration of oncogenic HPV and gain of the human telomerase gene TERC at 3q26 are strongly associated events in the progression of uterine cervical dysplasia to invasive cancer. J Pathol. Dec. 2006;210(4):412-419. [pmid: 17054308].
Andersson S, Wallin KL, Hellstrom AC, et al. Frequent gain of the human telomerase gene TERC at 3q26 in cervical adenocarcinomas. Br J Cancer. Aug. 7. 2006;95(3):331-338. [pmid: 16847471].
Wilting SM, Snijders PJ, Meijer GA, et al. Increased gene copy numbers at chromosome 20q are frequent in both squamous cell carcinomas and adenocarcinomas of the cervix. J Pathol. Jun. 2006;209(2):220-230. [pmid: 16538612].
Heselmeyer-Haddad K, Sommerfeld K, White NM, et al. Genomic amplification of the human telomerase gene (TERC) in pap smears predicts the development of cervical cancer. Am J Pathol. Apr. 2005;166(4):1229-1238. [pmid: 15793301].
Heselmeyer-Haddad K, Janz V, Castle PE, et al. Detection of genomic amplification of the human telomerase gene (TERC) in cytologic specimens as a genetic test for the diagnosis of cervical dysplasia. Am J Pathol. Oct. 2003;163(4):1405-1416. [pmid: 14507648].
Evans MF, Mount SL, Beatty BG, et al. Biotinyl-tyramide-based in situ hybridization signal patterns distinguish human papillomavirus type and grade of cervical intraepithelial neoplasia. Mod Pathol. Dec. 2002;15(12):1339-1347. [pmid: 12481016].
Menezes G, Euscher E, Schwartz B, et al. Utility of the in situ detection of HPV in Pap smears diagnosed as within normal limits. Acta Cytol. Nov. 2001;45(6):919-926. [pmid: 11726118].
Bar JK, Harlozinska A, Sedlaczek P, et al. Relations between the expression of p53, c-erbB-2, Ki-67 and HPV infection in cervical carcinomas and cervical dysplasias. Anticancer Res. Mar. 2001;21(2A):1001-06. [pmid: 11396132].
Kalantari M, Blennow E, Hagmar B, et al. Physical state of HPV16 and chromosomal mapping of the integrated form in cervical carcinomas. Diagn Mol Pathol. Mar. 2001;10(1):46-54. [pmid: 11277395].
Vassallo J, Derchain SF, Pinto GA, et al. High risk HPV and p53 protein expression in cervical intraepithelial neoplasia. Int J Gynaecol Obstet. Oct. 2000;71(1):45-48. [pmid: 11044541].
Hennig EM, Di LA, Venuti A, et al. HPV 16 in multiple neoplastic lesions in women with CIN III. J Exp Clin Cancer Res. Sep. 1999;18(3):369-377. [pmid: 10606184].
Bettinger D, Bernard B, Riethmuller D, et al. Human papillomavirus detection by non isotopic in situ hybridization, in situ hybridization with signal amplification and in situ polymerase chain reaction. Eur J Histochem. 1999;43(3):185-198. [pmid: 10563251].
Berthier S, Mougin C, Vercherin P, et al. Does a particular risk associated with papillomavirus infections exist in women with lupus?. Rev Med Interne. Feb. 1999;20(2):128-132. [pmid: 10227090].
Tichy M, Ticha V, Kolar Z, et al. Inflammatory stromal reaction in epithelial neoplasia of the uterine cervix in correlation with HPV infection. Cesk Patol. Nov. 1998;34(4):142-148. [pmid: 9929943].
Bertelsen B, Tande T, Sandvei R, et al. Laser conization of cervical intraepithelial neoplasia grade 3: free resection margins indicative of lesion-free survival. Acta Obstet Gynecol Scand. Jan. 1999;78(1):54-59. [pmid: 9926893].
Nuovo GJ. Detection of human papillomavirus in Papanicolaou smears: correlation with pathologic findings and clinical outcome. Diagn Mol Pathol. Jun. 1998;7(3):158-163. [pmid: 9836071].
Calore EE, Calore NM, Cavaliere MJ. Non-isotopic in situ hybridization of HPV types in cervical intraepithelial lesions in patients with AIDS. Arch Gynecol Obstet. 1998;262(1–2):75-79. [pmid: 9836004].
O'Leary JJ, Landers RJ, Silva I, et al. Molecular analysis of ras oncogenes in CIN III and in stage I and II invasive squamous cell carcinoma of the uterine cervix. J Clin Pathol. Aug. 1998;51(8):576-582. [pmid: 9828814].
Ziol M, Di TC, Biaggi A, et al. Virological and biological characteristics of cervical intraepithelial neoplasia grade I with marked koilocytotic atypia. Hum Pathol. Oct. 1998;29(10):1068-1073. [pmid: 9781643].
Lizard G, Roignot P, Brunet-Lecomte P, et al. Morphological analysis of in situ hybridization signals in cervical intraepithelial neoplasia containing human papillomavirus type 16 or 18: relationship with histological grade and DNA content. Cytometry. Aug. 15. 1998;34(4):180-186. [pmid: 9725458].
Mittal K, Demopoulos RI, Tata M. A comparison of proliferative activity and atypical mitoses in cervical condylomas with various HPV types. Int J Gynecol Pathol. Jan. 1998;17(1):24-28. [pmid: 9475188].
Davidson B, Goldberg I, Kopolovic J. Angiogenesis in uterine cervical intraepithelial neoplasia and squamous cell carcinoma: an immunohistochemical study. Int J Gynecol Pathol. Oct. 1997;16(4):335-338. [pmid: 9421072].
Monsonego J, Valensi P, Zerat L, et al. Simultaneous effects of aneuploidy and oncogenic human papillomavirus on histological grade of cervical intraepithelial neoplasia. Br J Obstet Gynaecol. Jun. 1997;104(6):723-727. [pmid: 9197877].
Dellas A, Schultheiss E, Oberholzer M, et al. Analysis of proliferative activity using Ki-67 on cervical precancerous lesions and the relationship to p53 expression. Anticancer Res. Nov. 1996;16(6B):3403-3407. [pmid: 9042198].
Rihet S, Lorenzato M, Clavel C. Oncogenic human papillomaviruses and ploidy in cervical lesions. J Clin Pathol. Nov. 1996;49(11):892-896. [pmid: 8944607].
Spinillo A, Tenti P, Baltaro F, et al. Cervical intraepithelial neoplasia in pregnant intravenous drug users infected with human immunodeficiency virus type 1. Eur J Obstet Gynecol Reprod Biol. Sep. 1996;68(1–2):175-178. [pmid: 8886703].
Dellas A, Schultheiss E, Almendral AC, et al. Assessment of EGFR and TGF-alpha expression in relationship to HPV status and Ki-67 distribution in cervical intraepithelial neoplasms. Int J Cancer. Jun. 21. 1996;69(3):165-169. [pmid: 8682581].
Balbi C, Di GF, Piscitelli V, et al. Retrospective study of cervical papillomavirus lesions: early Herpes simplex virus proteins as markers of risk for progression. Minerva Ginecol. May. 1996;48(5):175-179. [pmid: 8927276].
Soini Y, Pollanen R, Kemppainen S, et al. The association of vascular proliferation with HPV status and epithelial PCNA positivity in cervical intraepithelial lesions. APMIS. Mar. 1996;104(3):183-190. [pmid: 8611192].
Kotrsova L, Kolar Z, Tichy M, et al. Detection and typing of HPV DNA in situ--improvement in diagnosis of lesions of the uterine cervix. Ceska Gynekol. Oct. 1995;60(5):231-234. [pmid: 8599698].
Akasofu M, Oda Y. Immunohistochemical detection of p53 in cervical epithelial lesions with or without infection of human papillomavirus types 16 and 18. Virchows Arch. 1995;425(6):593-602. [pmid: 7697216].
Tweddel G, Heller P, Cunnane M, et al. The correlation between HIV seropositivity, cervical dysplasia, and HPV subtypes 6/11, 16/18, 31/33/35. Gynecol Oncol. Feb. 1994;52(2):161-164. [pmid: 8314133].
Pollanen R, Soini Y, Vahakangas K, et al. Aberrant p53 protein expression in cervical intra-epithelial neoplasia. Histopathology. Nov. 1993;23(5):471-474. [pmid: 8314222].
Pollanen R, Vuopala S, Lehto VP. Detection of human papillomavirus infection by non-isotopic in situ hybridisation in condylomatous and CIN lesions. J Clin Pathol. Oct. 1993;46(10):936-939. [pmid: 8227412].
Spinillo A, Tenti P, Zappatore R, et al. Langerhans' cell counts and cervical intraepithelial neoplasia in women with human immunodeficiency virus infection. Gynecol Oncol. Feb. 1993;48(2):210-213. [pmid: 8381376].
Sassi I, Mangili F, Luchini S, et al. Correlations between the HPV type, DNA index and evolution of cervical intraepithelial neoplasia (CIN). Pathologica. Jan. 1993;85(1095):79-84. [pmid: 8390639].
Bejui-Thivolet F, Liagre N, Patricot LM, et al. Human papillomavirus DNA in cervix. In-situ hybridization with biotinylated probes on Bouin's fixed paraffin embedded specimens. Pathol Res Pract. Feb. 1992;188(1–2):67-73. [pmid: 1317560].
Pich A, Margaria E, Ghiringhello B, et al. In situ hybridization for human papillomavirus as a method of predicting the evolution of cervical intraepithelial neoplasia. Arch Gynecol Obstet. 1992;252(1):11-19. [pmid: 1329676].
Shepherd P, Lunny D, Brookes R, et al. The detection of human papillomaviruses in cervical biopsies by immunohistochemistry and in situ hybridization. Scand J Immunol Suppl. 1992;11:69-74. [pmid: 1325072].
Herrington CS, Troncone G, Evans MF, et al. Screening for high- and low-risk human papillomavirus types in single routine cervical smears by non-isotopic in situ hybridization. Cytopathology. 1992;3(2):71-78. [pmid: 1319766].
Cadorin L, Sopracordevole F, Iuzzolino C, et al. Histological diagnosis of human papillomavirus (HPV)-related dysplasia: quality control by in situ hybridization (ISH) analysis. Eur J Gynaecol Oncol. 1992;13(5):427-430. [pmid: 1283127].
Ji HX, Yliskoski M, Vayrynen M, et al. Colposcopic analysis of genital human papillomavirus infections during an 8-year prospective follow-up. Int J Gynaecol Obstet. Dec. 1991;36(4):291-300. [pmid: 1684763].
Nuovo GJ, Walsh LL, Gentile JL, et al. Correlation of the Papanicolaou smear and human papillomavirus type in women with biopsy-proven cervical squamous intraepithelial lesions. Am J Clin Pathol. Oct. 1991;96(4):544-548. [pmid: 1654025].
Meyer MP, Markiw CA, Matuscak RR, et al. Detection of human papillomavirus DNA in genital lesions by using a modified commercially available in situ hybridization assay. J Clin Microbiol. Jul. 1991;29(7):1308-1311. [pmid: 1653262].
Cooper K, Herrington CS, Graham AK, et al. In situ human papillomavirus (HPV) genotyping of cervical intraepithelial neoplasia in South African and British patients: evidence for putative HPV integration in vivo. J Clin Pathol. May. 1991;44(5):400-405. [pmid: 1646237].
Choi YJ. Detection of human papillomavirus DNA on routine Papanicolaou's smears by in situ hybridization with the use of biotinylated probes. Am J Clin Pathol. Apr. 1991;95(4):475-480. [pmid: 1849699].
Mougin C, Schaal JP, Bassignot A, et al. Detection of human papillomavirus and human cytomegalovirus in cervical lesions by in situ hybridization using biotinylated probes. Biomed Pharmacother. 1991;45(8):353-357. [pmid: 1663402].
Weaver MG, bdul-Karim FW, Dale G, et al. Outcome in mild and moderate cervical dysplasias related to the presence of specific human papillomavirus types. Mod Pathol. Nov. 1990;3(6):679-683. [pmid: 2175897].
Hara Y, Tuchida S, Nakamura T, et al. Human papillomavirus infection of the uterine cervix analyzed by nonisotopic in situ hybridization. J Med Virol. Jun. 1990;31(2):120-128. [pmid: 2167347].
Neumann R, Nelles G, Eggers HJ, et al. Comparison of the detection of cervical human papillomavirus infection by filter DNA hybridization of cytologic specimens and by in situ DNA hybridization of tissues. Acta Cytol. Mar. 1990;34(2):115-118. [pmid: 2157319].
Amortegui AJ, Meyer MP, Intyre-Seltman K, et al. Detection of human papillomavirus DNA in cervical lesions by in situ hybridization using biotinylated DNA probes. Int J Gynecol Pathol. 1990;9(4):306-315. [pmid: 2174026].
Tase T, Okagaki T, Clark BA, et al. Human papillomavirus DNA in glandular dysplasia and microglandular hyperplasia: presumed precursors of adenocarcinoma of the uterine cervix. Obstet Gynecol. Jun. 1989;73(6):1005-1008. [pmid: 2542853].
D'Amico M. Human immunodeficiency virus localization in human papillomavirus-related, high-grade squamous intraepithelial lesions of the cervix in women with HIV infection: Microdissection and molecular analysis on formalin-fixed and paraffin-embedded specimens. J Lower Genital Tract Dis. 2012;3:254-259.
He J, Yin G, Lu J, et al. Relationship of human telomerase mRNA component gene expression in cervical exfoliated cells with cervical lesions and human papilloma virus infection. Academic Journal of Second Military Medical University. 2010;31:838-841.

## No Analytic Validity Data (n=7)

Theelen W, Speel EJ, Herfs M, et al. Increase in viral load, viral integration, and gain of telomerase genes during uterine cervical carcinogenesis can be simultaneously assessed by the HPV 16/18 MLPA-assay. Am J Pathol. Oct. 2010;177(4):2022-2033. [pmid: 20813962].
Badr RE, Walts AE, Chung F, et al. BD ProEx C: a sensitive and specific marker of HPV-associated squamous lesions of the cervix. Am J Surg Pathol. Jun. 2008;32(6):899-906. [pmid: 18425044].
Vocaturo A, Marandino E, Celata E, et al. Colourimetric signal amplification of in situ hybridization assay for human papillomavirus DNA detection in cytological samples. J Exp Clin Cancer Res. Jun. 2002;21(2):239-246. [pmid: 12148585].
Herrington CS, Evans MF, Charnock FM, et al. HPV testing in patients with low grade cervical cytological abnormalities: a follow up study. J Clin Pathol. Jun. 1996;49(6):493-496. [pmid: 8763265].
Symmans F, Mechanic L, MacConnell P, et al. Correlation of cervical cytology and human papillomavirus DNA detection in postmenopausal women. Int J Gynecol Pathol. Jul. 1992;11(3):204-209. [pmid: 1328078].
Alonso MJ, Gomez F, Munoz E, et al. Comparative study of in situ hybridization and immunohistochemical techniques for the detection of human papillomavirus in lesions of the uterine cervix. Eur J Histochem. 1992;36(3):271-278. [pmid: 1281009].
Alejo M, Margall N, Matias-Guiu X, et al. DNA-ploidy and HPV infection in epithelial lesions of the lower female genital tract. Int J Gynecol Cancer. 1996;6:1-7.

## Studies do not Report Sensitivity and Specificity of FISH Results Within Pertinent Cytology Class for Histology Outcomes Classified as CIN (n=16)

al-Saleh W, Delvenne P, van den Brule FA, et al. Expression of the 67 KD laminin receptor in human cervical preneoplastic and neoplastic squamous epithelial lesions: an immunohistochemical study. J Pathol. Mar. 1997;181(3):287-293. [pmid: 9155714].
Caraway NP, Khanna A, Dawlett M, et al. Gain of the 3q26 region in cervicovaginal liquid-based pap preparations is associated with squamous intraepithelial lesions and squamous cell carcinoma. Gynecol Oncol. Jul. 2008;110(1):37-42. [pmid: 18433848].
Cavalcanti SM, Zardo LG, Passos MR, et al. Epidemiological aspects of human papillomavirus infection and cervical cancer in Brazil. J Infect. Jan. 2000;40(1):80-87. [pmid: 10762117].
Daste G, Butet MH, Berrebi A, et al. Typing of human papillomaviruses in intra-epithelial malpighian lesions of the cervix uteri: correlation with cytohistologic grade and progression of the lesions. J Gynecol Obstet Biol Reprod (Paris). 1994;23(1):28-34. [pmid: 8157887].
Gitsch G, Reinthaller A, Tatra G, et al. Diagnosis of cervical intraepithelial neoplasia and human papillomavirus infection: punch biopsy versus cervical smear. Arch Gynecol Obstet. 1991;249(4):179-184. [pmid: 1665685].
Hopman AH, Smedts F, Dignef W, et al. Transition of high-grade cervical intraepithelial neoplasia to micro-invasive carcinoma is characterized by integration of HPV 16/18 and numerical chromosome abnormalities. J Pathol. Jan. 2004;202(1):23-33. [pmid: 14694518].
Hording U, Daugaard S, Bock JE, et al. HPV 11, 16 and 18 DNA sequences in cervical swabs from women with cervical dysplasia: prevalence and associated risk of progression. Eur J Obstet Gynecol Reprod Biol. Jun. 5. 1991;40(1):43-48. [pmid: 1649773].
Lakshmi S, Rema P, Somanathan T. p16ink4a is a surrogate marker for high-risk and malignant cervical lesions in the presence of human papillomavirus. Pathobiology. May. 2009;76(3):141-148. [pmid: 19468254].
Nagai N, Takehara K, Murakami T, et al. Cytological analysis for human papillomavirus DNAs in cervical intraepithelial neoplasia by in situ hybridization. Hiroshima J Med Sci. Sep. 1994;43(3):105-110. [pmid: 7896562].
Schon HJ, Czerwenka KF, Schurz B, et al. Papanicolaou test and enzyme-linked in-situ hybridization. A combined diagnostic system for papilloma virus infections with high prognostic value. Eur J Clin Chem Clin Biochem. Feb. 1991;29(2):131-138. [pmid: 1646654].
Sopracordevole F, Cadorin L, Muffato G, et al. Papanicolau smear chances to be diagnostic for cervical squamous intraepithelial lesions (SIL) with or without detectable HPV DNA at in situ hybridization analysis. Eur J Gynaecol Oncol. 1993;14(4):336-338. [pmid: 8393793].
Tabbara S, Saleh AD, Andersen WA, et al. The Bethesda classification for squamous intraepithelial lesions: histologic, cytologic, and viral correlates. Obstet Gynecol. Mar. 1992;79(3):338-346. [pmid: 1738511].
Takac I, Arko D, Kodric T, et al. Human telomerase gene amplification and high-risk human papillomavirus infection in women with cervical intra-epithelial neoplasia. J Int Med Res. Sep. 2009;37(5):1588-1595. [pmid: 19930867].
Xiao Y, Sato S, Oguchi T, et al. High sensitivity of PCR in situ hybridization for the detection of human papillomavirus infection in uterine cervical neoplasias. Gynecol Oncol. Aug. 2001;82(2):350-354. [pmid: 11531292].
Wright TC, Kilpatrick M, Tsipouras P. Chromosome 3q gain identified using FISH discriminates between CIN 3 and normal cervical biopsies. J Lower Genital Tract Dis. Apr. Supplement 15. 2012;16:S16. [abstract].
Zheng L, Liu AL, Qi T, et al. Human telomerase RNA gene amplification detection increases the specificity of cervical intraepithelial neoplasia screening. Int J Gynecol Cancer. Aug. 2010;20(6):912-917. [pmid: 20683395].