# Search Strategy

We performed two automated searches on November 7, 2011: one in MEDLINE and the Cochrane Central Register of Controlled Trials; the other was in the Scopus database to capture citations in Embase. After reduplication of the two search yields, we identified a total of 1441 unique abstracts to screen for inclusion. We reran the same two searches on July 12, 2012, to update our yield; this search identified 21 additional abstracts.

## SEARCH 1

Databases:

1. Ovid MEDLINE ® without Revisions 1996 to October Week 2 2011
2. Ovid MEDLINE ® 1948 to October Week 2 2011
3. Ovid MEDLINE ® In-Process & Other Non-Indexed Citations October 24, 2011
4. EBM Reviews-Cochrane Central Register of Controlled Trials 4th Quarter 2011

Table A1 Search Terms

# | Searches | Brief description of terms | Number of abstracts
1 | in situ hybridization.af | Terms related to test of interest | 106611
2 | in situ hybridization.sh | Terms related to test of interest | 45501
3 | (situ and hybridization).af | Terms related to test of interest | 108832
4 | in situ hybridization, fluorescence.sh | Terms related to test of interest | 31122
5 | (situ and hybridization and fluorescence).af | Terms related to test of interest | 37588
6 | fluorescence in situ hybridization.af | Terms related to test of interest | 17824
7 | in situ hybridization, fluorescence.af | Terms related to test of interest | 31126
8 | or/1-7 | Terms related to test of interest | 108832
9 | uterine cervical neoplasms.sh | Terms related to the disease of interest | 55036
10 | (uterine and cervical and neoplasms).af | Terms related to the disease of interest | 56825
11 | uterine cervical neoplasms.af | Terms related to the disease of interest | 55047
12 | (cervical and neoplasm).af | Terms related to the disease of interest | 18198
13 | cervical neoplasm.af | Terms related to the disease of interest | 92
14 | cervical intraepithelial neoplasia.sh | Terms related to the disease of interest | 6478
15 | uterine cervical dysplasia.af | Terms related to the disease of interest | 3420
16 | uterine cervical dysplasia.sh | Terms related to the disease of interest | 3416
17 | or/9-16 | Terms related to the disease of interest | 63287
18 | ((precancerous conditions and cervic$) or cervix uteri).af | Terms related to the disease of interest | 25551
19 | ((precancerous conditions and cervic$) or cervix uteri).sh | Terms related to the disease of interest | 21360
20 | 18 or 19 | Terms related to the disease of interest | 25551
21 | 17 or 20 | Terms related to the disease of interest | 79043
22 | 8 and 21 | | 1198

The above search strategy was tested against the studies referenced in the bibliography of the test manufacturer’s website. The search identified all relevant studies.

## SEARCH 2

Database: Scopus

Search terms ALL(in situ hybridization OR fluorescence in situ hybridization) AND ALL(cervical neoplasms OR cervical intraepithelial neoplasia OR cervical dysplasia)

Number of abstracts: 1441 from all years (included all 1198 captured in the above search)