# Executive Summary

## Background

### Overview

Cervical cancer is a highly preventable disease. Most cases are related to infection with human papillomavirus (HPV).1 Persistent cervical infection with high-risk, oncogenic HPV genotypes is necessary for the development of cervical cancer and its immediate precursor lesion, high-grade cervical intraepithelial neoplasia (CIN).2 Progression is generally slow and screening for cervical cancer has the potential to detect precancerous lesions and cancers in early stages, which can be effectively treated. Thus, in the United States, regular screening is recommended for all women between the ages of 21 and 65 years.3

Incidence and mortality rates for cervical cancer vary globally, depending on the availability of cervical screening and prevention programs. In the United States, which has widespread screening practices, there were more than 12,000 new cases of cervical cancer and 4,220 related deaths in 2011. 1,4

The screening tests currently used in the United States on cervical cell samples include the Papanicolaou (Pap) test to detect cellular changes, as well as tests for high-risk HPV genotypes. Although both tests identify a large proportion of women who harbor high-grade CIN, in a large number of women abnormalities detected on these tests will spontaneously resolve or will not be confirmed on histologic examination by colposcopy. A particular challenge is the management of women with test results of atypical squamous cells of unknown significance (ASCUS) or of low-grade squamous intraepithelial lesions (LSIL) on cytology or those with a normal Pap test but a positive test for high-risk HPV genotypes, since only a fraction of these women will have a finding on colposcopically directed tissue biopsy that warrants treatment. The median percentage of all Pap tests reported by various U.S. laboratories in 2009 for ASCUS ranged from 2.9 to 4.8 percent and for LSIL, from 1.2 to 2.8 percent, depending on the cytology preparation method (according to the College of American Pathologists Laboratory Accreditation Program). 5 Less than one-fifth of women with these findings will have a finding on colposcopically directed biopsy that warrants treatment.6 Colposcopy incurs expense and may be associated with adverse events.7,8 Another complication of an ablative procedure is that on subsequent cervical cancer screening, if a screening test comes back abnormal, it can be difficult to visualize the lesion and allow the lesion to be optimally treated. Thus, testing strategies that can more accurately triage patients to colposcopy are needed, to minimize overtreatment. Tests being marketed and offered by some laboratories include in situ hybridization (ISH) tests to detect chromosomal abnormalities or HPV DNA.

This Technology Assessment (TA) examines the role of in situ hybridization (ISH) tests, including fluorescence ISH (FISH), to detect chromosomal abnormalities or HPV DNA on cervical cytologic specimens and their clinical validity for identification of precancerous lesions or cervical cancer.

### Terminology for Cervical Lesions

In the United States, most laboratories use the Bethesda System for reporting cervical cytology findings (Table A).9

Table A The 2001 Bethesda System for Reporting Cervical Cytology10

Specimen Type Indicate: conventional test (Pap test), liquid-based preparation, or other
Specimen Adequacy; - Satisfactory for evaluation (describe presence/absence or endocervical/transformation zone component and any other quality indicators, e.g., partially obscuring blood inflammation, etc.); - Unsatisfactory for evaluation (specify reason); - Specimen rejected/not processed (specify reason); - Specimen processed and examined, but unsatisfactory for evaluation of epithelial abnormality because of (specify reason)
General Categorization (Optional); - Negative for intraepithelial lesion or malignancy; - Other: see Interpretation/Result (e.g., endometrial cells in a woman aged 40 years or older); - Epithelial cell abnormality: See interpretation/Result (specify “squamous” or “glandular” as appropriate)
Interpretation/Result; - Negative for intraepithelial lesion or malignancy (when there is no cellular evidence of neoplasia, state this in the General Categorization above, in the Interpretation/Result section of the report, or both-whether or not there are organisms or other nonneoplastic findings); - Organisms; - Trichomonas vaginalis; - Fungal organisms morphologically consistent with Candida species; - Shift in flora suggestive of bacterial vaginosis; - Bacteria morphologically consistent with Actinomyces species; - Cellular changes consistent with herpes simplex virus; - Other nonneoplastic findings (optional to report; list not inclusive); - Reactive cellular changes associated with; - Inflammation (includes typical repair); - Radiation; - Intrauterine device; - Glandular cells status posthysterectomy; - Atrophy; - Other (list not comprehensive); - Endometrial cells (in a woman aged 40 years or older)(specify if negative for squamous intraepithelial lesion); - Epithelial cell abnormalities; - Squamous cell; - Atypical squamous cells (ASC); - Of undetermined significance (ASC-US); - Cannot exclude HSIL (ASC-H); - Low-grade squamous intraepithelial lesion (LSIL) (encompassing: human papillomavirus/mild dysplasia/cervical intraepithelial neoplasia (CIN) 1; - High-grade squamous intraepithelial lesion (HSIL) (encompassing: moderate and severe dysplasia, carcinoma in situ; CIN2 and CIN3); - With features suspicious for invasion (if invasion is suspected); - Squamous cell carcinoma; - Glandular cell; - Atypical; - Endocervical cells (not otherwise specified or specifyin comments); - Endometrial cells (not otherwise specified or specify in comments); - Glandular cells (not otherwise specified or specify in comments); - Atypical; - Endocervical cells, favor neoplastic; - Glandular cells, favor neoplastic; - Endocervical adenocarcinoma in situ (AIS); - Adenocarcinoma; - Endocervical; - Endometrial; - Extrauterine; - Not otherwise specified; - Other malignant neoplasms (specify)
Ancillary Testing Provide a brief description of the test method(s) and report the result so that it is easily understood by the clinician. Automated Review If case examined by automated device, specify device and result
Educational Notes and Suggestions (Optional) Suggestions should be concise and consistent with clinical followup guidelines published by professional organizations (references to relevant publications may be included)

Histologic changes (those detected on biopsy) are described as cervical intraepithelial neoplasia (CIN). CIN is categorized, according to the depth of involvement and the atypicality of the cell, into three degrees of severity. CIN1 is considered a low-grade lesion. It refers to mildly atypical cellular changes in the lower third of the epithelium (formerly called mild dysplasia). HPV-induced cytopathic effects (koilocytotic atypia) are often present. CIN2 is considered a high-grade lesion. It refers to moderately atypical cellular changes confined to the basal two-thirds of the epithelium (formerly called moderate dysplasia) with preservation of epithelial maturation. CIN3 is also considered a high-grade lesion, but it refers to severely atypical cellular changes encompassing greater than two-thirds of the epithelial thickness and includes full-thickness lesions (formerly called severe dysplasia or carcinoma in situ). Invasive cancer may also be diagnosed on histology.

Recent consensus recommendations by the Lower Anogenital Squamous Terminology (LAST) initiative aim to unify the terminology for HPV-associated lower anogenital lesions.2 This new terminology classifies into a two-tiered system of low-grade squamous intraepithelial lesions (LSIL) and high-grade intraepithelial lesion (HSIL), similar to the Pap testing classification. The pathologist must still determine the CIN category on the basis of what proportion of the epithelium is involved (lower one-third, lower two-thirds, or full thickness) and then stratify to LSIL or HSIL. CIN1 under the old classification maps to LSIL, and CIN3 maps to HSIL. CIN2 is a biologically equivocal lesion and if this diagnosis is entertained by a pathologist, LAST recommends stratification to high-grade or low-grade disease on the basis of p16 immunohistochemistry. The LAST classification is not yet broadly used.

Generally, a higher grade of cytology indicates a greater risk for higher-grade histology, but cytology may also be associated with both more or less severe histologic findings.

### Cervical Human Papillomavirus Infection in Cervical Cancer

HPV testing detects the presence of HPV DNA. Even though cervical abnormalities may not be present or may not develop in every person with an HPV infection, infection with specific high-risk genotypes of HPV is associated with risk for precancer or cancer. Of the approximately 30 to 40 HPV genotypes that infect the mucosa of the genital tract, 8 (types 16, 18, 31, 33, 35, 45, 52, and 58) are responsible for over 90 percent of cervical cancers and are therefore called “high-risk” types. Two of these types (types 16 and 18) are alone responsible for about 70 percent of cervical cancers.11–13

### Cytologic Screening for Cervical Cancer

Screening tests are performed on a sample of cervical cells obtained from scraping the cervix during a speculum examination, called a Pap test. Conventional cervical samples are prepared by smearing the specimen on a slide. Liquid-based preparation involves placing the specimen into a liquid fixative solution (e.g., ThinPrep or SurePath).

The Pap test is widely performed to screen for precancerous or cancerous changes in cervical cells and is usually reported in the United States according to the Bethesda system (see Table A above). LSIL, especially in young women, is generally associated with a transient HPV infection, whereas a finding of high-grade squamous intraepithelial lesion (HSIL) is more likely to be associated with persistent HPV infection and a higher risk of progression to cervical cancer.14

If abnormal cells are detected on Pap testing, then further evaluation is conducted, with a colposcopy, a procedure in which the cervix is viewed at high magnification, and colposcopically directed cervical biopsy. 15Increasingly, HPV testing is done either reflexively on abnormal Pap tests or concurrently with Pap testing to aid risk stratification before proceeding to colposcopy, as described in a section below.

Histology allows for triage to either a low or a high-grade lesion, with the latter requiring ablative therapy (loop electrosurgical excision procedure [LEEP], conization, or cryosurgery). Histologic examination is useful because it decreases the number of unnecessary ablative procedures, since some equivocal lesions on cytology will regress spontaneously or be so small that they cannot be identified on colposcopic sampling and presumably do not pose an immediate threat warranting definitive ablative therapies. On the other hand, high-grade lesions diagnosed by cytology have a low false positive rate. Therefore, a “see and treat” approach for patients with HSIL findings on cytology is acceptable. “See and treat” allows an ablation to take place upon the first colposcopic visit and avoids the cost of an additional colposcopic exam and histologic confirmation.

### Current Guidelines for Cervical Cancer Screening and Treatment

Recent guidelines issued by the U.S. Preventive Services Task Force (USPSTF)16 suggest screening with a Pap test every 3 years for all healthy women ages 21 through 65 years. The 2012 guidelines by American Cancer Society, the American Society for Colposcopy and Cervical Pathology, and the American Society for Clinical Pathology (ASCP)3 recommend cytology testing alone every 3 years, but in women aged 30–65 years, state a preference for HPV and cytology cotesting every 5-years. Given its improved performance over Pap testing alone in this age group, cotesting (Pap plus HPV testing) can be used for screening at less frequent intervals. Because few studies have sufficient numbers of cancer cases to assess cancer risk directly, the guidelines considered the absolute risk of CIN3, including the rare cases of cancer (CIN3+) prior to or at the visit after a given visit, as the best measure of the risk of incident cervical cancer. Screening by HPV testing alone (without concurrent Pap testing) is not currently recommended in the United States, but several clinical trials outside the United States in resource-poor settings have documented the value of “primary HPV screening”—that is, if the HPV test is negative, no other testing is needed, and if the test is positive, cytologic Pap testing is effective for triage because of the high specificity of Pap test findings.

Genotype-specific testing for HPV 16 or HPV 16/18 is only recommended as an option in one particular clinical setting: for women who have a normal Pap result and a positive HPV test. In these women, both tests should be repeated at an interval, or alternatively these women can undergo genotyping to determine whether they have infection with HPV16 and/or HPV 18. If positive on HPV16/18 testing, then colposcopy is recommended. If negative, then retesting after 1 year is recommended.

Recent guidelines by the American College of Gynecology (ACOG) specify that women with ASCUS on Pap testing and a negative HPV test continue with routine screening as indicated for their age.17

All guidelines recommend against screening for cervical cancer in women over the age of 65 years who have had negative results on an adequate number of previous screening tests (with “adequate number” defined as three consecutive negative Pap results or two negative Pap and HPV tests in the prior 10 years, with the most recent within the previous 5 years). Finally, women who have been vaccinated against HPV should begin cervical cancer screening at the same age as unvaccinated women (i.e., at 21 years).

### Principles of ISH

ISH is a technique that is used to detect and localize the presence or absence of a specific genetic sequence in cells using a probe with a complementary polynucleotide sequence. The probe is either directly tagged with a fluorescent compound such as Texas Red (in FISH) or indirectly tagged with biotin (historically) or digoxigenin or dinitrophenol (more recently). After binding to the complementary sequences in the cell, the probes are either visualized under ultraviolet (UV) light (in FISH) or located using antibodies to the chemical tag and visualized using direct light (in chromogenic in situ hybridization [CISH]) or UV light (in FISH). Gains of a region are seen as additional spots in the cell, while deletions are seen as a loss of spots. The majority of probes in use are “cocktails” that combine the region of interest with a control probe, and loss or gain is determined with respect to the number of control signals. The technique is used to detect recurrent diagnostic changes in hematological malignancies (such as a deletion in the long arm of chromosome 5 in myelodysplastic syndrome), to look for gene amplification (e.g., of the HER2/neu gene in breast cancer), and to detect specific gene rearrangements that can be treated with particular drugs (e.g., ALK gene rearrangement in non–small-cell lung cancer, translocation 9 and 22 in chronic myeloid leukemia).

The resolution of ISH is limited by the size of the probe available for a region. The majority of commercially available ISH probes range in size from ~100 Kb to ~900 KB and will detect a genetic sequence of this size. Smaller sequences will not be detected. Scoring of ISH tests can be automated, reducing the potential for operator errors such as the evaluation of the wrong cell population or the incorrect area of a tumor section. Any ISH final interpretation must be rendered by a pathologist. The technique is reliable but requires appropriate specimen preparation for consistent results.18 Differentiating signals from experimental background can be problematic with CISH, but not with FISH.

### Potential for ISH Tests for Cervical Cancer Screening

ISH has been proposed as an additional noninvasive test on cervical smears to detect chromosomal abnormalities (markers of chromosomal damage) or HPV DNA. ISH testing on cervical specimens is not yet widely established, but some laboratories have developed their own tests, and manufacturers are starting to promote the use of ISH testing to triage women to colposcopy on the basis of their cytology, HPV result, and ISH test finding (e.g., www.cervicaldnadtextest.com/casestudies.php). This raises the question about the role of ISH as an add-on test when prior screening tests have yielded abnormal results.

### Key Questions

The four Key Questions in this TA were drafted by CMS and refined by the Evidence-based Practice Center through discussions with the Agency for Healthcare Research and Quality (AHRQ) Task Order Officer and CMS experts. Broadly, Key Question 1 asked for the results of a “horizon scan” to identify studies that have used any ISH tests on cervical cytologic or histologic samples and to identify the ISH probes most frequently studied; Key Question 2 asked to examine the analytic validity (technical performance) of the most frequently studied ISH tests for detection of markers of chromosomal damage or oncogenic HPV DNA; Key Question 3 asked to examine the clinical validity of ISH tests for detection of high-grade CIN or for prediction of cancer related clinical outcomes; and Key Question 4 asked to examine the clinical utility of ISH testing (i.e., how ISH testing impacts presumptive diagnosis, patient evaluation, management, and ultimately patients’ clinical outcomes). The Centers for Medicare and Medicaid Services (CMS) requested this TA to inform its decisionmaking about the coverage of this technology.

#### Key Question 1 What ISH tests have been used in cervical cytology or histology specimens?

To refine the scope for the detailed evidence review, we conducted a horizon scan to better understand the extent of the use of ISH tests for cervical cancer. On the basis of the findings of the horizon scan, we focused the subsequent review on ISH tests including probes for TERC (the telomerase RNA component gene, on chromosome 3, band 3q26), MYC (the myelocytomatosis oncogene, on chromosome 8, band 8q24), HPV 16, or HPV 18.

#### Key Question 2 For ISH tests for TERC or MYC or HPV 16 or HPV 18 in cervical cytology or cervical histology

a. What are the associations between ISH test results and reference test results? What thresholds were used for positive, indeterminate, and negative results of the ISH tests? What reference tests were used to assess the presence or absence of the genetic marker (TERC, MYC, or HPV 16 or 18)?
b. What is known about reliability and reproducibility of ISH tests? What genetic, environmental, or other factors are known to affect ISH test results (e.g., the presence of more than a certain proportion of necrotic tumor tissue in the sample or the presence of infection)?
c. Are there some conditions for which an ISH test is not able to give a clinically useable result?
d. What are the sample acceptance and rejection criteria for ISH tests?
e. What sample storage or preservation requirements are needed for a reliable ISH test result?
f. What variation occurs in results of the ISH test if performed in multiple laboratories?
g. What is the prevalence of the genetic marker(s) detected by the reference standards in Medicare beneficiaries by age or race/ethnicity?

#### Key Question 3 For ISH tests for TERC or MYC or HPV 16 or HPV 18

a. What is the association between ISH tests on cytology for high-grade CIN or cervical cancer on histopathology or for clinical outcomes related to cervical cancer morbidity and mortality? What thresholds were used for positive, indeterminate, and negative results on the ISH tests?
b. How similar are the spectrum and prevalence of the histopathological abnormalities and cervical cancers found in the studies to the spectrum and prevalence in Medicare beneficiaries? How is diagnostic accuracy modulated by age, race, and ethnicity?

#### Key Question 4 For ISH tests for TERC or MYC or HPV 16 or HPV 18 in cervical cytology, what is the published evidence about the test’s clinical utility and harms?

a. In comparative studies of ISH testing versus alternative testing (with similar or equivalent tests) or no testing, what is the effect on diagnostic thinking, evaluation, management, or clinical outcomes?
b. What are the clinical inclusion criteria in the studies? How similar are the populations to the core Medicare population (i.e., persons ≥65 years of age) overall as well as according to race/ethnicity?
c. How similar are the spectrum and prevalence of the cancers in these studies to the spectrum and prevalence in the core Medicare population?

### Analytic Framework

The overarching analytic framework for the report is shown in Figure A. Key Question 1 relates to a horizon scan of the literature to identify the most relevant ISH tests for subsequent detailed evidence review. Key Question 2 pertains to analytic validity, Key Question 3 to clinical validity, and Key Question 4 to clinical utility.

Key Question 3 was further focused on specific clinical scenarios according to currently recommended screening options in 2012 clinical practice guidelines (described above).3,16 Under current guidelines, a woman whose Pap results show HSIL or ASC-H would be referred to colposcopy; whereas a woman with normal Pap or a woman with a normal Pap and a normal HPV results would be retested after a certain period. This leaves women with ASCUS or LSIL on Pap testing and those with a positive test for high-risk HPV, for whom additional testing with ISH might have a role as an add-on test instead of directly proceeding to colposcopy and as an alternative to non–ISH-based HPV 16/18 testing.

Figure A Analytic Framework

The key questions (KQs) are shown within the context of the population, tests, and outcomes. KQ1 reviews the existing literature on what in situ hybridization (ISH) test has been used in women tested for cervical cancer; KQ2 addresses the analytic validity of ISH testing to detect chromosomal abnormalities or high-risk HPV genotypes; KQ3 addresses the clinical validity of ISH testing to detect precancer or cancer; and KQ4 addresses the clinical utility of ISH testing to predict clinical outcomes, to affect diagnostic thinking, evaluation, and management and to ascertain harms.

Figure A shows the analytic framework for the report as a flow diagram. The key questions (KQs) are shown within the context of the PICO (population, intervention, comparators, and outcomes) criteria. KQ1 addresses the existing literature describing the use of fluorescence in situ hybridization (FISH) testing in the context of cervical cancer screening; KQ2, the analytic validity of FISH testing to detect genetic abnormalities; KQ3, the clinical validity of FISH testing to detect cervical dysplasia or malignancy; and KQ4, the clinical utility of FISH testing to predict clinical outcomes, to affect diagnostic thinking, evaluation, and management, and to ascertain harms.

## Methods

### Data Sources, Study Selection, and Data Extraction

The search was conducted in MEDLINE^®^, SciVerse Scopus (including Embase) (Elsevier), and the Cochrane Central Register of Controlled Trials and had no language restrictions. Key words included terms related to the test of interest (in situ hybridization) and terms related to cervical cancer or abnormalities (cervical, precancerous, neoplasm, and cervical intraepithelial neoplasia). The first search was performed on November 7, 2011; the update search was conducted on July 12, 2012. We also searched the sections on gynecologic cancer for the past 2 years of proceedings of major gynecology and oncology conferences. Studies were eligible if they provided relevant data on cervical tissue samples from at least 10 women examined with ISH tests in a clinical or research setting.

For Key Question 1, we included studies that described any ISH testing and mentioned cervical cytologic grade (e.g., ASCUS, LSIL, or normal cytology in combination with a positive HPV test) or cervical histologic grade or cancer stage (e.g., CIN or squamous-cell carcinoma). We excluded studies of cervical cell lines and reviews without primary data.

For Key Question 2a, we included any study that examined an ISH test for TERC, MYC, HPV 16, or HPV 18 (with or without additional probes) in cervical cytology or histology specimens and compared these ISH tests with a non-ISH reference test. We included studies that applied both ISH and reference test in the same cervical specimen, either cytologic or histologic, regardless of classification. Studies had to provide data that allowed for the reconstruction of 2×2 tables for the results of index and reference tests. We described the agreement between tests as the percent of those with concordant results (either positive or both negative) divided by the number of all samples tested. For Key Questions 2b–f, we reviewed studies eligible for Key Questions 2a, 3, or 4 for pertinent narrative or quantitative information on reliability and reproducibility of ISH tests and possible factors interfering with analytic test performance. For Key Question 2g, we conducted a focused search for literature on the prevalence of the markers detected by ISH by age or race/ethnicity in the United States.

For Key Question 3a, we included any study that examined ISH testing for TERC, MYC, HPV 16, or HPV 18 (alone or in combination with other probes) in cervical cytology samples to detect high-grade CIN or cervical cancer (or related clinical outcomes). We extracted ISH findings for each of the following groups: ASCUS, LSIL along with HPV status, and normal cytology if HPV positive. While the Bethesda nomenclature has evolved to further divide ASCUS into ASCUS and ASC-H, we were limited to using ASCUS as the term was used in the studies. If the study differentiated ASC-US and ASC-H, we included results for ASC-US only. Histology outcomes had to be classified as CIN and had to be expressible as either CIN3+ (i.e., CIN3 or cervical cancer) or CIN2+ (i.e., CIN2, CIN3, or cervical cancer). Studies included in this review had not uniformly adopted the recently published LAST nomenclature to categorize histology into HSIL or LSIL. Studies had to provide data on clinical validity, including sensitivity and specificity. We also looked within each study for comparisons of different test combinations that included ISH tests. For Key Question 3b, we conducted a focused review for information on population-based prevalence of CIN2+ and CIN3+, stratified for LSIL or ASCUS in Medicare beneficiaries.

For Key Question 4, we searched for studies that compared patient management strategies using different screening or testing algorithms. We considered strategies that compare different test thresholds or different combinations of ISH and/or non-ISH tests. Outcomes of interest were impacts on diagnostic thinking, evaluation, and management and clinical outcomes.

Study data were extracted into customized forms and tables. Data elements were related to study design, population characteristics, cytologic classification, HPV status, sampling, test characteristics, outcomes, and study results.

### Assessment of Risk of Bias and Completeness of Reporting for Individual Studies

For Key Question 2, we graded each study according to 11 items, based on an approach for assessing quality and reporting for studies on analytic validity recently proposed by Sun et al.19 in an AHRQ Methods Report. For Key Question 3, study quality was assessed according to the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) 2 instrument.20

### Data Synthesis and Grading Strength of Evidence

Evidence tables summarize study and sample characteristics, detailed descriptions of index tests and reference tests, outcomes, study quality, and relevant study results. Results were graphed.

For our survey of the literature on the most commonly used ISH probes in Key Question 1, no grading was performed. Neither did we assess strength of evidence for Key Question 2. For Key Question 4, we planned to rate the body of evidence based on risk of bias, consistency, directness, and precision for comparative studies.21,22 However, we found no comparative studies.

For Key Question 3, we followed the Methods Guide 21,22 to evaluate the strength of evidence with respect to four domains: risk of bias, consistency, directness, and precision. Risk of bias relied on the overall summary of the quality and reporting assessed with the QUADAS-2 tool. It was summarized as low, high, or unclear. We also rated the body of evidence on the basis of four strength of evidence levels (high, moderate, low, and insufficient21,22) to indicate our level of confidence that the evidence reflects the true effect for the major comparisons of interest.

### Applicability

We did not assess applicability of studies reviewed for Key Question 2 for analytic validity because they addressed technical test performance, which is not pertinent to the issue of applicability to a patient population.

We did appraise the applicability of studies reviewed for Key Question 3 using the QUADAS-2 applicability items. We also considered how the study characteristics, for example study county, might impact applicability to the general U.S. population of screened women.

## Results

### Overall Literature Yield

Our searches identified a total of 1462 abstracts, of which we screened 227 in full text and included 135 in the horizon scan for Key Question 1 (Figure B). Twenty-five studies were included for Key Questions 2 and 3: 16 studies addressed Key Question 2, and 10 studies addressed Key Question 3, with 1 study providing data for both of these key questions. One study was in Chinese; the others were all published in English. No studies addressed Key Question 4.

Figure B Literature Flow Diagram

Studies could have had more than one reason for exclusion but only one reason for each is listed here.

FISH=fluorescence in situ hybridization; HPV=human palillomavirus; ISH=in situ hybridization; KQ=Key Question; MYC=myelocytomatosis oncogene; PCR=polymerase chain reaction; TERC=telomerase RNA component.

Figure B is a literature flow diagram illustrating the number of studies identified in the initial search (1462) through the final numbers of studies included for each of the four key questions: 134 studies were in for Key Question 1, which was a horizon scan; 16 studies were in for Key Question 2 about analytic validity of in situ hybridization (ISH) testing, 10 studies were in for Key Question 3 about clinical validity of ISH testing, and 0 studies were in for Key Question 4 about clinical utility and harms of ISH testing. The main reasons for rejection of articles reviewed in full text were that the ISH test did not use the probes of interest (in 19 studies), there was no analytic validity data (in 7 studies), there was no analytic validity data and also no cytologic specimens (in 69 studies), and ISH results were not reported for cytologic classification according to histologic classification (in 16 studies).

### Key Question 1 (Horizon Scan)

#### Key Question 1 What ISH Tests Have Been Used in Cervical Cytology or Histology Specimens?

A horizon scan of the literature was performed, identifying 135 articles that described the use of an ISH probe on cervical cytology or histology samples. The probes most commonly used were TERC (31 studies), MYC (7 studies, all of which also used a TERC probe), HPV 16 (91 studies), and HPV 18 (used in 87 of the 91 studies with an HPV probe). We focused the subsequent detailed evidence review (i.e., Key Questions 2–4) on the 116 studies using one or more of these four most common ISH probes; the remaining 19 studies did not use these probes and were not reviewed further.

Focusing the detailed evidence review on ISH tests for TERC (with or without MYC) was supported by the frequency of its use in the literature and by our narrative review of microarray studies, which suggest that gain of TERC is linked to high-grade cervical cancer (see the Background section). Including ISH probes for HPV 16 (with or without HPV 18) was supported by the findings of a large amount of literature on these tests and because HPV 16 and HPV 18 are well characterized as the two high-risk genotypes most strongly associated with cancer development.

### Key Question 2

#### Key Question 2a (Analytic Validity): For ISH tests for TERC or MYC or HPV 16 or HPV 18, what are the associations between ISH test results and reference test results? What thresholds were used? What reference standards were used?

##### Agreement Between ISH and Reference Tests

No studies provided data on the association between ISH for TERC or MYC and a DNA-based reference test with measurement on the same samples.

Fourteen studies compared ISH tests that included HPV 16 or HPV 18 with another HPV test in a total of 852 patients. The studies were heterogeneous with regard to the types of tissue, ISH test, and reference test; the HPV genotype; and the number of probes in either the ISH test or the reference test. The ISH tests used were specifically ISH in 10 studies, FISH in 1 study, catalyzed signal amplified colorimetric (CSAC) ISH in 1 study, catalyzed reporter deposition amplified (CARD) ISH in 1 study, and nonisotopic ISH in 1 study. The reference tests were PCR in 11 studies, in situ PCR in 2 studies, and Hybrid Capture 2 in 2 studies. The ISH test and the reference tests conspicuously varied in the HPV genotypes captured, both within and across studies.

The percent agreement between the ISH test and the reference test in each study (the sum of concordant results over the total number of test comparisons, expressed as percentage) ranged between 35 percent (95 percent CI, 15.4 to 59.2) to 100 percent (95 percent CI, 91.6 to 100). This variability in agreement was expected, given the true heterogeneity from comparison of tests with different principles of measurement and different target DNA. Also, the HPV probe sets used by ISH and by the reference test in each study often did not overlap. Given the substantial disagreement between tests across studies, is possible that index and reference tests provide complementary information and that combining these tests could increase diagnostic or prognostic accuracy.

##### Assessment of Risk of Bias and Completeness of Reporting

In general, study reporting was variable across questions used to assess risk of bias. All studies described the performance of the index tests in sufficient detail to permit replication. About half the studies reported use of both positive and negative samples and use of the same type of tissue for those controls. Some criteria for scoring test results were established a priori in the majority of studies. No studies reported on the six remaining items (reproducibility on testing of the same specimen multiple times; reproducibility across operators, instruments, reagent lots, different days of the week, different laboratories; yield of useable results; and multisite collaborative, proficiency testing, or interlaboratory exchange programs). Information on cross-reactivity was provided in only two studies. Overall, the assessment shows deficiencies in reporting, likely because most of the studies were not designed to specifically address analytic validity.

##### Thresholds Used for Positive, Indeterminate, and Negative Results of the ISH Tests

We reviewed information from the 14 articles using ISH with HPV probes as well as 10 studies reviewed for Key Question 3 (8 reporting on FISH for TERC and 3 reporting on FISH for HPV). Most of the studies of FISH with a TERC or MYC probe defined test result positivity by the presence of additional signals in two or three or more cells, often in combination with a threshold for cellular positivity (typically a ratio of the TERC or MYC probe and the chromosomal control probe), but there were no standard thresholds for test positivity.

Two additional studies of FISH for TERC established the threshold for positivity for TERC gain by assaying cervical cytology samples from 20 women per study center who had normal Pap results and negative for HPV infection. The thresholds at four centers (one in one study and three in another) were 5.3 percent of cells with abnormal signals, 5.2 percent, 5.6 percent, and 6.4 percent. No statistical comparisons were performed.

For HPV, test positivity was usually defined simply by staining indicating the presence of HPV DNA in the nucleus of at least one cell, except in one study in which 30 or more cells had to have had staining for HPV for the sample to be deemed positive (for episomal infection).

#### Key Questions 2b–2f b) What is known about reliability and reproducibility of FISH tests? What factors affect FISH test results? c) Are there some conditions for which a FISH test is not useable? d) What are the sample criteria? e) What are the sample storage or preservation requirements? f) What variation occurs across laboratories?

To address Key Questions 2b through 2f, we looked at the 14 articles describing ISH with HPV probes as well as the 10 studies reviewed in detail for Key Question 3.

None of the studies reported on the true reliability of FISH results within a study or the genetic, environmental, or other factors and their impact on FISH results or addressed whether there are some conditions for which a FISH test is not able to give a clinically useable result. None of the studies addressed variation in ISH results across multiple laboratories.

Regarding sample acceptance and rejection criteria for FISH tests, there was limited evidence from single reports on possible causes of unreliable results, such as the type of fixative used (reflecting the age of the samples). A few studies described the ascertainment of the quality of DNA, by means of beta-globin testing, before including samples. Another study reported that the cytologic sample preparation (ThinPrep vs. SurePath) did not significantly affect positivity or negativity of FISH using probes for HPV.

Overall, for questions related to preanalytic issues impacting analytic validity, the data were sparse and highlighted a lack of commonly agreed upon test and validation standards.

#### Key Question 2g What is the prevalence of the genetic marker(s) detected by the reference standards in Medicare beneficiaries by age or race/ethnicity?

We conducted a focused search for literature on the prevalence of the markers detected by ISH (i.e., TERC, MYC, HPV 16, and HPV 18) by age or race/ethnicity in the United States. We did not find direct evidence.

### Key Question 3

For Key Question 3, we reviewed studies that examined the sensitivity or specificity of ISH tests in cytology samples for the diagnosis of high-grade CIN. We examined the role of ISH for add-on testing in 1) women who have a Pap test showing LSIL or ASCUS without a HPV test, and 2) in women who have a Pap test showing normal cytology or ASCUS as well as a positive HPV test.

#### Key Question 3a (Clinical Validity): What is the association between FISH test results on cytology and CIN or cervical cancer on histopathology? What thresholds were used?

Ten studies provided information on the clinical validity of FISH tests for CIN2+ or CIN3+. Of these, eight provided results for FISH with a probe for TERC (as well as FISH for MYC, in three of these); three provided results of FISH for HPV 16 or 18, 1 study for both TERC or MYC and HPV separately. In one study, all women were HPV positive (type not specified). HPV status in the other studies was not known.

##### Clinical Validity in LSIL Cytology Samples

###### FISH for TERC or MYC

Seven studies compared the clinical validity of TERC in LSIL for CIN2+; two examined FISH for TERC or MYC. Only one study tested patients who were all positive for HPV. In these studies, the sensitivity ranged from 0.24 to 1.00 and specificity ranged from 0.38 to 1.00. Meta-analysis of 7 studies of TERC in LSIL for CIN2+ found summary sensitivity of 0.76 (95 percent CI 0.60, 0.86) and summary specificity of 0.79 (95 percent CI 0.50, 0.93).

Five studies compared the clinical validity of TERC in LSIL for CIN3+, with two testing FISH for TERC or MYC. Again, only one study tested patients who were positive for HPV. In these studies, the sensitivity ranged from 0.45 to 0.93 and the specificity ranged from 0.42 to 1.00. Meta-analysis of five studies of TERC in LSIL for CIN3+ found summary sensitivity of 0.78 (95 percent CI 0.65, 0.87) and summary specificity of 0.79 (95 percent CI 0.51, 0.93).

###### FISH for TERC or MYC versus Other Tests

Two studies compared the performance of different tests or combinations of tests and their clinical validity in LSIL patients. One compared FISH testing for TERC or MYC, FISH for TERC or MYC or high-risk HPV, and Hybrid Capture 2 for high-risk HPV. For the diagnosis of CIN2+, testing with Hybrid Capture 2 for HPV was the most sensitive, whereas FISH for TERC or MYC was the most specific.

The other study compared FISH for TERC, Hybrid Capture 2 for HPV, and a combination of both. (We presumed that the combination was considered positive if either FISH or Hybrid Capture 2 was positive, although the study is unclear in this regard, given a consistent pattern of higher sensitivity and lower specificity from the combined test compared to either test alone.)

For the outcome of CIN2+, the combination of FISH and Hybrid Capture 2 appeared to be the most sensitive test, whereas FISH alone was the most specific. These results also held for the outcome of CIN3+.

###### FISH for HPV 16 or 18

Three studies examining FISH for HPV 16 or 18 (among other types) in women with LSIL provided data for the sensitivity and specificity in LSIL patients for the CIN2+ outcome. The sensitivities ranged from 0.75 to 0.81. The specificities ranged from 0.00 to 0.88. Two studies reported data for the outcome of CIN3+, showing similar sensitivities (0.83 and 0.80, respectively) with wide, overlapping CIs. The specificity was 0.42 in one study but only 0.17 in the other.

##### Clinical Validity in ASCUS Cytology Samples

###### FISH for TERC or MYC

Three studies assessed FISH for TERC (or TERC or MYC, in one study) and reported data by ASCUS cytology, one of which included patients positive for HPV (type not specified). Two of the studies provided data for the outcome of CIN2+: the sensitivity and specificity were 0.75 to 0.82 and 0.87 to 0.93, respectively. All three studies provided data for the CIN3+ outcome. Sensitivities ranged from 0.25 to 0.87. Specificities ranged from 0.67 to 0.89.

###### FISH for TERC versus Other Tests

One study compared FISH for TERC (not MYC), Hybrid Capture 2 for HPV, and a combination of FISH and Hybrid Capture 2 in women with ASCUS for CIN2+ and CIN3+. The results were similar to the corresponding findings in LSIL patients.

###### FISH for HPV 16 or 18

One study examined FISH for HPV 16 or 18 (among other types) in ASCUS patients for the CIN2+ outcome. The sensitivity was 1.00 and specificity was 0.57. Two studies examined FISH for HPV for the outcome of CIN3+, with sensitivities of 0.25 and 1.00 and specificities of 0.44 and 0.67.

##### Clinical Validity in HPV-Positive Normal Cytology Samples

We did not find relevant data in groups of women who were HPV test positive but had normal cytology.

##### Assessment of Risk of Bias and Completeness of Reporting for Individual Studies

Our assessment of study quality and reporting for the 10 studies of clinical validity (Key Question 3) was based on 18 questions related to assay performance and reporting thereof. Few studies reported information of recruitment and study design, although reporting of information on the index tests and references standards was generally adequate. Data on flow and timing was sparsely reported. All patients received the same reference standard, but inclusion of all patients was complete only in 50 percent of studies, resulting in variable clarity and bias resulting from patient flow. Overall, the reporting was frequently unclear, impeding the assessment of the risk of bias.

In contrast, concern regarding the applicability of studies to Key Question 3 was uniformly low, given the inclusion criteria for these studies.

##### Strength of Evidence

The strength of evidence for the studies on clinical validity reviewed for Key Question 3a was rated as low. The studies were generally small. The number of comparisons for each pair test–outcome pair was low. Reporting on items used for quality assessment was often unclear, yielding overall low methodological quality. Point estimates were heterogeneous. The CIs were often overlapping because of imprecise estimates. Across studies of FISH tests for HPV 16 or 18 (among other types), the panels of HPV probes used did not overlap, resulting in clinical heterogeneity.

Overall, the lower 95 percent confidence limit for sensitivity and specificity spanned 0.5 in a high proportion of studies, indicating that the test results may not distinguish between the presence or absence of FISH signals beyond chance. Thus, overall we have low confidence that the estimated clinical validity of the FISH test represents its true validity. The evidence was considered to be direct for clinical validity since the studies examined CIN2 or 3, which are meaningful outcomes for decisionmaking.

#### Key Question 3b How similar are the spectrum and prevalence of the histopathological abnormalities and cervical cancers between the studies and Medicare beneficiaries?

We conducted a focused review for information on population-based prevalence of CIN2+ and CIN3+, stratified for LSIL or ASCUS, in Medicare beneficiaries. We did not find any evidence. Further, the primary studies did not provide any unbiased estimates.

### Key Question 4 What are the clinical utility and harms for ISH tests in cervical cytology?

No studies compared patient care strategies resulting from different test thresholds or different combinations of ISH or non-ISH tests. This is not surprising, since ISH testing is not currently used in practice. Potential harms associated with colposcopy and biopsy include transient cervical bleeding and discharge or infection with fever and moderate-to-severe pain. Treatment with cervical conization can be complicated by cervical incompetence, resulting in fetal prematurity or infertility. An ablative procedure can also complicate subsequent testing for cervical cancer, as it makes it more difficult to visualize any lesions. Harms from false positive findings are anxiety and unnecessary procedures. Harms from false negative findings are the missed opportunity for early and potentially curative treatment.

## Discussion

### Key Findings and Strength of Evidence

Cervical cancer screening remains an evolving field with ongoing reevaluation of Pap screening practices and the role of HPV testing, as well as development of new technologies including ISH testing for genetic abnormalities. The key findings of this review and the strength of evidence are summarized in Table B.

Table B Key Findings and Strength of Evidence

Key Question | Population | Test/Assay | Outcome | Strength of Evidence Summary and Comments
1. Horizon scan | Women screened or tested for cervical cancer | Any ISH test | NA | SOE=NA 135 Articles described use of an ISH probe on cervical cytology or histology samples; - 31 Studies used ISH for TERC; 7 of these examined both TERC and MYC; - 91 Studies used ISH for HPV 16; 87 of these studies examined both HPV 16 and 18; - On the basis of these findings, we focused of the subsequent review on ISH for TERC, MYC, HPV 16, or HPV 18
2. Analytic validity | Women screened or tested for cervical cancer | Any ISH test for TERC, MYC, HPV 16, or HPV 18 | Agreement with reference test | SOE=NA No studies compared ISH test for TERC or MYC with DNA-based reference test 14 Studies compared ISH tests for HPV 16 or 18 (among other types) with various reference tests (mostly PCR and Hybrid Capture 2). Agreement was variable, indicating differences in measurement techniques between ISH and reference tests, as well as nonoverlapping panels of HPV probes. Assessment of study quality shows deficiencies in reporting, which may indicate low study quality. Overall, evidence for analytic validity of various ISH assays was limited.
| | | Thresholds | SOE=NA 14 Studies included for KQ2 and 10 studies included for KQ3 were examined for information on thresholds of positivity on ISH testing.; - Thresholds for ISH tests with TERC or MYC probes consisted of variable counts of signal-positive cells (three or more) and a range of different control probes for centromere or chromosome numbers.; - Test positivity for HPV DNA was dichotomized as detection versus no detection in most studies (except for one, which used a cutoff of 30 cells as positivity for episomal infection).; Two other studies provided information on threshold determination of FISH for TERC in samples from normal women across four laboratories (one in 1 study and three in the other); the value for a positive result ranged from 5.2–6.4 percent of cells with an abnormal signal (statistical comparison ND).
| | | Other preanalytic issues | SOE=NA For questions related to preanalytic issues impacting analytic validity, the data were sparse or not informative.
| | | Prevalence of genetic marker | SOE=NA No direct evidence for prevalence of the markers detected by ISH (i.e., TERC, MYC, HPV 16, and HPV 18) in US Medicare beneficiaries.
3a. Clinical validity | Women screened or tested for cervical cancer with finding of LSIL or ASCUS on cytology, with or without HPV infection | Any ISH test for TERC, MYC, HPV 16, or HPV 18 | CIN2+ or CIN3+ | SOE=low 10 Studies provided information on clinical validity of FISH tests for CIN2+ or CIN3+. Of these, 8 provided results for FISH on TERC (3 tested for TERC or MYC) and 3 studies provided results for FISH for HPV 16 or 18 (1 study tested both probe types, separately). In one study all women were HPV positive (type not reported); HPV status in the other studies was not known. Meta-analysis of 7 studies of TERC in LSIL for CIN2+ found summary sensitivity of 0.76 (95% CI 0.60, 0.86) and summary specificity of 0.79 (95% CI 0.50, 0.93). Meta-analysis of 5 studies of TERC in LSIL for CIN3+ found summary sensitivity of 0.78 (95% CI 0.65, 0.87) and summary specificity of 0.79 (95% CI 0.51,0.93). 2 Studies compared different test combinations.; - One compared results of FISH for TERC, Hybrid Capture 2 for high-risk HPV, and either test. FISH for TERC alone showed lower sensitivity but higher specificity than the combination of FISH or Hybrid Capture 2.; - The other study compared three test strategies: FISH for TERC or MYC, Hybrid Capture 2 for high-risk HPV, and FISH for TERC, MYC, or HPV. FISH for TERC or MYC alone showed lower sensitivity but higher specificity than either other test strategy.; For other cytology classifications and tests, the numbers of studies was limited. 3 Studies had data on FISH for TERC (without MYC) in women with ASCUS. One included only samples positive for HPV. There were also only 3 studies with data on FISH for HPV 16 or 18 in women with LSIL or ASCUS. Across all studies and tests, there was a trade-off between sensitivity and specificity, which may indicate a threshold effect. However, there was also great clinical heterogeneity across populations and test probes, Assessment of risk of bias showed low study quality or incomplete reporting. There was inconsistency in effect estimates and many were imprecise. The evidence was considered direct for clinical validity. Overall, the strength of evidence was graded as low, failing to show consistently better sensitivity or specificity with FISH testing for identification of CIN2+ or CIN3+ than would be expected by chance.
3a. Clinical validity | Women screened for cervical cancer with finding of LSIL or ASCUS, with or without HPV infection | Any ISH test for TERC, MYC, HPV 16, or HPV 18 | Clinical outcomes | SOE=insufficient No studies examined the association of ISH test results with clinical outcomes.
3b. Prevalence of the outcome in comparison to the Medicare population | | NA | Prevalence of disease (CIN2+ or 3+) | SOE=NA No direct evidence for prevalence of CIN2+ or 3+ in US Medicare beneficiaries.
4. Clinical utility | Women screened for cervical cancer | Any ISH test for TERC, MYC, HPV 16, or HPV 18 | Clinical outcomes | SOE=insufficient No studies compared patient care strategies among various tests, thresholds, or combinations of ISH or non-ISH tests. Potential harms associated with colposcopy and biopsy are transient cervical bleeding and discharge or infection with fever and moderate-to-severe pain. Cervical conization can be complicated by cervical stenosis or incompetence resulting in fetal prematurity or infertility. An ablative procedure can also complicate subsequent testing for cervical cancer, as it makes it more difficult to visualize any lesions. Harms from false positive findings are anxiety and unnecessary procedures. Harms from false negative findings are the missed opportunity for early and potentially curative treatment.

ASCUS=atypical squamous cells of undetermined significance, CI=confidence interval; CIN=cervical intraepithelial neoplasia, FISH=fluorescence in situ hybridization, HPV=human papillomavirus, ISH=in situ hybridization, KQ=key question, MYC=myelocytomatosis oncogene, NA=not applicable; LSIL=low-grade squamous intraepithelial lesion, NHANES=National Health and Nutrition Examination Survey; PCR=polymerase chain reaction, SOE=strength of evidence, TERC=telomerase RNA component gene, US=United States.

The horizon scan conducted for Key Question 1 led to the subsequent focus on ISH tests for TERC, MYC, HPV 16, or HPV 18 as tests for cervical abnormalities or cancer.

Our review of data on analytic validity for Key Question 2 revealed a paucity of evidence. We found no studies examining the association between ISH for TERC or MYC and another genetic test in cytology or histology samples. For HPV, we identified some studies for which we could examine the correlation between ISH and reference tests, namely PCR and Hybrid Capture 2. However, these tests measure different biological parameters since, unlike ISH, the reference HPV tests are not restricted to detecting nuclear episomal or integrated HPV. (In situ ISH testing for HPV, which is the only ISH that can identify integration into the genome, may add information beyond the most common ISH testing for 13 or 14 types of HPV or ISH for HPV 16 and 18, which only indicate HPV infection, not integration.)

Further, the panels of HPV genotypes tested for by ISH and the reference tests varied and were not completely overlapping. This heterogeneity limits the conclusions that can be drawn about analytic validity. Not surprisingly, the agreement between ISH tests and reference tests was inconsistent across the studies.

Risk of bias assessment of analytic validity studies showed variable detail of reporting, which was particularly poor for the reference tests. Review of the evidence on thresholds for ISH tests also showed incomplete reporting as well as variable thresholds of positivity and chromosomal control probes used. Information on other preanalytic issues was sparse or not informative. The lack of data on reproducibility is a major deficiency in the evidence base. This suggests a need for research to explore thresholds and standardize test procedures.

For Key Question 3 on clinical validity, the strength of evidence for ISH testing was graded as low, failing to show that the addition of ISH tests resulted in better clinical validity. Clinical practice guidelines suggest that ISH is a potential add-on test after initial Pap testing, with subsequent HPV testing, or after initial Pap and HPV cotesting. In this context, it is more desirable for ISH to show high specificity than high sensitivity. In our review, FISH testing did not show consistently increased sensitivity for the identification of CIN2+ or CIN3+ on histology, although it was more specific than other tests or test combinations. However, we cannot conclude that ISH testing would increase clinical validity of an overall screening strategy. As compared with FISH or Hybrid Capture 2 testing for HPV, FISH for TERC or MYC alone was more specific and less sensitive than the test combinations.

Regarding Key Question 4, we found no studies examining the association of ISH test results with clinical outcomes. There were also no comparative studies of strategies that include ISH tests that examined clinical utility, which would be of particular interest for colposcopy rates and histology results.

### Comparison with Current Knowledge

ISH tests are not used routinely used in screening for cervical cancer at this point. However, there is a need to improve the clinical validity of screening for cervical cancer. Thus there is a potential role for tests such as ISH. HPV tests for panels of high-risk genotypes have been shown to have a higher sensitivity but lower specificity that what we found for ISH tests.23 Thus, when cotesting is used, add-on tests with greater specificity may be useful. However, HPV testing is evolving, and new reference tests for HPV testing will change the performance of add-on tests. ISH may need to be examined as an alternative to tests that can identify HPV 16 and 18 individually. Further, the recent launch of HPV vaccination in adolescents is expected to change the natural history of HPV-associated cervical carcinoma going forward.

### Applicability

Formal appraisal of applicability of the Key Question 3 studies on clinical validity with the QUADAS-2 tool showed no major concern regarding applicability. However, studies included populations from around the world, with variable prevalence of HPV infections, CIN classes, and cervical cancer.

CMS has a particular interest in the Medicare population, whose core beneficiaries are 65 years of age or older. On the basis of the lower incidence of HPV infection and cervical cancer among older women who have undergone adequate screening than among younger women, the 2012 guidelines recommend cessation of screening after the age of 65 years (so long as screening tests were negative in the prior 10 years). Since a notable proportion of Medicare beneficiaries are younger than 65, the findings of the report are still relevant for CMS.

### Implications for Clinical and Policy Decisionmaking

The current evidence base is insufficient to consider routine ISH testing in the clinical scenarios analyzed in the report. Specifically the evidence is insufficient to recommend routine ISH testing for TERC, MYC, HPV 16 or 18 in women screened or tested for cervical cancer with a finding of LSIL or ASCUS on cytology, with or without HPV infection.

### Limitations

Our review is limited to published reports, which usually do not allow for detailed analysis of individual patient data for subgroups of interest. Studies evaluating more than one test approach did not include cross-tabulation of positive and negative test results across all tests. Our review addresses a limited scope based on what was determined to be the most meaningful clinical questions. Given our stringent inclusion criteria for articles, requiring the mention of cytologic or histologic sampling in the abstract, we may have missed studies that could have contributed additional data for the review of analytic validity.

Regarding Key Question 3 on clinical validity of ISH in particular, the identified evidence base was limited. Studies were generally small and those that we could meta-analyze yielded imprecise effect estimates. Study samples often were from sample banks or databanks, limiting the applicability to the screening population. With one exception, the included studies did not unequivocally report or stratify by HPV status. Studies conducted before the Bethesda terminology change that divided ASCUS into ASC-US and ASC-H may have included a mix of ASC-US and ASC-H in their ASCUS group. There was clinical heterogeneity among the results, given the variety of ISH probe panels used across studies and differences between ISH and the reference tests within studies. In addition, the reporting of study quality items was deficient. No studies examined risk prediction with ISH or the test’s clinical utility or addressed screening for cervical adenocarcinoma in particular.

### Research Gaps

Our review reveals four major research gaps. First, the assessment of the analytic validity of ISH (Key Question 2) highlights a need to establish common thresholds, probe sets, controls, and procedures. An expert conference may be helpful to agree on common measurement guidelines, a path that was successfully pursued to arrive at the consensus Bethesda classification for cytological abnormalities in cervical cancer. Scoring of ISH slides can be time-consuming. Automated approaches are promising, but in order for ISH to become a routine test, the evaluation of test results needs to be standardized and accelerated.

Second, bigger studies are needed to yield more precise estimates and to have adequate numbers of individuals with CIN3+ on histology, which is considered a more valid marker for the risk to cancer progression than CIN2+. Third, future research should reflect changes in clinical practice. On the basis of the current guidelines, it can be expected that Pap with reflexive HPV testing or Pap–HPV cotesting will become more widely used. This will require study of the clinical validity of ISH as an add-on test in groups of women characterized as having a normal Pap or ASCUS or LSIL along with a positive or negative HPV test. It is also expected that HPV testing will eventually be able to routinely identify not only high-risk HPV genotypes broadly but also HPV 16 and 18 individually, with the use of either sequential or combined tests. This will require reevaluation of the role of ISH, which we considered in this review as a hypothetical alternative to testing for HPV 16 or HPV 18. Development of automated HPV testing may provide an incentive to explore the performance of up-front HPV testing rather than Pap testing, since testing of cervical cytologic specimens requires a trained human operator. This would generate another constellation in which to study the value added by ISH testing.

Fourth, changes in terminology should be followed in future studies, specifically the differentiation between ASC-US and ASC-H and the use of LAST terminology, including p16 staining in ambiguous cases for classifying histology as LSIL or HSIL. Fifth, further evaluation of clinical validity of ISH should be better designed to achieve this aim. Studies could examine ISH testing for not only a single probe (such as TERC) but also panels of probes, for example for both TERC and HPV. Ideally, large studies would allow for the comparison of multiple tests in order to make it possible to select tests with best analytic validity as well as clinical validity for CIN. However, to measure false negative rates, colposcopy would need to be performed in patients with negative screening tests. Such studies should therefore identify the tests, thresholds, and combinations that are most promising for further evaluation of clinical utility. Efficient exploration of the correct test use (i.e., the testing with the best performance) would again be conducted with several promising tests, thresholds, and test combinations studied simultaneously in a sufficiently large sample on the same specimens and follow patients with routine or test-directed care to assess impacts on diagnostic thinking, evaluation, management, and clinical outcomes. Projecting the clinical utility of different tests may entail modeling of data from different studies in decision analyses.

Lastly, the role ISH testing for detection of adenocarcinoma should be examined. The variability in chromosomal aberrations between squamous-cell cancer and adenocarcinoma suggests that a panel of ISH probes, rather than a single probe, would capture a greater variety of chromosomal changes.

### Conclusions

This report shows an emerging body of literature on ISH testing for cervical cancer. Although ISH tests are marketed by some laboratories for triaging women with abnormal screening tests, there is a lack of standardization of probes and procedures that needs to be addressed. The role of add-on ISH testing has not been adequately examined in current screening contexts, that is, after HPV and Pap testing. Further, HPV testing is likely to evolve, for example with primary screening for 13 or 14 HPV genotypes or with wider availability of HPV16/18 testing. This will again require reexamination of the role of add-on tests such as ISH, and its impact not only on diagnostic utility but also on clinical utility (in particular colposcopy) and on clinical outcomes. Thus, the evidence is currently too immature to suggest ISH testing for routine practice.

## Acronyms

AHRQ: Agency for Healthcare Research and Quality
ASCP: American Society for Clinical Pathology
ASC-H: Atypical squamous cells, cannot exclude HSIL
ASCUS (cytologic classification): Atypical squamous cells of undetermined significance
CIN: Cervical intraepithelial neoplasia, with mild dysplasia (CIN1), moderate dysplasia (CIN2), or severe dysplasia (CIN3)
CMS: Centers for Medicare and Medicaid Services
FISH: Fluorescence in situ hybridization
HPV: Human papillomavirus
HSIL: High-grade squamous intraepithelial lesion
ISH: In situ hybridization
LSIL: Low-grade squamous intraepithelial lesion
MYC: Myelocytomatosis oncogene (on chromosome 8, band q24)
Pap test: Papanicolaou test (of cervical cytology)
QUADAS-2: Quality Assessment of Diagnostic Accuracy Studies 2
SCC: Squamous-cell carcinoma
TERC: Telomerase RNA component gene (on chromosome 3, band q26)
USPSTF: U.S. Preventive Services Task Force

### References

1 World Health Organisation. Cervical cancer, human papillomavirus (HPV), and HPV vaccines. WHO/RHR/08.14. Geneva, Switzerland. WHO Press. 2007.
2 Darragh TM, Colgan TJ, Cox JT, et al. The Lower Anogenital Squamous Terminology Standardization Project for HPV-Associated Lesions: background and consensus recommendations from the College of American Pathologists and the American Society for Colposcopy and Cervical Pathology. Arch Pathol Lab Med. Oct. 2012;136(10):1266-1297. [pmid: 22742517].
3 Saslow D, Solomon D, Lawson HW, et al. American Cancer Society, American Society for Colposcopy and Cervical Pathology, and American Society for Clinical Pathology screening guidelines for the prevention and early detection of cervical cancer. CA Cancer J Clin. May. 2012;62(3):147-172. [pmid: 22422631].
4 American Cancer Society. Cancer Facts & Figures 2011. 2011. Available at: http://www.cancer.org/Research/CancerFactsFigures/CancerFactsFigures/cancer-facts-figures-2011. Accessed on October 21, 2011.
5 College of American Pathologists. Cytopathology checklist: CAP Accreditation Program. College of American Pathologists. Northfield, IL. College of American Pathologists. 2012.
6 Kinney WK, Manos M, Hurley LB, et al. Where's the high-grade cervical neoplasia? The importance of minimally abnormal Papanicolaou diagnoses. Obstet Gynecol. 1998;91(6):973-976. [pmid: 9611007].
7 Rogstad KE. The psychological impact of abnormal cytology and colposcopy. BJOG: An International Journal of Obstetrics & Gynaecology. 2002;109(4):364-368. [pmid: 12013155].
8 The TOMBOLA (Trial Of Management of Borderline and Other Low-grade Abnormal smears) Group á. After-effects reported by women following colposcopy, cervical biopsies and LLETZ: results from the TOMBOLA trial. BJOG: An International Journal of Obstetrics & Gynaecology. 2009;116(11):1506-1514. [pmid: 19583712].
9 Solomon D, Davey D, Kurman R, et al. The 2001 Bethesda System: terminology for reporting results of cervical cytology. JAMA. Apr. 24. 2002;287(16):2114-2119. [pmid: 11966386].
10 The Bethesda System for Reporting Cervical Cytology. Seond Edition. New York. Springer-Verlag. 2004.
11 WHO/ICO Information Centre on HPV and Cervical Cancer. Human Papillomavirus and Related Cancers in World. Summary Report 2010. Accessed 11.20.2012. Barcelona, Spain. WHO Press. 2010.
12 Clifford G, Franceschi S, Diaz M, et al. Chapter 3: HPV type-distribution in women with and without cervical neoplastic diseases. Vaccine. Aug. 31. Suppl 3. 2006;24:S3-26-S3/34. [pmid: 16950015].
13 Kahn JA. HPV vaccination for the prevention of cervical intraepithelial neoplasia. N Engl J Med. Jul. 16. 2009;361(3):271-278. [pmid: 19605832].
14 Wright TC, Schiffman M. Adding a Test for Human Papillomavirus DNA to Cervical-Cancer Screening. N Engl J Med. Feb. 6. 2003;348(6):489-490. [pmid: 12571255].
15 Feldman S, Sirovich B, Goodman A. Screening for cervical cancer: rationale and recommendations. 2012. Available at: www.uptodate.com.
16 Moyer VA. Screening for Cervical Cancer: U.S. Preventive Services Task Force Recommendation Statement. Annals of Internal Medicine. Jun. 19. 2012;156(12):880-891. [pmid: 22711081].
17 Screening for cervical cancer. Obstet Gynecol. Nov. 2012;120(5):1222-1238. [pmid: 23090560].
18 Mascarello JT, Brothman AR, Davison K, et al. Proficiency testing for laboratories performing fluorescence in situ hybridization with chromosome-specific DNA probes. Arch Pathol Lab Med. Dec. 2002;126(12):1458-1462. [pmid: 12456204].
19 Sun F, Bruening W, Erinoff E, et al. Addressing challenges in genetic test evaluation. Rockville, MD. Agency for Healthcare Research and Quality. 2011. Available at: http://www.effectivehealthcare.ahrq.gov/ehc/products/105/704/Genetic-Test-Evaluation_Final-Report_20110615.pdf. Accessed on November 4, 2011.
20 Whiting PF, Rutjes AWS, Westwood ME, et al. QUADAS-2: A Revised Tool for the Quality Assessment of Diagnostic Accuracy Studies. Annals of Internal Medicine. Oct. 18. 2011;155(8):529-536. [pmid: 22007046].
21 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. AHRQ. 2011. Available at: http://www.effectivehealthcare.ahrq.gov/ehc/products/60/318/MethodsGuide_Prepublication_Draft_20110824.pdf.
22 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-523. [pmid: 19595577].
23 Ratnam S, Coutlee F, Fontaine D, et al. Aptima HPV E6/E7 mRNA test is as sensitive as Hybrid Capture 2 Assay but more specific at detecting cervical precancer and cancer. J Clin Microbiol. Feb. 2011;49(2):557-564. [pmid: 21147950].