# Acknowledgements

The authors gratefully acknowledge the Peer Reviewers for their contributions to this project.

## Peer Reviewers

- Amy Clayton, M.D.
  Assistant Professor of Pathology
  Mayo Clinic
  Rochester, Minnesota
- Andrew H. Fischer M.D.
  Professor of Pathology
  University of Massachusetts
  Worcester, Massachusetts
- Anna-Barbara Moscicki, M.D.
  Professor of Pediatrics
  University of California San Francisco
  San Francisco, California
- Mark Schiffman, M.D., M.P.H.
  Senior Investigator
  National Cancer Institute
  Bethesda, Maryland
- Nicolas Wentzensen, M.D., Ph.D.
  Investigator
  National Cancer Institute
  Bethesda, Maryland
- David C. Wilbur, M.D.
  Professor of Pathology
  Harvard Medical School
  Director of Pathology Imaging
  Massachusetts General Hospital
  Boston, Massachusetts