# Acronyms

ACOG: American Congress of Obstetricians and Gynecologists
ACS: American Cancer Society
AHRQ: Agency for Healthcare Research and Quality
ASCCP: American Society for Colposcopy and Cervical Pathology
ASCP: American Society for Clinical Pathology
ASC-H: Atypical squamous cells, cannot exclude HSIL
ASCUS: Atypical squamous cells of undetermined significance
CIN: Cervical intraepithelial neoplasia, with mild dysplasia (CIN1), moderate dysplasia (CIN2), or severe dysplasia (CIN3)
CMS: Centers for Medicare and Medicaid Services
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
FISH: Fluorescence in situ hybridization
HPV: Human papillomavirus
HSIL: High-grade squamous intraepithelial lesion
ISH: In situ hybridization
LSIL: Low-grade squamous intraepithelial lesion
MYC: Myelocytomatosis oncogene (on chromosome 8, band q24)
Pap test: Papanicolaou test (of cervical cytology)
PCR: Polymerase chain reaction
QUADAS-2: Quality Assessment of Diagnostic Accuracy Studies 2
SCC: Squamous-cell carcinoma
TA: Technology Assessment
TERC: Telomerase RNA component gene (on chromosome 3, band q26)
USPSTF: U.S. Preventive Services Task Force