# References

1 World Health Organisation. Cervical cancer, human papillomavirus (HPV), and HPV vaccines. WHO/RHR/08.14. Geneva, Switzerland. WHO Press. 2007.
2 Darragh TM, Colgan TJ, Cox JT, et al. The Lower Anogenital Squamous Terminology Standardization Project for HPV-Associated Lesions: background and consensus recommendations from the College of American Pathologists and the American Society for Colposcopy and Cervical Pathology. Arch Pathol Lab Med. Oct. 2012;136(10):1266-1297. [pmid: 22742517].
3 Saslow D, Solomon D, Lawson HW, et al. American Cancer Society, American Society for Colposcopy and Cervical Pathology, and American Society for Clinical Pathology screening guidelines for the prevention and early detection of cervical cancer. CA Cancer J Clin. May. 2012;62(3):147-172. [pmid: 22422631].
4 American Cancer Society. Cancer Facts & Figures 2011. 2011. Available at: http://www.cancer.org/Research/CancerFactsFigures/CancerFactsFigures/cancer-facts-figures-2011. Accessed on October 21, 2011.
5 College of American Pathologists. Cytopathology checklist: CAP Accreditation Program. College of American Pathologists. Northfield, IL. College of American Pathologists. 2012.
6 Kinney WK, Manos M, Hurley LB, et al. Where's the high-grade cervical neoplasia? The importance of minimally abnormal Papanicolaou diagnoses. Obstet Gynecol. 1998;91(6):973-76. [pmid: 9611007].
7 Rogstad KE. The psychological impact of abnormal cytology and colposcopy. BJOG: An International Journal of Obstetrics & Gynaecology. 2002;109(4):364-368. [pmid: 12013155].
8 The TOMBOLA (Trial Of Management of Borderline and Other Low-grade Abnormal smears) Group á. After-effects reported by women following colposcopy, cervical biopsies and LLETZ: results from the TOMBOLA trial. BJOG: An International Journal of Obstetrics & Gynaecology. 2009;116(11):1506-1514. [pmid: 19583712].
9 Solomon D, Davey D, Kurman R, et al. The 2001 Bethesda System: terminology for reporting results of cervical cytology. JAMA. Apr. 24. 2002;287(16):2114-2119. [pmid: 11966386].
10 The Bethesda System for Reporting Cervical Cytology. Second Edition. New York. Springer-Verlag. 2004.
11 National Cancer Institute. Cervical cancer screening. 2012. Available at: http://www.cancer.gov/cancertopics/pdq/screening/cervical/HealthProfessional/page2. Accessed on October 21, 2011.
12 CancerHelp UK. Cervical cancer risks and causes. 2012. Available at: http://cancerhelp.cancerresearchuk.org/type/cervical-cancer/about/cervical-cancer-risks-and-causes.
13 CancerQuest. Cervical Cancer: Risk Factors. 2012. Available at: http://www.cancerquest.org/cervical-cancer-risks.html.
14 Surveillance Research Program. Fast Stats: An interactive tool for access to SEER cancer statistics. 2012. Available at: http://seer.cancer.gov/faststats/.
15 International Agency on Research and Cancer. Cervical cancer incidence and mortality worldwide in 2008:GLOBOCAN 2008. Lyon, France. IARC. 2008.
16 College of American Pathologists. Cervical cancer: Cervical Squamous Cell Carcinoma. 2011. Available at: http://www.cap.org/apps/docs/reference/myBiopsy/cervicalsquamous.pdf.
17 Amercian Cancer Society. What are the key statistics about cervical cancer?. 2012. Available at: http://www.cancer.org/Cancer/CervicalCancer/DetailedGuide/cervical-cancer-key-statistics. Accessed on June 26, 2012.
18 Moyer VA. Screening for Cervical Cancer: U.S. Preventive Services Task Force Recommendation Statement. Annals of Internal Medicine. Jun. 19. 2012;156(12):880-891. [pmid: 22711081].
19 Screening for cervical cancer. Obstet Gynecol. Nov. 2012;120(5):1222-1238. [pmid: 23090560].
20 WHO/ICO Information Centre on HPV and Cervical Cancer. Human Papillomavirus and Related Cancers in World. Summary Report 2010. Accessed 11.20.2012. Barcelona, Spain. WHO Press. 2010.
21 Clifford G, Franceschi S, Diaz M, et al. Chapter 3: HPV type-distribution in women with and without cervical neoplastic diseases. Vaccine. Aug. 31. Suppl 3. 2006;24:S3-26-S3/34. [pmid: 16950015].
22 Kahn JA. HPV vaccination for the prevention of cervical intraepithelial neoplasia. N Engl J Med. Jul. 16. 2009;361(3):271-278. [pmid: 19605832].
23 Dunne EF, Unger ER, Sternberg M, et al. Prevalence of HPV Infection Among Females in the United States. JAMA: The Journal of the American Medical Association. Feb. 28. 2007;297(8):813-819.
24 Herfs M, Yamamoto Y, Laury A, et al. A discrete population of squamocolumnar junction cells implicated in the pathogenesis of cervical cancer. Proceedings of the National Academy of Sciences. 2012. Jun. 11.
25 Workowski K, Brennan S. Sexually transmitted diseases treatment guidelines, 2006. 55(RR11). Altanta, GA. Centers for Disease Control and Prevention. 2006.
26 National Institute of Allergy and Infectious Diseases. Human Papillomavirus (HPV) and Genital Warts. 2010. Available at: http://www.niaid.nih.gov/topics/genitalwarts/pages/default.aspx.
27 Hildesheim A, de González AB. Etiology and Prevention of Cervical Adenocarcinomas. Journal of the National Cancer Institute. Mar. 1. 2006;98(5):292-293. [pmid: 16507820].
28 Wright TC, Schiffman M. Adding a Test for Human Papillomavirus DNA to Cervical-Cancer Screening. N Engl J Med. Feb. 6. 2003;348(6):489-490. [pmid: 12571255].
29 American Society for Colposcopy and Cervical Pathology. Diagnosis of HPV-induced disease: cervical intraepithelial neoplasia grades 1,2,3 (CIN1, 2, and 3). 2012. Available at: http://www.asccp.org/practicemanagement/hpv/diagnosisofhpvinduceddisease/tabid/5825/default.aspx.
30 Marion DW. Basow D, editor. Cervical cancer screening tests: Techniques and test characteristics of cervical cytology and human papillomavirus testing. UpToDate. Waltham, MA. 2012.
31 X.Castellsagué SdSTAKSLLBJMMDKIMGOBGAEFSBFXB. HPV and Cervical Cancer in the World. 2007 Report. 2007. Available at: www.who.int/hpvcentre.
32 Stoler MH SM. Interobserver reproducibility of cervical cytologic and histologic interpretations: Realistic estimates from the ascus-lsil triage study. JAMA: The Journal of the American Medical Association. Mar. 21. 2001;285(11):1500-05.
33 Feldman S, Sirovich B, Goodman A. Screening for cervical cancer: rationale and recommendations. 2012. Available at: www.uptodate.com.
34 Naucler P, Ryd W, Törnberg S, et al. Human Papillomavirus and Papanicolaou Tests to Screen for Cervical Cancer. N Engl J Med. Oct. 18. 2007;357(16):1589-1597. [pmid: 17942872].
35 Bulkmans NWJ, Berkhof J, Rozendaal L, et al. Human papillomavirus DNA testing for the detection of cervical intraepithelial neoplasia grade 3 and cancer: 5-year follow-up of a randomised controlled implementation trial. Lancet. 2007;370:1764-1772. [pmid: 17919718].
36 Ronco G, Giorgi-Rossi P, Carozzi F, et al. Efficacy of human papillomavirus testing for the detection of invasive cervical cancers and cervical intraepithelial neoplasia: a randomised controlled trial. The Lancet Oncology. Mar. 2010;11(3):249-257. [pmid: 20089449].
37 Mascarello JT, Brothman AR, Davison K, et al. Proficiency testing for laboratories performing fluorescence in situ hybridization with chromosome-specific DNA probes. Arch Pathol Lab Med. Dec. 2002;126(12):1458-1462. [pmid: 12456204].
38 Allen DG, White DJ, Hutchins AM, et al. Progressive genetic aberrations detected by comparative genomic hybridization in squamous cell cervical cancer. Br J Cancer. Dec. 2000;83(12):1659-1663. [pmid: 11104563].
39 Dellas A, Torhorst J, Gaudenz R, et al. DNA copy number changes in cervical adenocarcinoma1. Clin Cancer Res. Aug. 1. 2003;9(8):2985-2991. [pmid: 12912946].
40 Heselmeyer K, Macville M, Schrock E, et al. Advanced-stage cervical carcinomas are defined by a recurrent pattern of chromosomal aberrations revealing high genetic instability and a consistent gain of chromosome arm 3q. Genes Chromosomes Cancer. Aug. 1997;19(4):233-240. [pmid: 9258658].
41 Hidalgo A, Baudis M, Petersen I, et al. Microarray comparative genomic hybridization detection of chromosomal imbalances in uterine cervix carcinoma. BMC Cancer. 2005;5:77. [pmid: 16004614].
42 Huang KF, Lee WY, Huang SC, et al. Chromosomal gain of 3q and loss of 11q often associated with nodal metastasis in early stage cervical squamous cell carcinoma. J Formos Med Assoc. Nov. 2007;106(11):894-902. [pmid: 18063510].
43 Kirchhoff M, Rose H, Petersen BL, et al. Comparative genomic hybridization reveals non-random chromosomal aberrations in early preinvasive cervical lesions. Cancer Genet Cytogenet. Aug. 2001;129(1):47-51. [pmid: 11520566].
44 Peter M, Stransky N, Couturier J, et al. Frequent genomic structural alterations at HPV insertion sites in cervical carcinoma. J Pathol. Jul. 2010;221(3):320-330. [pmid: 20527025].
45 Rao PH, rias-Pulido H, Lu XY, et al. Chromosomal amplifications, 3q gain and deletions of 2q33-q37 are the frequent genetic changes in cervical carcinoma. BMC Cancer. Feb. 6. 2004;4:5. [pmid: 15018632].
46 Umayahara K, Numa F, Suehiro Y, et al. Comparative genomic hybridization detects genetic alterations during early stages of cervical cancer progression 1. Genes Chromosomes Cancer. Jan. 2002;33(1):98-102. [pmid: 11746992].
47 Wilting SM, Snijders PJ, Meijer GA, et al. Increased gene copy numbers at chromosome 20q are frequent in both squamous cell carcinomas and adenocarcinomas of the cervix 1. J Pathol. Jun. 2006;209(2):220-230. [pmid: 16538612].
48 Yang YC, Shyong WY, Chang MS, et al. Frequent gain of copy number on the long arm of chromosome 3 in human cervical adenocarcinoma1. Cancer Genet Cytogenet. Nov. 2001;131(1):48-53. [pmid: 11734318].
49 Jiang J, Wei LH, Li YL, et al. Detection of TERC amplification in cervical epithelial cells for the diagnosis of high-grade cervical lesions and invasive cancer: a multicenter study in China 1. J Mol Diagn. Nov. 2010;12(6):808-817. [pmid: 20864639].
50 Peter M, Rosty C, Couturier J, et al. MYC activation associated with the integration of HPV DNA at the MYC locus in genital tumors. Oncogene. May. 8. 2006;25(44):5985-5993. [pmid: 16682952].
51 Ferber MJ, Thorland EC, Brink AA, et al. Preferential integration of human papillomavirus type 18 near the c-myc locus in cervical carcinoma. Oncogene. 22:7233-7242. [pmid: 14562053].
52 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. AHRQ. 2011. Available at: http://www.effectivehealthcare.ahrq.gov/ehc/products/60/318/MethodsGuide_Prepublication_Draft_20110824.pdf.
53 Agency for Healthcare Research and Quality. Methods Guide for Medical Test Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2010. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=558&pageaction=displayproduct.
54 Wallace BC, Trikalinos TA, Lau J, et al. Semi-automated screening of biomedical citations for systematic reviews. BMC Bioinformatics. 2010;11:55. [pmid: 20102628].
55 Atkins D, Eccles M, Flottorp S, et al. Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. Dec. 22. 2004;4(1):38. [pmid: 15615589].
56 West S, King V, Carey TS, et al. Systems to rate the strength of scientific evidence. Evid Rep Technol Assess (Summ). Mar. 2002;(47):1-11. [pmid: 11979732].
57 Sun F, Bruening W, Erinoff E, et al. Addressing challenges in genetic test evaluation. Rockville, MD. Agency for Healthcare Research and Quality. 2011. Available at: http://www.effectivehealthcare.ahrq.gov/ehc/products/105/704/Genetic-Test-Evaluation_Final-Report_20110615.pdf. Accessed on November 4, 2011.
58 Whiting PF, Rutjes AWS, Westwood ME, et al. QUADAS-2: A Revised Tool for the Quality Assessment of Diagnostic Accuracy Studies. Annals of Internal Medicine. Oct. 18. 2011;155(8):529-536. [pmid: 22007046].
59 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3:25. [pmid: 14606960].
60 Whiting P, Rutjes AW, Dinnes J, et al. Development and validation of methods for assessing the quality of diagnostic accuracy studies. Health Technol Assess. Jun. 2004;8(25). iii, 1-iii234.
61 Whiting PF, Weswood ME, Rutjes AWS, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. 2006;6:9. [pmid: 16519814].
62 The Cochrane Collaboration. Cochrane Handbook for Systematic Reviews of Interventions, version 5.1.0. 2011. Available at: http://www.cochrane-handbook.org/. Accessed on November 4, 2011.
63 Jennings BA, Mills KI. c-myc locus amplification and the acquisition of trisomy 8 in the evolution of chronic myeloid leukaemia. Leuk Res. 1998;22:899-903. [pmid: 9766750].
64 Rutter CM, Gatsonis CA. A hierarchical regression approach to meta-analysis of diagnostic test accuracy evaluations. Statist Med. 2001;20(19):2865-2884.
65 Reitsma JB, Glas AS, Rutjes AWS, et al. Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. J Clin Epidemiol. 2005;58:982-990. [pmid: 16168343].
66 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-523. [pmid: 19595577].
67 Alameda F, Marinoso ML, Bellosillo B, et al. Detection of HPV by in situ hybridization in thin-layer (ThinPrep) cervicovaginal samples. Tumour Biol. Jun. 2011;32(3):603-609. [pmid: 21302019].
68 Andersson S, Sowjanya P, Wangsa D, et al. Detection of genomic amplification of the human telomerase gene TERC, a potential marker for triage of women with HPV-positive, abnormal Pap smears. Am J Pathol. Nov. 2009;175(5):1831-1847. [pmid: 19880826].
69 Ansari-Lari MA, Staebler A, Zaino RJ, et al. Distinction of endocervical and endometrial adenocarcinomas: immunohistochemical p16 expression correlated with human papillomavirus (HPV) DNA detection. Am J Surg Pathol. Feb. 2004;28(2):160-167. [pmid: 15043304].
70 Bernard C, Mougin C, Bettinger D, et al. Detection of human papillomavirus by in situ polymerase chain reaction in paraffin-embedded cervical biopsies. Mol Cell Probes. Oct. 1994;8(5):337-343. [pmid: 7877628].
71 Bertelsen B, Kalvenes MB, Hartveit F. Human papillomavirus infection in progressive and non-progressive cervical intraepithelial neoplasia. APMIS. Dec. 1996;104(12):900-906. [pmid: 9048869].
72 Birner P, Bachtiary B, Dreier B, et al. Signal-amplified colorimetric in situ hybridization for assessment of human papillomavirus infection in cervical lesions. Mod Pathol. Jul. 2001;14(7):702-709. [pmid: 11455003].
73 Bulten J, Melchers WJ, Kooy-Smits MM, et al. Numerical aberrations of chromosome 1 in cervical intraepithelial neoplasia are strongly associated with infection with high-risk human papillomavirus types. J Pathol. Nov. 2002;198(3):300-309. [pmid: 12375262].
74 Cavalcanti SM, Deus FC, Zardo LG, et al. Human papillomavirus infection and cervical cancer in Brazil: a retrospective study. Mem Inst Oswaldo Cruz. Jul. 1996;91(4):433-440. [pmid: 9070405].
75 Hesselink AT, van den Brule AJ, Brink AA, et al. Comparison of hybrid capture 2 with in situ hybridization for the detection of high-risk human papillomavirus in liquid-based cervical samples. Cancer. Feb. 25. 2004;102(1):11-18. [pmid: 14968413].
76 Kong CS, Balzer BL, Troxell ML, et al. p16INK4A immunohistochemistry is superior to HPV in situ hybridization for the detection of high-risk HPV in atypical squamous metaplasia. Am J Surg Pathol. Jan. 2007;31(1):33-43. [pmid: 17197917].
77 Lie AK, Skjeldestad FE, Hagen B, et al. Comparison of light microscopy, in situ hybridization and polymerase chain reaction for detection of human papillomavirus in histological tissue of cervical intraepithelial neoplasia. APMIS. Feb. 1997;105(2):115-120. [pmid: 9113073].
78 Masumoto N, Fujii T, Ishikawa M, et al. P16 overexpression and human papillomavirus infection in small cell carcinoma of the uterine cervix. Hum Pathol. Aug. 2003;34(8):778-783. [pmid: 14506638].
79 Qureshi MN, Bolick D, Ringer PJ, et al. HPV testing in liquid cytology specimens: comparison of analytic sensitivty and specificity for in situ hybridization and chemiluminescent nucleic acid testing. Acta Cytol. Mar. 2005;49(2):120-126. [pmid: 15839613].
80 Tu Z, Zhang A, Wu R, et al. Genomic amplification of the human telomerase RNA gene for differential diagnosis of cervical disorders. Cancer Genet Cytogenet. May. 2009;191(1):10-16. [pmid: 19389503].
81 Walker F, Bedel C, uge-Geffroy MC, et al. Improved detection of human papillomavirus infection in genital intraepithelial neoplasia in human immunodeficiency virus positive (HIV +) women by polymerase chain reaction-in situ hybridization. Diagn Mol Pathol. Jun. 1996;5(2):136-146. [pmid: 8727101].
82 Jin Y, Li JP, He D, et al. Clinical significance of human telomerase RNA gene (hTERC) amplification in cervical squamous cell lesions detected by fluorescence in situ hybridization. Asian Pac J Cancer Prev. 2011;12(5):1167-1171. [pmid: 21875260].
83 Fujii T, Saito M, Iwata T, et al. Ancillary testing of liquid-based cytology specimens for identification of patients at high risk of cervical cancer. Virchows Arch. Dec. 2008;453(6):545-555. [pmid: 18936966].
84 Huang X, Shi H. Expression of human telomerase gene in cervical cytological specimens. Journal of Dalian Medical University. 2009;31:633-656.
85 Jalali GR, Herzog TJ, Dziura B, et al. Amplification of the chromosome 3q26 region shows high negative predictive value for nonmalignant transformation of LSIL cytologic finding 1. Am J Obstet Gynecol. Jun. 2010;202(6):581-585. [pmid: 20171606].
86 Kokalj-Vokac N, Kodric T, Erjavec-Skerget A, et al. Screening of TERC gene amplification as an additional genetic diagnostic test in detection of cervical preneoplastic lesions. Cancer Genet Cytogenet. Nov. 2009;195(1):19-22. [pmid: 19837263].
87 Li Y, Zeng WJ, Ye F, et al. Application of hTERC in thinprep samples with mild cytologic abnormality and HR-HPV positive. Gynecol Oncol. Jan. 2011;120(1):73-83. [pmid: 21035173].
88 Sokolova I, geciras-Schimnich A, Song M, et al. Chromosomal biomarkers for detection of human papillomavirus associated genomic instability in epithelial cells of cervical cytology specimens. J Mol Diagn. Nov. 2007;9(5):604-611. [pmid: 17975027].
89 Sui W, Ou M, Chen J, et al. Human telomerase RNA gene (TERC) gain and polysomy of chromosome 3 in cervicovaginal liquid-based pap preparations: a fluorescence in situ hybridization study. Eur J Gynaecol Oncol. 2010;31(4):375-379. [pmid: 20882876].
90 Voss JS, Kipp BR, Campion MB, et al. Assessment of fluorescence in situ hybridization and hybrid capture 2 analyses of cervical cytology specimens diagnosed as low grade squamous intraepithelial lesion for the detection of high grade cervical intraepithelial neoplasia. Anal Quant Cytol Histol. Jun. 2010;32(3):121-130. [pmid: 20701064].
91 Ratnam S, Coutlee F, Fontaine D, et al. Aptima HPV E6/E7 mRNA test is as sensitive as Hybrid Capture 2 Assay but more specific at detecting cervical precancer and cancer. J Clin Microbiol. Feb. 2011;49(2):557-564. [pmid: 21147950].