# SUMMARY AND CONCLUSIONS

The electronic literature search for this assessment yielded 1,992 records, of which 1,738 were excluded at initial title and abstract review and 254 were retrieved for full text examination. Forty-one articles describing results of comparative studies were abstracted.

Overall, the frequency of reporting of power calculations and/or the adequacy of sample size in this literature is low. Among on-label studies, 4 of 13 (31%) had some level of reporting of power and/or sample size, while 2 of 28 (7%) off-label studies had some level of reporting of power and/or sample size. This finding is consistent with the generally fair to poor quality of comparative studies that comprise the evidence base for BMP efficacy and safety.

Table 59 Summarizes the conclusions for each Key Question

Key Questions | Conclusion
1. What is the evidence supporting improved outcomes with on-label* use of rhBMP2 (InFUSE®) for fusion of the lumbar-sacral spine? * Spinal fusion procedures in skeletally mature patients with degenerative disc disease (DDD) at 1 level from L2-S1 | The strength of the body of evidence for improved outcomes with on-label use of rhBMP2 (InFUSE®) was graded as moderate. Two RCTs reported radiographic fusion outcomes to be similar to that of autograft bone. No significant adverse events were attributed to rhBMP2 in any study. However, the size and duration of the RCTs are not sufficient to precisely determine the frequency and severity of adverse events. Thus, the evidence gives moderate support to clinical benefit from the use of rhBMP2 as patients can avoid the additional procedure of autograft bone harvest and its associated adverse events.
2. What is the evidence supporting improved outcomes with on-label* use of rhBMP7 (OP-1®) for fusion in the lumbar spine? * Revision posterolateral lumbar spinal fusion | No comparative studies were identified for this Key Question. The strength of evidence is insufficient, thus no conclusions can be reached.
3. What is the evidence supporting improved outcomes with on-label* use of rhBMP7 (OP-1®) in recalcitrant long bone non-unions? * Alternative to autograft in recalcitrant long bone non-unions where use of autograft is unfeasible and alternative treatments have failed | There are two RCTs and one retrospective cohort study. The risk of bias in this evidence is high. In one RCT, the intervention arm was confounded by use of a mix of bone graft extenders, and it was unclear if radiographic outcomes were assessed independently. In the second RCT the BMP arm had higher risk for poor outcomes, and thus the effect of BMP could be underestimated. The third study was nonrandomized and thus had high risk of bias. Device-related harms are inconsistently reported in this literature. The strength of the body of evidence on radiographic fusion, pain, and function outcomes is low.
4. What is the evidence supporting improved outcomes with on-label* use of rhBMP2 (InFUSE®) for the treatment of acute, open shaft tibial fractures? * Acute, open tibial shaft fractures that have been stabilized with IM nail fixation after appropriate wound management. The device must be applied within 14 days after the initial fracture. | The main evidence is in one RCT (n=450) (BESTT) that compared two different doses of rhBMP2 versus standard of care. The RCT is supported by a combined subgroup analysis that pooled data from patients with Gustilo-Anderson type III fractures in BESTT with data from a second smaller unpublished RCT (n=60) with identical design. The strength of the body of evidence on clinical outcomes is moderate for on-label use of rhBMP2 to enhance bony fusion in acute open shaft fractures.
5. What is the level of evidence and summary of evidence for the on-label* use of rhBMP2 (InFUSE) for sinus augmentation? * Sinus augmentations, and for localized alveolar ridge augmentations for defects associated with extraction sockets | Three RCTs were identified in which rhBMP2 was used according to the FDA-approved marketing label in patients undergoing staged bilateral or unilateral maxillary sinus floor augmentation and extraction socket alveolar ridge augmentation procedures. The strength of the body of evidence is moderate that rhBMP2 does not provide an advantage in prosthesis implantation and functional loading compared to autograft plus allograft bone. However, there is also moderate evidence that oral sensory loss associated with autograft bone harvest can be avoided by use of rhBMP2.
6. For which indications are there clinical studies in which BMP is used off-label? In such studies, what is the evidence of the effectiveness of BMP? | The strength of evidence for off-label uses was graded only for settings that had more than one comparative trial involving patients with bony defects sufficiently similar to allow synthesis. Lumbar-Sacral Spine rhBMP2 There are six randomized and five nonrandomized comparative studies of off-label use of rhBMP2 in fusion of the lumbar-sacral spine. The two largest RCTs were rated “fair” and are given greatest weight in this review of evidence. Among all six RCTs, interstudy variables included rhBMP2 dose, surgical approach, carrier matrix formulation, and interbody devices. Despite the use of different surgical approaches and unapproved formulations and instrumentation, the strength of evidence that rhBMP2 improves radiographic fusion success is moderate. No conclusions can be drawn regarding the potential impact of the off-label components on radiographic fusion success. The strength of evidence that rhBMP2 improves other outcomes is low. rhBMP7 The best available evidence for the efficacy of rhBMP7 used off-label for lumbar spinal fusion comes from one randomized trial. There are three additional small, poor quality trials. The evidence is insufficient to draw conclusions on the off-label use of rhBMP7 in fusion of the lumbar-sacral spine. Cervical Spine rhBMP2 The evidence consists of one randomized trial and four nonrandomized comparative studies of off-label use of rhBMP2 for cervical spinal fusion. Two small studies, a randomized trial and a nonrandomized comparative study, reported on radiographic fusion success and changes in mean neck disability scores. The other 3 nonrandomized studies focused mainly on complications. There is moderate evidence that off-label use of rhBMP2 in anterior cervical spinal fusion increases cervical swelling and related complications. There is insufficient evidence to draw conclusions about radiographic fusion success or associated changes in neck disability scores. There are 10 additional off-label uses, each with a single small study, most rated as poor quality. There is insufficient evidence to draw conclusions about any of these off-label uses.
7. What is the evidence of adverse events with (a) on-label use of BMP and (b) off-label use of BMP? And, at what dosage and administration do such adverse events occur? | Overall the evidence on BMP-specific harms is insufficient to draw conclusions in most settings. There is moderate evidence that off-label use of rhBMP2 in anterior cervical spinal fusion increases cervical swelling and related complications. The body of evidence suggests that autograft bone harvest is associated with pain at the harvest site, but it is not possible to systematically assess the frequency, duration, and clinical significance. Overall, autograft harms were inconsistently reported. It is not clear that the absence of reported harms in many studies reflects true absence, or whether the investigators did not seek such data or did not report it.
8. What is the quality of reporting of adverse events in publications? Provide summary to support conclusion. | BMP-specific harms in comparative studies were assessed using a modification of the McHarms survey. The quality of reporting in the 41 comparative studies reviewed in this assessment is variable and inconsistent, in particular with respect to attribution of harms to BMP use and the use of standardized or validated instruments to collect harms. It also is not clear that the absence of reported harms in many studies reflects true absence, or that the investigators did not seek such data or did not report it.
9. What is the incremental cost effectiveness of the use of BMP for spinal fusion and tibial fracture? | The incremental cost-effectiveness ratios (ICERs) for both open tibial fracture and spinal fusion are highly influenced by the assumed added cost of rhBMP2. Open Tibial Fracture Assuming rhBMP-2 to be an added cost of $3,000, the ICER when all other variables were at mean or middle values was $49,204 per quality-adjusted life year (QALY) gained. Excluding the lowest and highest values for one influential variable, ICERs ranged between $24,471 and $64,181 per QALY gained. Assuming the cost of rhBMP2 to be $1,000 yields a mean ICER of $7,960 per QALY gained and a restricted range between $5,201 and $16,771 per QALY gained. When rhBMP2 is assumed to cost $5,000, rhBMP2 becomes much less cost-effective, with a mean ICER of $90,449 per QALY gained and a range of $59,101 to $190,491 per QALY gained. At a cost for rhBMP2 of $8,000, the mean ICER is $152,317 per QALY gained, with a range of $99,525 to $198,677 per QALY gained. As concluded in Key Question 4, of the effects of rhBMP2 in on-label treatment of acute open tibial shaft fracture, evidence is moderate that healing is enhanced and need for secondary intervention is reduced. These outcomes are reflected in QALY differences captured in the Markov model. Spinal Fusion Assuming that rhBMP2 was an added cost of $3,000, the ICER for all other variables at mean or middle value was $121,160 per QALY gained. Excluding the lower and upper values of one influential variable, the restricted range of ICERs was between $56,959 and $162,714 per QALY gained. At a cost of $1,000, the mean ICER is $37,785 per QALY gained and the range is between $17,763 and $50,557. If rhBMP2 is assumed to cost $5,000, the mean ICER is $204,536, and range is from $96,155 to $274,870 per QALY gained. When the cost of rhBMP2 is assumed to be $8,000, the mean ICER is $329,599 per QALY gained and the range is from $154,948 to $443,385 per QALY gained. As concluded in Key Question 1, of the effects of on-label lumbar spinal fusion, evidence is moderate, consistently showing similar and possibly better frequency of fusion and avoidance of bone graft harvest adverse events. The spinal fusion cost-effectiveness analysis relies primarily in the effectiveness component results on the avoidance of bone graft donor site pain.
10. What is the age distribution of study patients compared to the Medicare population (age 65 and older)? What are the considerations in generalizing evidence from trials to the age 65 and older Medicare populations (such as comorbid conditions in the Medicare population and this population’s susceptibility to adverse events). | Among all studies the mean reported age was typically in the mid- to upper-50-years range. A randomized trial performed by Glassman and colleagues is the study identified as most relevant to the age 65 years and older Medicare population. The Glassman study does not specifically relate outcomes to age or comorbidities. The considerations relevant to generalizing from studies in the non-Medicare population include patient age, presence of comorbidities such as osteoporosis or diabetes. However, in generalizing from available studies to the Medicare population, BMP dose and surgical methods should also be considered.