# RESULTS

## Search Results

The electronic literature search yielded 1,992 records, of which 1,738 were excluded at initial title and abstract review and 254 were retrieved for full text examination. Based on the study selection criteria, 140 of 254 retrieved articles were excluded, while 114 met inclusion criteria. Examination of abstracts of non-English language articles revealed no information that could alter the results of the assessment based on English articles, so all were excluded.

Forty-one articles describing results of comparative studies were abstracted, as summarized in Table 2. This technology assessment will focus on the comparative studies, but we also abstracted and compiled data from noncomparative studies in off-label indications to further gather evidence of possible harms associated with clinical use of bone morphogenetic protein (BMP) devices (see Table 3). The key questions addressed in this technology assessment are listed in the Introduction.

## Organization of the Results Chapter

- Assessment of power and sample size in comparative BMP studies
- Synthesis and summary of evidence for each Key Question organized by setting and U.S. Food and Drug Administration (FDA) label status (i.e., indication included as part of the approved label [“on-label”] or not [“off-label”)

Table 2 Distribution of Comparative Studies of rhBMP2 and rhBMP7 According to U.S. Food and Drug Administration (FDA) Label Status

FDA Label Status | rhBMP2 RCT (reference numbers) | rhBMP7 RCT (reference numbers) | rhBMP2 non-RCT (reference numbers) | rhBMP7 non-RCT (reference numbers)
On-label | 6 studies (71, 72, 74, 75, 76, 77) | 2 studies (78, 79) | 2 studies (80, 81) | 2 studies (82, 83)
Off-label | 9 studies (73, 84, 85, 86, 87, 88, 89, 90, 91) | 7 studies (92, 93, 94, 95, 96, 97, 98) | 11 studies (99, 100, 101, 102, 103, 104, 105, 106, 107, 108, 109) | 2 studies (110, 111)

Abbreviations: RCT: randomized, controlled trial

Table 3 Distribution of Off-Label Noncomparative Studies of rhBMP2 and rhBMP7

Surgical Setting | rhBMP2 case series (reference numbers) | rhBMP7 case series (reference numbers) | rhBMP2 case report (reference numbers) | rhBMP7 case report (reference numbers)
Cervical spine | 10 reports (112, 113, 114, 115, 116, 117, 118, 119, 120, 121, 122) | 2 reports (123, 124) | 2 reports (125, 126) | 0
Lumbar spine | 19 reports (116, 118, 120, 127, 128, 129, 130, 131, 132, 133, 134, 135, 136, 137, 138, 139, 140, 141, 142) | 5 reports (123, 124, 136 143, 144,) | 5 reports (145, 146, 147, 148, 149, 150) | 1 report (151)
Arm | 0 | 2 reports (152, 153) | 1 report (154) | 1 report (155)
Wrist (2 case reports; rhBMP type not reported)
Femur | 1 report (156) | 1 report (156) | 1 report (157) | 1 report (158)
Tibia | 0 | 1 report (159) | 0 | 2 reports (160, 161)
Foot and ankle | 2 reports (162, 163) | 0 | 1 report (164) | 1 report (165)
Oral-facial cleft | 4 reports (166, 167, 168, 169) | 0 | 1 report (167) | 0
Mandibular defects | 3 reports (170, 171, 172) | 1 report (170) | 2 (173, 174) | 0
Other | 3 reports (175, 176, 177) | 2 reports (178, 179) | 2 reports (180, 181) | 0

## Assessment of Power and Sample Size

Detailed results from this evaluation are presented in Appendix 3, Table A (on-label comparative studies) and Appendix 3, Table B (off-label comparative studies).

Among on-label studies, 4 of 13 (31 percent) had some level of reporting of power and/or sample size. Two trials appear to report these numbers retrospectively.76,78 Two performed the calculations prior to participant enrollment.74,77 Of those, only one enrolled enough participants and followed a sufficient number to assess their primary outcome at the prespecified level.74

Among off-label studies 2 of 28 (7 percent) had some level of reporting of power and/or sample size. These numbers were calculated retrospectively in one trial.90 In the other trial, power calculations were performed prior to participant enrollment; however the investigators did not recruit or follow a sufficient number of participants to assess their primary outcome measures.94

Overall, the frequency of reporting of power calculations and/or the adequacy of sample size in this literature is low. This finding is consistent with the generally poor to fair quality of individual comparative studies that comprise the evidence base for BMP efficacy and safety.

## Synthesis of Evidence According to Key Questions

We have synthesized the body of evidence available for on- and off-label use of rhBMP2 and rhBMP7 for Key Questions 1–6 using the modified AHRQ/GRADE framework.69 This analysis was applied only if at least two studies were available involving a single rhBMP device and patients with similar bone defects.

### Key Question 1 What is the evidence supporting improved outcomes with on-label use of rhBMP2 (InFUSE®) for fusion of the lumbar-sacral spine?

As shown in Table 4, the strength of the body of evidence for improved outcomes with on-label use of rhBMP2 (InFUSE®) was graded as moderate. Two RCTs reported fusion outcomes to be similar to that of autograft bone.71, 72 No significant adverse events were attributed to rhBMP2 in any study. However, the size and duration of the RCTs are not sufficient to precisely determine the frequency and severity of adverse events. Thus, the evidence gives moderate support to clinical benefit from the use of rhBMP2 as patients can avoid the additional procedure of autograft bone harvest and its associated adverse events.

Table 4 Overall Grade of Strength of Comparative Study Evidence for On-Label Use of rhBMP2 for Fusion of the Lumbar-Sacral Spine

Key Question | Study Design | Risk of bias | Consistency | Directness | Precision | Overall Grade/Conclusion
What evidence of improved outcomes is associated with the on-label use of InFUSE for fusion of the lumbar-sacral spine? Outcomes of interest include radiographic fusion, pain, function, satisfaction measures, and adverse events. | There are two RCTs. The largest included 279 patients, the other included 14 patients. Both used independent assessment of radiographic outcomes. Neither reported statistically significant results or power and sample size calculations. | Risk of bias is medium in these studies. Both were RCTs, but all did not clearly report randomization methods. Intent-to-treat analysis was not consistently reported but loss to follow-up was relatively low. Standardized clinical outcomes measures were used. Only radiological fusion was independently assessed. Device-related harms are inconsistently reported in this literature. Therefore there is a high risk of bias with respect to adverse events. | Consistent results were seen in the sense that no study or scale within a study reported numerically worse results for rhBMP2 versus iliac crest bone graft (ICBG). No quantitation of effect size is possible because no statistical significance was reported. Radiographic fusion outcomes were qualitatively similar with rhBMP2 and ICBG. The most numerically favorable results were reported in the smaller RCT. The frequency of adverse events associated with autograft bone harvest varied in these reports. | Direct evidence was available for all outcomes considered under this Key Question. | The body of evidence is imprecise. | The strength of the body of evidence for this indication is moderate. The results are consistent in that frequency of fusion was similar, and may possibly be better, for rhBMP2 compared to autograft bone. Among the two RCTs, no device-related adverse events were reported. However, the size and duration of RCTs are not sufficient to precisely determine the frequency and severity of adverse events. Thus, the evidence gives moderate support to clinical benefit from the use of rhBMP2 as patients can avoid the additional procedure of autograft bone harvest and its associated adverse events.

#### Key Question 1 Evidence Summary

Table 5 summarizes two RCTs that compared rhBMP2 (total N=154) and autograft bone (AGB) (total n=139) for fusion within the lumbar spine.71, 72 Both studies were rated as “fair” according to the USPSTF study quality evaluation system (see Appendixes 1 and 2 for full details on study characteristics and USPSTF quality ratings). These trials reflect on-label use according to the PMA for InFUSE®. The literature search did not identify any trials deemed on-label for the product initially approved via the HDE process (InFUSE®/Mastergraft).

Table 5 On-Label Randomized Trials of rhBMP2 for Lumbar-Sacral Spinal Fusion

Indication (ref no.) | No. of studies | Group | Total no. pts | Follow-up (mos.) | BMP dose range (mg/pt) | USPSTF study quality
Degenerative disc disease of the lumbar spine (71, 72) | 2 | rhBMP2 | 154 | 24 | 4.2–8.4 | 2 FAIR
Degenerative disc disease of the lumbar spine (71, 72) | 2 | AGB | 139 | 24 | 0 | 2 FAIR

Abbreviations: AGB: autograft bone; mos.: months; no.: number; pts: patients; ref: reference; USPSTF: U.S. Preventive Services Task Force

All patients had symptomatic (low back pain, leg pain, functional impairment) single-level DDD that had not responded to noninvasive therapies for a minimum of 6 months.

Spinal fusion was performed using an anterior approach in both studies71,72 with follow-up of 24 months. Autograft bone was harvested from the iliac crest in all cases that received this treatment.

In both studies,71,72 rhBMP was used at a dose of 4.2–8.4 mg per patient; The BMP product was administered via absorbable collagen sponge (ACS), inside interbody fusion cages according to the approved marketing label (InFUSE®). 71,72 Patient demographics were similar in each study, with no statistically significant intergroup differences (see Appendix 1 Table C for detailed patient characteristics). Tobacco use was reported in about 33 percent72 of all patients in one study, but was uneven in the third71 (0 percent in the BMP group versus 33 percent in the control group), although this difference was not statistically significant and likely due to a very small number of cases (n=3) in the control group

Table 6 shows key results from the two RCTs of the use of rhBMP2 in lumbar spinal fusion.71, 72

Table 6 Clinical Outcomes in On-Label Randomized Trials of rhBMP2 for Lumbar-Sacral Spinal Fusion

Study (ref no.) | Group | No. of Pts. | BMP dose range (mg/pt) | Radiographic fusion success, 24 mos., % | ODI success, 24 mos., % | Leg pain mn point score ↑ 24 mos. | Work status 24 mos. , % | Patient satisfaction 24 mos., % | USPSTF study quality
Burkus et al., 2002 (72) | BMP2 | 143 | 4.2–8.4 (InFUSE®) | 94 | 84 | 6.2 | 66 | 81 | FAIR
Burkus et al., 2002 (72) | ICBG | 136 | 0 | 89 | 82 | 6.2 | 56 | 80 | FAIR
Boden et al., 2000 (71) | BMP2 | 11 | 4.2–8.4 (InFUSE®) | 100 | 91 | NR | 91 | 100 | FAIR
Boden et al., 2000 (71) | ICBG | 3 | 0 | 67 | 67 | NR | 67 | 100 | FAIR

Abbreviations: ICBG: iliac crest bone graft; mn: mean; mos.: months; no.: number; ODI: Oswestry Disability Index; pt(s): patient(s); USPSTF: U.S. Preventive Services Task Force

In both studies,71, 72 radiographic fusion success reflected the presence of continuous trabecular bone growing through both interbody fusion cages. ODI success was defined explicitly as a 15 percent or greater improvement over the preoperative score in one study.71 The second study72 alluded to a 15% improvement as important, but did not specify it as significant. Leg pain visual analog scores (VAS) improved significantly from baseline in both groups, but no significant intergroup differences were reported.71, 72 Work status reflected the proportion of patients who were working prior to surgery and resumed work postsurgery. 71,72

In one study,71 the mean operating room time was significantly longer in the iliac crest bone graft (ICBG) group than in the BMP2 group (3.3 vs. 1.9 hours, respectively, p=0.006). Mean operating room time was 1.6 and 2.0 hours, respectively, in the second trial,72 which were not statistically significant differences. No other significant intergroup differences in perioperative outcomes were reported in any of the trials, including the need for second procedures, blood loss, or procedural complications (see Appendix 1 for details).

Iliac crest harvest site pain was reported in 100% of patients in one study,72 with a mean VAS of 12.7 (of a 20-point scale) immediately following surgery; 32 percent of patients still experienced pain at 24 months’ follow-up, with an average score of 1.8. In that study, seven adverse events related to bone graft harvest (three injuries to the lateral femoral cutaneous nerve, two avulsion fractures of the anterior superior iliac crest, one infection, one hematoma) were identified in eight (5.9 percent) patients. No adverse events related to graft harvest were reported in the other trial.71

Evidence is available from two randomized trials of rhBMP2 to enhance fusion in the lumbar spine.71, 72 Both studies used InFUSE® at a dose of 4.2–8.4 mg per patient. 71,72 Both report results numerically favoring or identical to rhBMP2, but results are not statistically significant. No device-related complications (biological or mechanical) were reported in these studies. Pain and complications were reported secondary to autograft bone harvest in 1 study.72

Table 7 notes a pooled analysis that has been widely cited in the review literature of BMP for lumbar-sacral spinal fusion.182 The authors state this report includes data from four prospective multicenter clinical trials. These include the largest of the RCTs reviewed above72 (n=279), a partial dataset (n=22) published from a prospective RCT,183 and the balance (n=378) from unpublished sources. The literature search identified no on-label studies that used InFUSE®/Mastergraft approved under the HDE.

Table 7 Pooled Comparative Analysis of On-Label Use of rhBMP2 for Lumbar-Sacral Spinal Fusion

Indication (ref no.) | No. of studies | Group | Total no. pts | Follow- up (mos.) | BMP dose range (mg/pt) | USPSTF study quality
DDD of the lumbar spine (182) | 1 | rhBMP2 | 277 | 24 | 4.2–8.4 | POOR
DDD of the lumbar spine (182) | 1 | ICBG | 402 | 24 | 0 | POOR

Abbreviations: AGB: autograft bone; mos.: months; no.: number; pts: patients; ref: reference; USPSTF: U.S. Preventive Services Task Force

This pooled analysis does not add substantively to the evidence reviewed above. Concerns include inability to access more than half the primary data, which precludes appraisal of its quality, methods, population, and outcomes. Nor does the report clearly outline statistical methods used to combine data from these disparate sources.

### Key Question 2 What is the evidence supporting improved outcomes with on-label use of rhBMP7 (OP-1®) for fusion in the lumbar spine?

As shown in Table 8, no comparative studies were identified for this Key Question.

Table 8 Overall Grade of Strength of Comparative Study Evidence for On-Label Use of rhBMP7 for Fusion of the Lumbar-Sacral Spine

Key Question | Study Design | Risk of bias | Consistency | Directness | Precision | Overall Grade/Conclusion
What evidence of improved outcomes is associated with the on-label use of OP-1 for fusion of the lumbar-sacral spine? | No comparative studies addressed this Key Question | Not applicable (NA) | NA | NA | NA | The strength of evidence is insufficient, thus no conclusions can be reached.

#### Key Question 2 Evidence Summary

OP-1® Putty received FDA Humanitarian Device Exemption (HDE) approval for use in revision posterolateral lumbar spinal fusion based on several lines of data. A primary source of data was the results of a pilot study conducted in 36 patients (n=24 OP-1, n=12 ICBG) undergoing primary fusion to treat symptomatic single-level degenerative lumbar spondylolisthesis and spinal stenosis.184 Patients included those for whom autograft bone harvest was not feasible or not expected to promote fusion because of tobacco use, osteoporosis, or diabetes. Clinical success reflected improvement in pain and function as assessed by at least 20 percent improvement over the baseline ODI score. Radiographic success was defined as lack of motion of flexion/extension radiographs manifested as not more than 5 degrees angulation or 2 mm translation and evidence of bridging trabecular bone. Outcomes at 12 months of follow-up are summarized in Table 9.

Table 9 Pilot Study Outcomes for OP-1 Putty in Lumbar Spinal Fusion

Outcome^*^ | OP-1 Putty (%) (n=24) | ICBG (%) (n=12)
Clinical Success | 83 | 67
Radiographic Success | 62 | 50
Overall Success | 50 | 33

* no significant differences reported in any outcome

Abbreviations: ICBG: iliac crest bone graft

Subsequent publications reported follow-up data at two185 and four years.95 Data from the four-year follow-up study are contained in Appendix 1 Table B and in Table 28 (Key Question 6), with results consistent with the pilot study.

This study evaluated the use of OP-1® Putty in primary posterolateral spinal fusions. However, the basis for using these data to support the probable benefit of using OP-1® Putty for revision posterolateral spinal fusion surgery was based on a risk/benefit judgment, adopted as follows from the FDA summary (http://www.accessdata.fda.gov/cdrh_docs/pdf2/H020008b.pdf):

Preclinical studies in animals demonstrate that OP-1 Putty is osteoinductive and:

- is capable of inducing solid fusion in the posterolateral spine following primary treatment or revision of nicotine induced pseudarthrosis
- induces bone formation in a variety of animal species and
- generates bone that is mechanically and histologically normal.

The FDA noted that results from the pilot clinical study suggested probable benefit as an alternative to autograft in patients who require primary uninstrumented fusion for the treatment of degenerative spondylolisthesis. These data cannot be directly extrapolated to the expected performance of OP-1® Putty in revision posterolateral spinal fusions in the compromised population, but there is reason to believe that OP-1 Putty could have a probable benefit in this population, as follows.

The FDA emphasized that when revision of a failed fusion is required, most patients are limited to either living with pain and altered function or repeating the original procedure with additional autologous bone, which may result in depletion of the bone stock and further risk to the patient. Allograft bone and bone graft substitutes are not considered feasible alternatives to autograft in revision surgery due to their lack of osteogenic potential. For certain patients, for example those with implanted leads, bone growth stimulators would not be considered as feasible options. OP-1® Putty has the potential to eliminate the risks and complications associated with these treatment alternatives while providing a feasible and beneficial alternative treatment.

The FDA concluded that the body of preclinical and clinical evidence available at the time was reasonably sufficient to conclude that the probable benefit to health from using the device for the target population outweighs the risk of illness or injury, taking into account the probable risks and benefits or currently available alternative treatments. Accordingly, the FDA's Center for Devices and Radiological Health (CDRH) determined that, based on the data submitted in the HDE application, the use of OP-1® Putty will not expose patients to an unreasonable or significant risk of illness or injury and the probable benefit to health from using the device outweighs the risk of illness or injury, and issued an HDE approval order on April 7, 2004.

### Key Question 3 What is the evidence supporting improved outcomes with on-label use of rhBMP7 (OP-1®) in recalcitrant long bone non-unions?

The evidence for this indication consists of two RCTs, one of fair quality79 and one of poor quality,78 as well as a poor quality nonrandomized cohort study.83 Appraisal and synthesis of the randomized trial evidence is complicated by the choice of different comparators, platelet-rich plasma (PRP) in one78 and autograft bone in the other.79 Radiographic fusion rates with rhBMP7 in both studies were similar to the comparator rates, with a statistically significant (p=0.016) advantage for rhBMP7 in one trial.78 However, in the other trial, the relative efficacy of rhBMP7, in fact, may have been underestimated because statistical adjustments were not made to account for group demographic differences predisposing to a poor fusion outcome.79

Other outcomes reported with rhBMP7 were not consistently reported and thus could not be appraised. A high risk of bias in the cohort study, due to its design and small sample size, precludes conclusions about clinical outcomes associated with rhBMP7. The overall strength of this body of evidence is low to support improved outcomes with on-label use of rhBMP7 (OP-1) for long bone non-unions (Table 10).

#### Key Question 3 Evidence Summary

Table 11 shows two RCTs of labeled use of rhBMP7 to treat recalcitrant long bone non-unions (see Appendixes 1 and 2 for details on study characteristics and USPSTF quality ratings). One study78 was rated as “poor” according to the USPSTF study quality evaluation system, the other was graded as “fair.”79

In the RCTs, patients with long bone non-unions were randomly assigned to undergo surgical fixation of the fracture site, and receive adjuvant rhBMP7, which was compared to autograft bone79 or PRP.78 A statistically higher prevalence of atrophic non-unions (41 percent compared with 25 percent, p=0.048) and a strong trend toward more smokers (74 percent compared with 57 percent, p=0.057) in the rhBMP7 group was reported in one RCT;79 however, the report does not indicate whether the investigators attempted to statistically adjust for differences in study group characteristics.

Table 12 shows radiographic fusion success at 9 months’ follow-up was achieved at a statistically significantly higher rate (87 percent vs. 68 percent, p=0.016) among rhBMP7 recipients than those treated with PRP and adjuvant bone graft extenders.78 However, no significant differences were reported in the average time needed to achieve radiological (8 vs. 9 months) or clinical union (3.5 vs. 4.0 months). No adverse events related to rhBMP7 were reported.

Table 10 Overall Grade of Strength of Comparative Study Evidence for On-Label Use of rhBMP7 in Recalcitrant Long Bone Non-Unions

Key Question | Study Design | Risk of bias | Consistency | Directness | Precision | Overall Grade/Conclusion
What evidence of improved outcomes is associated with the on-label use of OP-1 in recalcitrant long bone non-unions? Outcomes of interest include radiographic fusion, pain, function, satisfaction measures, and adverse events. | There are two RCTs and one retrospective cohort study. These involve different comparators, autograft bone in 2 reports, platelet-rich plasma in the third. None reported power or sample size calculations. | The risk of bias in this evidence is high. In one RCT, the intervention arm was confounded by use of a mix of bone graft extenders and it was unclear if radiographic outcomes were assessed independently. In the second RCT the BMP arm had higher risk for poor outcomes, and thus the effect of BMP could be underestimated. The third study was nonrandomized and thus had high risk of bias. Device-related harms are inconsistently reported in this literature. | Results for radiographic fusion appear consistent for rhBMP7 in that they are similar and not worse. Clinical outcomes were not completely reported in both RCTs so consistency cannot be determined. | Where outcomes were reported, the evidence is direct. | The evidence is imprecise, effects cannot be quantified. | The strength of the body of evidence on radiographic fusion, pain, and function outcomes is low. But, of note, one RCT reports similar outcomes with autografting and rhBMP7 although the BMP group is at higher risk of poor outcomes.

Table 11 On-Label Randomized Trials of rhBMP7 for Recalcitrant Long Bone Non-Unions

Indication (ref no.) | No. of studies | Group | Total no. pts | Follow-up (mos.) | BMP dose range (mg/pt) | USPSTF study quality
Long bone non-union (78, 79) | 2 | rhBMP7 | 121 | 9–43 | 3.5–7.0 | 1 FAIR, 1 POOR
Long bone non-union (78, 79) | 2 | AGB | 61 | 9–43 | 3.5–7.0 | 1 FAIR, 1 POOR
Long bone non-union (78, 79) | 2 | PRP | 60 | 9–43 | 3.5–7.0 | 1 FAIR, 1 POOR

Abbreviations: AGB: autograft bone; mos.: months; no.: number; PRP: platelet-rich plasma; pt(s): patient(s); USPSTF: U.S. Preventive Services Task Force

Table 12 Clinical Outcomes in On-Label Randomized Trials of rhBMP7 for Recalcitrant Long Bone Non-Unions

Study (ref no.) | Group | No. Pts | BMP dose range (mg/pt) | Fusion or clinical success 9 mos. % | Time to radiologic union (md ± SD, mos.) | Time to clinical union (md ± SD, mos.) | Pain-free weight bearing 9 mos. % | USPSTF study quality
Calori et al., 2008 (78) | rhBMP7/ACS | 60 | 3.5–7.0 (Osigraft) | 87 | 8±0.5 | 3.5±0.5 | NR | POOR
Calori et al., 2008 (78) | PRP | 60 | 0 | 68 (p=0.016) | 9±0.5 | 4.0±0.6 | NR | POOR
Friedlander et al., 2001 (79) | rhBMP7/ACS | 61 | 3.5–7.0 (OP-1 Implant) | 81 | NR | NR | 89 | FAIR
Friedlander et al., 2001 (79) | AGB | 61 | 0 | 85 | NR | NR | 90 | FAIR

Abbreviations: ACS: absorbable collagen sponge; AGB; autograft bone; md: median; mos.: months; no.: number; PRP: platelet-rich plasma; pt(s): patient(s); SD: standard deviation; USPSTF: U.S. Preventive Services Task Force

In the other RCT,79 there was no difference in the combined clinical success rate at 9 months (81 percent rhBMP7 vs. 85 percent AGB) which was defined as full weight-bearing with less than severe pain at the fracture site and no further intervention to enhance repair. About 90 percent of patients in both groups reached a state of pain-free weight-bearing at 9 months. Moderate-to-severe pain was reported at the autograft harvest site by 80 percent of patients in the immediate postoperative period; 13% reported mild to moderate pain at the harvest site at 12 months’ follow-up. No other harvest site adverse events were reported.

Table 13 summarizes characteristics of a nonrandomized retrospective cohort study in which rhBMP7 (Osigraft [available in Europe], 3.5 mg per patient, n=15) applied via a absorbable collagen sponge was compared to ICBG (n=12) as part of surgical treatment of recalcitrant tibial fracture non-union.83 This small, nonrandomized, poor quality study has a high risk of bias, which precludes conclusions based on its outcomes.

Table 13 On-Label Nonrandomized Comparative Study of rhBMP7 for Recalcitrant Long Bone Non-Unions

Indication (ref no.) | No. of studies | Group | Total no. pts | Follow-up (mos.) | BMP dose range (mg/pt) | USPSTF study quality
Long bone non-union (83) | 1 | rhBMP7 | 15 | 29–34 | 3.5 | POOR
Long bone non-union (83) | 1 | iliac crest bone graft | 12 | 29–34 | 0 | POOR

### Key Question 4 What is the evidence supporting improved outcomes with on-label use of rhBMP2 (InFUSE®) for the treatment of acute, open shaft tibial fractures?

As shown in Table 14, the main evidence is one RCT (“BMP2 Evaluation in Surgery for Tibial Trauma,” or BESTT74) that compared two different doses of rhBMP2 versus standard of care. BESTT was a large (n=450) fair quality, prospective randomized clinical trial that showed a statistically significant relative advantage for adjuvant rhBMP2 at a dose of 12 mg per patient in the need for invasive second surgeries with autograft bone (18 percent versus 43 percent, p=0.0264), clinical success rate (65 percent versus 47 percent, p=0.0028), infections (24 percent versus 44 percent, p=0.047), and median healing rate (145 versus 184 days, p=0.0022). Other evidence consists of a fair quality subgroup analysis of data on Gustilo-Anderson type-III fractures (n=244) combined from BESTT74 and an unpublished RCT (n=60) known as the “U.S. study.”81 Adjuvant rhBMP2 (12 mg per patient) was associated with a statistically significant reduction in wound infection rates (21 percent vs. 40 percent, p=0.02), and secondary autologous bone-grafting interventions (2 percent versus 20 percent, p=0.0022) for delayed union or non-union.

The strength of the body of evidence on clinical outcomes is moderate for on-label use of rhBMP2 to enhance bony fusion in acute open shaft fractures, reduce wound infections, and reduce the need for a second procedure involving autograft bone. Significant device-related adverse events were not reported.

#### Key Question 4 Evidence Summary

Table 15 shows two reports of rhBMP2 in acute open shaft tibial fractures. The BMP-2 Evaluation in Surgery for Tibial Trauma (BESTT) trial74 randomized patients with open fractures of the tibial shaft according to wound severity to receive the standard of care (intramedullary [IM] nail fixation and routine soft tissue management) with rhBMP2 (InFUSE®) applied via collagen sponge at 6 mg per patient (n=151) and 12 mg per patient (n=149) or to the standard care alone without use of an autograft (n=150). The primary outcome measure was the proportion of patients that required a secondary intervention because of delayed union or non-union within 12 months after surgery. There were two significant intergroup differences in patient demographics. One was an overall difference in age (by ANOVA, otherwise not specified). The second significant intergroup difference was in the proportion of patients who underwent reamed intramedullary nailing among the treatment groups (p=0.0371). However, multiple regression analysis of potential interaction between rhBMP2 and fixation method revealed these variables independently affected the primary outcome. Recent tobacco use was noted in 45–52% of patients. This study was rated as “fair” according to the USPSTF study quality evaluation system.

A second concurrent study (unpublished) conducted in ten level-I trauma centers in the U.S. included a total of 60 patients, using design and patient selection criteria identical to BESTT. Raw patient data from this study and BESTT were combined in a subgroup analysis of clinical outcomes for patients with Gustilo-Anderson type-III open fractures (n=131, 65 controls, 66 rhBMP2 group) and those who underwent reamed IM nailing without use of autograft bone (n=113; 48 controls, 65 rhBMP2 group) type-III from that trial.81 It presented separate results of the control treatment and the FDA-approved concentration of rhBMP2 at 12 mg per patient. The comparison group of interest was the Gustilo-Anderson type III subgroup with rhBMP2 and without.

Table 14 Overall Grade of Strength of Comparative Study Evidence for On-Label Use of rhBMP2 for Treatment of Acute Open Shaft Fractures

Key Question | Study Design | Risk of bias | Consistency | Directness | Precision | Overall Grade/Conclusion
What evidence of improved outcomes is associated with the on-label use of InFUSE for the treatment of acute, open shaft fractures? Outcomes of interest include radiographic fusion, pain, function, satisfaction measures, and adverse events. | The main evidence is in one RCT (BESTT) that compared two different doses of rhBMP2 versus standard of care. The RCT is supported by a combined subgroup analysis that pooled data from patients with Gustilo-Anderson type III fractures in BESTT with data from a second smaller unpublished RCT (n=60) with identical design. | The risk of bias is medium. The BESTT RCT had fusion outcomes independently assessed by a radiology panel. It did not specify whether the panel assessment was undertaken prospectively or retrospectively. It is not possible to assess risk of bias in the smaller RCT incorporated in the subgroup analysis because it is unpublished and unavailable to review methods. Device-related harms are inconsistently reported in this literature. Therefore there is a high risk of bias with respect to adverse events. | The evidence is consistent. The BESTT and combined subgroup analysis report statistically significant improvement in invasive secondary interventions and infection rate in Gustilo-Anderson type III fractures when rhBMP2 is used as an adjunct to standard of care. Clinical success rate was improved in the BESTT but not reported in the subgroup analysis. Median time to healing was improved in the BESTT but was not significant in the combined subgroup analysis. | Direct evidence was reported for the outcomes of interest. | The evidence is precise. The only confidence interval reported was in the BESTT for secondary invasive interventions (RR= 0.56, 95% CI=0.40–0.78). | The strength of the body of evidence on clinical outcomes is moderate for on-label use of rhBMP2 to enhance bony fusion in acute open shaft fractures. One randomized and one retrospective subgroup analysis of data from 2 RCTs consistently show that rhBMP2 enhances healing and reduces the need for invasive second procedures.

Table 15 On-Label use of rhBMP2 for Acute Open Tibial Fractures

Indication (ref no.) | No. of studies | Group | Total no. pts | Follow-up (mos.) | BMP dose range (mg/pt) | USPSTF study quality
Open tibial fractures (74) | 1 (BESTT) | rhBMP2 | 151 | 12 | 6 | FAIR
Open tibial fractures (74) | 1 (BESTT) | rhBMP2 | 149 | 12 | 12 | FAIR
Open tibial fractures (74) | 1 (BESTT) | Standard care | 150 | 12 | 0 | FAIR
Open tibial fractures (81) | 1 (subgroup analysis) | Gustilo-Anderson III rhBMP2 | 66 | 12 | 12 | FAIR
Open tibial fractures (81) | 1 (subgroup analysis) | Gustilo-Anderson III Standard care | 65 | 12 | 0 | FAIR
Open tibial fractures (81) | 1 (subgroup analysis) | Gustilo-Anderson I–III rhBMP2 | 65 | 12 | 12
Open tibial fractures (81) | 1 (subgroup analysis) | Gustilo-Anderson I–III Reamed IM nailing | 48 | 12 | 0

Abbreviations: IM: intramedullary nail; mos.: months; no.: number; pt(s): patient(s); USPSTF: U.S. Preventive Services Task Force

Clinical outcomes are summarized in Table 16.

Table 16 Clinical Outcomes of On-Label use of rhBMP2 for Acute Open Tibial Fractures

Study (ref no.) | Group | Invasive secondary intervention rate (%) | Clinical success rate (%) | Median time to fracture healing (days) | Infection rate in Gustilo-Anderson type III fractures (%)
BESTT (74) | rhBMP2 | 18 | 65 | 145 | 24
BESTT (74) | Standard care | 43 (p=0.0264) (RR=0.56, 95% CI=0.40. 0.78) | 47 (p=0.0028) | 184 (p=0.0022) | 44 (p=0.047)
Combined Data Subgroup Analysis (81) | rhBMP2 | 2 | NR | 271 | 21
Combined Data Subgroup Analysis (81) | Standard care | 20 (p=0.0065) | NR | 277 (NS) | 40 (p=0.02)
Combined Data Subgroup Analysis (81) | rhBMP2 | 2 | NR | 234 | 18
Combined Data Subgroup Analysis (81) | Reamed IM nailing | 6 | NR | 251 (NS) | 27 (NS)

Abbreviations: IM: intramedullary nail; mos.: months; no.: number; NR: not reported; NS: not significant;

The BESTT results74 in patients with Gustilo-Anderson type I-III fractures suggest that rhBMP2 hastens fracture healing (defined as the presence of cortical bridging and/or disappearance of the fracture lines on at least three of four cortices on the anteroposterior and lateral radiographs), increases the proportion of patients who achieve a successful clinical outcome, and reduces the number of invasive secondary intervention with autologous bone grafting when compared to standard surgical and soft tissue management (standard of care). Among smokers, patients who received rhBMP2 had a significantly lower rate of secondary intervention than did the standard of care patients (30 percent compared with 52 percent, p=0.0138). No significant adverse effects related to rhBMP2 were reported. The 12 mg per patient rhBMP2 group had significantly fewer (p=0.047) infections in association with Gustilo-Anderson type III fractures than the standard of care group (24 percent compared with 44 percent).

Results from the combined data subgroup analysis in Gustilo-Anderson type III fractures show a significant reduction in the rate of invasive secondary interventions among rhBMP2 recipients with minimal reduction in the median time to fracture healing. The time to achieve full weight-bearing capacity in Gustilo-Anderson type III patients in the subgroup analysis was 95 +/− 38 days in the rhBMP2 group and 126 +/− 61 days in the standard of care group (p=NR). The infection rate was significantly lower in rhBMP2 recipients than standard of care patients (p=0.02). The secondary comparison between rhBMP2 and reamed IM nailing showed no significant differences.

### Key Question 5 What is the level of evidence and summary of evidence for the on-label use of rhBMP2 (InFUSE) for sinus augmentation?

As shown in Table 17, three RCTs were identified in which rhBMP2 was used according to the FDA-approved marketing label in patients undergoing staged bilateral or unilateral maxillary sinus floor augmentation75,77 and extraction socket alveolar ridge augmentation procedures.76 The strength of the body of evidence is moderate that rhBMP2 does not provide an advantage in prosthesis implantation and functional loading compared to autograft plus allograft bone. However, there is also moderate evidence that oral sensory loss associated with autograft bone harvest can be avoided by use of rhBMP2.

#### Key Question 5 Evidence Summary

Three RCTs (Table 18) were identified in which rhBMP2 was used according to the FDA-approved marketing label in patients undergoing staged bilateral or unilateral maxillary sinus floor augmentation75,77 or extraction socket alveolar ridge augmentation procedures.76 Patients in those studies received rhBMP2 applied via absorbable collagen sponge in dose range of 6 to 48 mg per patient (total n=158), autograft bone (total n=93), or placebo (n=37). The mean rhBMP2 dose was reported in one study,76 rather than total dose. AGB harvested from the iliac crest, tibia, or the oral cavity was used alone or mixed with allograft bone (ALG) in two studies.75,77

Clinical outcomes included new bone formation sufficient for endosseous dental implant placement, dental implant success rate following functional loading, patient success, perioperative complications, and device-related adverse events at 4–36 months’ follow-up.

Two RCTs75,77 (Table 19) were rated as “good” (75, 77) and one “fair,”76 according to the USPSTF study quality evaluation system.

rhBMP2 does not appear to provide an advantage compared to AGB/ALG. Although statistical significance is not reported, prosthesis implantation was numerically less frequent with rhBMP2 compared to AGB/ALG. In the pivotal trial by Triplett et al.,77 successful prosthetic functional loading occurred statistically significantly less frequently in the rhBMP2 than the comparator group. Fiorellini et al.76 reported significantly more frequent prosthesis implantation with the higher dose rhBMP2 arm than the lower dose.

Table 17 Overall Grade of Strength of Comparative Study Evidence for On-Label Use of rhBMP2 for Sinus Augmentation

Key Question | Study Design | Risk of bias | Consistency | Directness | Precision | Overall Grade/Conclusion
What is the level of evidence and summary of evidence for the on-label use of InFUSE for sinus augmentation? Clinical outcomes included radiographic evidence of new bone formation sufficient to allow prosthetic implantation and functional loading, and adverse events associated with the rhBMP device and with autograft harvest. | The evidence comprises three RCTs. A pilot study which compared rhBMP2 versus autograft/allograft bone, and a larger follow-up trial that compared rhBMP2 versus autograft/allograft bone. The third trial compared four arms, two different doses of rhBMP2, placebo, and no treatment. | Risk of bias in the body of clinical evidence is low in all of the studies. All were rated as good quality with independent assessment of radiographic outcomes, intent-to-treat analysis, and reported randomization methods. Device-related harms are inconsistently reported in this literature. Therefore there is a high risk of bias with respect to adverse events. | The body of evidence is consistent showing that rhBMP2 does not provide an advantage in prosthesis implantation and functional loading compared to AGB/ALG. No statement on consistency of rhBMP2 outcomes versus placebo can be made because only one trial is available. Both trials comparing rhBMP2 to AGB/ALG reported oral sensory loss. One trial reported 8% at 1 month, the other 17% at 6 months. | Direct evidence was available for all outcomes of interest. | The evidence is imprecise. Statistical significance is not reported and it is not possible to calculate confidence intervals. | The strength of the body of evidence is moderate that rhBMP2 does not provide an advantage in prosthesis implantation and functional loading compared to autograft plus allograft bone. However, there is also moderate evidence that oral sensory loss associated with autograft bone harvest can be avoided by use of rhBMP2.

Table 20 shows facial edema was reported among patients who underwent staged bilateral or unilateral maxillary sinus floor augmentation.75,77 Transient immune sensitization to rhBMP2 was observed in recipients at 1.9 mg/pt, but this was associated with no clinical sequelae.75,77

Transient immune sensitization to bovine collagen also was reported in 11 to 32 percent of patients who received rhBMP2 in those studies. Adverse events associated with the autograft harvest site included edema, pain, rash, gait disturbance, and sensory loss. The larger trial77 reported oral sensory loss in 17 percent of patients 6 months after the procedure.

Table 18 On-Label Randomized Trials of rhBMP2 for Sinus and Alveolar Ridge Augmentation

Indication (ref no.) | No. of studies | Group | Total no. pts | Follow-up (mos.) | BMP dose range (mg/pt) | USPSTF study quality
Maxillofacial defects (75, 76, 77) | 3 | rhBMP2 | 158 | 4–36 | 6–48 | 3 GOOD
Maxillofacial defects (75, 76, 77) | 3 | AGB | 93 | 4–36 | 0 | 3 GOOD
Maxillofacial defects (75, 76, 77) | 3 | Placebo | 37 | 4–36 | 0 | 3 GOOD

Abbreviations: AGB: autograft bone; no.: number; pt(s): patient(s); ref: reference;

Table 19 Clinical Outcomes in On-Label Randomized Trials of rhBMP2 for Sinus and Alveolar Ridge Augmentation

Study (ref no.) | Group | No. pts | BMP dose range (mg/pt) | Bone height change (mn +/− SD, mm) | Prosthesis implantation into newly induced bone, % | Successful prosthetic functional loading, % | USPSTF study quality
Boyne et al., 2005 (75) | rhBMP2 | 18 | 6–24 | 9.47 +/− 5.72 | 83 | 100 | GOOD
Boyne et al., 2005 (75) | rhBMP2 | 17 | 15–48 | 10.16 +/− 4.70 | 88 | 100 | GOOD
Boyne et al., 2005 (75) | AGB/ALG | 13 | 0 | 11.29 +/− 4.12 (4 mos.) | 100 | 100 (36 mos.) | GOOD
Triplett et al., 2009 (77) | rhBMP2 | 80 | 12–24 | 7.83 +/− 3.52 | 82 | 76 | GOOD
Triplett et al., 2009 (77) | AGB/ALG | 80 | 0 | 9.46 +/− 4.11 (p=0.009) | 95 | 91 (p=0.017) | GOOD
Fiorellini et al., 2005 (76) | rhBMP2 | 22 | 0.9 | NR | 55 | NR | GOOD
Fiorellini et al., 2005 (76) | rhBMP2 | 21 | 1.9 | NR | 86 | NR | GOOD
Fiorellini et al., 2005 (76) | Placebo | 20 | 0 | NR | 59 | NR | GOOD
Fiorellini et al., 2005 (76) | No Tx | 20 | 0 | NR | 45 (p=0.009 no tx vs. 1.9 mg/pt) | NR | GOOD

Abbreviations: AGB: autograft bone; ALG: allograft bone; no.: number; pt(s): patient(s); ref: reference; Tx: treatment

Table 20 Adverse Events in On-Label Randomized Trials of rhBMP2 for Sinus and Alveolar Ridge Augmentation

Study (ref no.) | Group | Facial edema (%) | Autograft harvest-site adverse events (%)
Boyne et al., 2005 (75) | rhBMP2 (0.9 mg/pt) | 39 | edema (46) pain (38) rash (46) gait disturbance (16) oral sensory loss (8)
Boyne et al., 2005 (75) | rhBMP2 (1.9 mg/pt) | 82 | edema (46) pain (38) rash (46) gait disturbance (16) oral sensory loss (8)
Boyne et al., 2005 (75) | AGB/ALG | 38 (p=0.0227 AGB/ALG vs. 0.9 mg gp, p=0.0152 0.9 mg gp vs. 1.9 mg gp) | edema (46) pain (38) rash (46) gait disturbance (16) oral sensory loss (8)
Triplett et al., 2009 (77) | rhBMP2 | p=0.048 vs. AGB/ALG, numbers not reported | oral sensory loss (17) pain (NR) gait disturbance (NR)
Triplett et al., 2009 (77) | AGB/ALG | p=0.048 vs. AGB/ALG, numbers not reported | oral sensory loss (17) pain (NR) gait disturbance (NR)
Fiorellini et al., 2005 (76) | rhBMP2 | NR | NA
Fiorellini et al., 2005 (76) | rhBMP2 | NR | NA
Fiorellini et al., 2005 (76) | Placebo | NR | NA
Fiorellini et al., 2005 (76) | No Tx | NR | NA

Abbreviations: AGB: autograft bone; ALG: allograft bone; gp: group; NA: not applicable; no.: number; pt(s): NR: not reported; patient(s); ref: reference; Tx: treatment

### Key Question 6 For which indications are there clinical studies in which BMP is used off-label? In such studies, what is the evidence of the effectiveness of BMP?

The strength of evidence for off-label uses was graded only for settings that had more than one comparative trial involving patients sufficiently similar to allow synthesis. Those comprise the lumbar-sacral spine and cervical spine, with distribution between rhBMP2 and rhBMP7 summarized in Table 21.

#### Lumbar-Sacral Spine

##### rhBMP2

Summary. There are six randomized73, 84–88 and five nonrandomized comparative studies99–103 of off-label use of rhBMP2 in fusion of the lumbar-sacral spine. The two largest RCTs85, 86 were rated “fair” and are given greatest weight in this review of evidence. The strength of evidence that rhBMP2 improves radiographic fusion success is moderate. The strength of evidence that rhBMP2 improves other outcomes is low.

###### Off-Label Randomized Clinical Trials of rhBMP2 in Lumbar-Sacral Spine

As shown in Table 22, six reports describe the results of RCTs in which off-label use of rhBMP2 (total N=449) was compared to autograft bone (total N=383) to enhance surgical fusion of the lumbar spine.73, 84–88

There are several reasons to consider rhBMP2 use off-label in these studies. These include use of a nonapproved formulation, or matrix, in conjunction with the approved rhBMP2; use of a non-anterior surgical approach with InFUSE®; use of InFUSE® with a nonapproved interbody entity; and, use in multi-level fusion. Thus, rhBMP2 (InFUSE®) was applied via an absorbable collagen sponge, alone or with an unapproved compression-resistant matrix (CRM) in two trials.84,86 in which a 40 mg dose was used in Investigational Device Exemption (IDE) studies for the AMPLIFY device, which was under FDA review for marketing approval at the time this report was prepared. In two trials, rhBMP2 (InFUSE®) was administered in a dose range of 4.2 to 12 mg per patient, placed inside cortical threaded allograft bone dowels in one RCT85 and for single- or multi-level, posterolateral instrumented fusion with discretionary bone graft extenders in the second.87 Another study73 was an FDA Investigational Device Exemption (IDE) study for InFUSE®/Mastergraft, with rhBMP2 (InFUSE®) applied at a dose of 12 mg per patient with an unapproved osteoconductive compression-resistant matrix (CRM) comprising 15 percent hydroxyapatite and 85 percent tricalcium phosphate ceramic. However, the manufacturer of this product has voluntarily withdrawn the HDE approval so this is a nonapproved formulation of an approved rhBMP2 product (InFUSE®). The last study reported on single-level posterolateral interbody fusion using InFUSE®, but it was stopped prior to full accrual.88 In all RCTs, patients underwent primary fusion.

In all trials, autograft bone (AGB), mainly harvested from iliac crest, and additional instrumentation were used.

Four RCTs73, 84–86 were rated as “fair” according to the USPSTF study quality evaluation system, and the other two were rated as “poor” (see Appendix 2 for details). All trials independently assessed radiographic fusion success, generally reflecting the presence of bilateral bridging bone between transverse processes at 17 to 24 months. In the InFUSE®/Mastergraft trial,73 this outcome also reflected incorporation of the compression-resistant matrix into newly formed bone. The RCTs rated as “fair” did not report intention-to-treat (ITT) analysis or describe randomization procedures. One trial that was rated “poor”88 did not report randomization method or ITT analysis and included a subset of data on patients from a larger, terminated trial. The second trial, rated “poor,”87 did not report randomization procedures or ITT analysis, patient characteristics and comorbid conditions were not well described, the investigators reported use of undefined bone graft extender or filler plus local bone shavings in 100 percent of cases in both groups, and pooled outcome data from multilevel and single-level fusion patients.

Statistically significant improvement in radiographic fusion success was reported in the two largest two trials85,86 (Table 23) . A third trial reported a statistically significant improvement in radiographic fusion success, but this result is limited by the small number of patients in the study.84 Similarly, conclusions cannot be drawn for radiographic fusion success in the other 3 studies due to limited sample sizes. Inconsistent reporting of ODI success, ODI mean point score, leg pain mean point score, and SF-36 mean point score limits synthesis and conclusions.

Three RCTs84,86,88 reported on autograft harvest site pain (Table 24). At discharge, scores on a 20-point numeric rating scale were 11.3, 11.6, and 16.0. By 17 to 24 months, mean pain scores had decreased to approximately 5 on a 20-point scale. In another study, pain was not reported at the graft harvest site, but an infection was reported in one patient.73

Table 21 Overall Grade of Strength of Comparative Study Evidence for Off-Label Use of rhBMP2 in the Lumbar-Sacral Spine

Key Question | Study Design | Risk of bias | Consistency | Directness | Precision | Overall Grade/Conclusion
What is the level of evidence and summary of evidence for the off-label use of rhBMP2 in fusion of the lumbar-sacral spine? Outcomes of interest include radiographic fusion, pain, function, satisfaction measures, and adverse events. | There are six RCTs and five nonrandomized comparative studies of rhBMP2 versus autograft. Studies were deemed off-label because of a nonapproved surgical approach (84, 86–88), use of nonapproved matrix formulations of the approved rhBMP2 product (73, 84, 86), or use of the approved rhBMP2 product with nonapproved device(s) (85). | Overall there a medium risk of bias for the body of evidence. The two largest RCTs were rated “fair” and are given greatest weight in the review of evidence. The remaining evidence is four randomized and five nonrandomized comparative studies that were largely rated as poor quality or were very small in size. Risk of bias in this body of evidence for radiographic and functional outcomes is medium for the RCTs and high for the nonrandomized studies. Device-related harms are inconsistently reported in this literature. Therefore there is a high risk of bias with respect to adverse events. | Statistically significant improvement in radiographic fusion success was reported in the two largest RCTs. (86, 85) One (n = 463) involved the use of a nonapproved matrix formulation with InFUSE and a posterolateral surgical approach (86). The second RCT (n = 131) used cortical threaded allograft bone dowels rather than an approved cage device to contain the rhBMP2 product (InFUSE). (85) A third RCT (n = 27) reported a statistically significant difference in rhBMP2 recipients and controls, but this result is limited by the small number of patients (84). In the other three RCTS, no statements regarding consistency can be made due to limited sample sizes. Three RCTs that reported autograft harvest site pain showed pain at discharge, diminishing over time. (84, 87, 88) Conclusions on these observations are limited. The nonrandomized comparative studies generally reported similar results but are given low weight in this review because of poor quality. | Direct evidence was available for outcomes, but was limited for ODI success. | The evidence is imprecise. | The strength of evidence that rhBMP2 improves radiographic fusion success is moderate, based on the two largest RCTs. Among all six RCTs, interstudy variables include rhBMP2 dose, surgical approach, matrix formulation, or hardware. No conclusions can be drawn regarding the potential impact of the off-label components on radiographic fusion success. The strength of evidence that rhBMP2 improves other outcomes is low. The evidence gives moderate support to clinical benefit from the use of rhBMP2 as patients can avoid the additional procedure of autograft bone harvest and its associated adverse events.

Table 22 Off-Label Randomized Trials of rhBMP2 for Lumbar-Sacral Spinal Fusion

Indication (ref no.) | No. of studies | Group | Total no. pts | Follow-up (mos.) | BMP dose range (mg/pt) | USPSTF study quality
Degenerative disc disease of the lumbar spine (73, 84–88) | 6 | rhBMP2 | 449 | 12–27 | 4.2–40 | 4 FAIR 2 POOR
Degenerative disc disease of the lumbar spine (73, 84–88) | 6 | AGB | 383 | 12–27 | 0 | 4 FAIR 2 POOR

Table 23 Clinical Outcomes in Off-Label Randomized Trials of rhBMP2 for Lumbar-Sacral Spinal Fusion^*^

Study (ref no.) | Group | No. Pts | BMP dose (mg/pt) | Off-Label Category | Radiographic fusion success % | ODI success % | ODI mean point score ↑ | Leg pain mean point score ↑ | SF-36 PCS mean point score ↑ | USPSTF study quality
Boden et al, 2002 (84) | BMP2/BCP/TSRHSS | 11 | 40 | - unapproved formulation comprising a BCP CRM with approved rhBMP2 (InFUSE®); - posterolateral fusion; - proprietary instrumentation | 100 | ~65 | ~13 | ~3 | ~4 | FAIR
Boden et al, 2002 (84) | BMP2/BCP | 11 | 40 | - unapproved formulation comprising a BCP CRM with approved rhBMP2 (InFUSE®); - posterolateral fusion; - proprietary instrumentation | 100 | ~100 | ~29 | ~9 | ~16 | FAIR
Boden et al, 2002 (84) | ICBG/TSRHSS | 5 | 0 | - unapproved formulation comprising a BCP CRM with approved rhBMP2 (InFUSE®); - posterolateral fusion; - proprietary instrumentation | 40 (p=0.018, 0.028 in BMP2 grps vs. ICBG) | ~80 | ~25 | ~4 | ~7 (p=0.070 for BMP2/BCP vs. other groups) | FAIR
Burkus et al, 2005 (85) | BMP2 | 79 | 8–12 | - cortical threaded allograft bone dowels with approved rhBMP2 (InFUSE®) rather than an approved cage device | 98 | NR | 33 | 6.8 | 16 | FAIR
Burkus et al, 2005 (85) | ICBG | 52 | 0 | - cortical threaded allograft bone dowels with approved rhBMP2 (InFUSE®) rather than an approved cage device | 76 (p <0.001) | NR | 27 | 4.9 (p=0.011) | 12 (p=0.015) | FAIR
Dawson et al., 2009 (73) | BMP2/BCP | 25 | 12 | - unapproved formulation comprising a BCP CRM with approved rhBMP2 (InFUSE®); - HDE approval voluntarily withdrawn by Medtronic in early 2010 | 95 | 91 | 28 | 9.3 | NR | FAIR
Dawson et al., 2009 (73) | ICBG | 21 | 0 | - unapproved formulation comprising a BCP CRM with approved rhBMP2 (InFUSE®); - HDE approval voluntarily withdrawn by Medtronic in early 2010 | 67 | 70 | 23 | 7.2 | NR | FAIR
Dimar et al., 2009 (86) | BMP2/BCP | 239 | 40 | - unapproved formulation comprising a BCP CRM with approved rhBMP2 (InFUSE®); - posterolateral surgical approach | 96 | NR | ~26 | ~8 | ~13 | FAIR
Dimar et al., 2009 (86) | ICBG | 224 | 0 | - unapproved formulation comprising a BCP CRM with approved rhBMP2 (InFUSE®); - posterolateral surgical approach | 89 (p=0.014) | NR | ~24 | ~9 | ~10 | FAIR
Glassman et al., 2008 (87) | BMP2 | 50 | 8–12 | - posterolateral fusion with approved rhBMP2 (InFUSE®); - multi-level fusions in some patients; - additional discretionary bone graft extenders (local bone in all cases in both groups, others not described) | 86 | NR | 15 | 3.6 | 7 | POOR
Glassman et al., 2008 (87) | ICBG | 52 | 0 | | 71 | NR | 13 | 3.1 | 7 | POOR
Haid et al., 2004 (88) | BMP2 | 34 | 4.2–8.4 | - posterolateral interbody fusion with rhBMP2 (InFUSE®) | 92 | 69 | 30 | 7.7 | ~14 | POOR
Haid et al., 2004 (88) | ICBG | 33 | 0 | - posterolateral interbody fusion with rhBMP2 (InFUSE®) | 78 | 56 | 24 | 6.5 | ~11 | POOR

* Boden reported outcomes at 17 months, all others were 24 months

Abbreviations: BCP: biphasic calcium phosphate carrier; CRM: compression-resistant matrix; ICBG: iliac crest bone graft; NR: not reported; pt(s): patients(s); ODI: Oswestry Disability Index; PCS: physical component summaries; ref: reference; SF: short form; TSRHSS: Texas Scottish Rite Hospital Spinal System

Table 24 Autograft Harvest Site Pain Scores in Off-Label Randomized Studies of rhBMP2 in the Lumbar-Sacral Spine

Study (reference no.) | Pain score at discharge (20-point NRS) | Pain score at 24 months (20-point NRS)
Boden et al, 2002 (84) | 11.3 | 5.1
Glassman et al., 2008 (87) | 11.6 | 5.5
Haid et al., 2004 (88) | 16.0 | 5.2 (17 months)
Burkus et al, 2005 (85) | not reported | not reported
Dawson et al., 2009 (73) | not reported | not reported
Dimar et al., 2009 (86) | not reported | not reported

Abbreviations: NRS: numeric rating scale

###### Off-Label Nonrandomized Comparative Studies of rhBMP2 in Lumbar-Sacral Spine

Table 25 summarizes five nonrandomized studies99–103 (prospective and retrospective designs) of the off-label use of rhBMP2 for primary fusion in the lumbar-sacral spine. Two studies101,103 reported on the use of rhBMP2 in anterior lumbar interbody fusion procedures. Two studies99,102 reported results of fusion using a posterolateral approach. One study100 reported lumbar interbody fusion using a posterolateral transforaminal route. Three studies99,101,102 reported only fusion data; two100,103 reported fusion results plus limited clinical outcomes.

One study101 used stand-alone femoral ring allograft spacers packed with either ICBG or rhBMP2. The other four studies used pedicle screw instrumentation, among which one103 used FRA interbody spacers, another100 used polyetheretherketone (PEEK) or titanium interbody cages, and the other two99,102 used ICBG chips wrapped in collagen sponge soaked with rhBMP2.

Table 25 Off-Label Nonrandomized Comparative Studies of rhBMP2 for Lumbar-Sacral Spinal Fusion

Indication (ref no.) | No. of studies | Group | Total no. pts | Follow- up (mos.) | BMP dose range (mg/pt) | USPSTF study quality
Degenerative disc disease of the lumbar spine (99, 100, 101, 102, 103) | 5 | rhBMP2 | 209 | 3–38 | 3–36 | 1 FAIR 4 POOR
Degenerative disc disease of the lumbar spine (99, 100, 101, 102, 103) | 5 | ICBG or ALG | 122 | 3–38 | 0 | 1 FAIR 4 POOR

Abbreviations: ALG: allograft bone; ICBG: iliac crest bone graft; mos.: months; no.: number; pt(s); patient(s) USPSTF: U.S. Preventive Services Task Force

rhBMP2 (total N=209) was typically applied via collagen sponge in a dose range of 3 to 36 mg per patient, compared to ICBG or ALG bone, and had 3 to 38 months’ follow-up. Two studies100,102 admixed rhBMP2 and AGB, with ALGB used solely as comparator in one study.103

One study101 was rated as “fair”; the other four99,100,102,103 were rated “poor” according to the USPSTF study quality rating system.

Table 26 Clinical Outcomes in Off-Label Nonrandomized Comparative Studies of rhBMP2 for Lumbar-Sacral Spinal Fusion

Study (ref no.) | Group | No. Pts | BMP dose (mg/pt) | Radiographic fusion success 24 mos., % | USPSTF study quality
Glassman et al., 2007; USA(99) | rhBMP2 | 91 | 12 | 96 | POOR
Glassman et al., 2007; USA(99) | ICBG | 35 | 0 | 89 | POOR
Mummaneni et al., 2004; USA(100) | rhBMP2/AGB | 25 | 8.4 | 96 | POOR
Mummaneni et al., 2004; USA(100) | ICBG | 19 | 0 | 95 | POOR
Pradhan et al., 2006; USA (101) | rhBMP2 | 9 | NR | 44 | FAIR
Pradhan et al., 2006; USA (101) | ICBG | 27 | 0 | 63 | FAIR
Singh et al., 2006; USA (102) | rhBMP2/ICBG | 39 | 12–36 | 94 | POOR
Singh et al., 2006; USA (102) | ICBG | 11 | 0 | 77 (p<0.05) | POOR
Slosar et al., 2007; USA (103) | rhBMP2 | 45 | 3–9 | 99 | POOR
Slosar et al., 2007; USA (103) | ALG | 30 | 0 | 82 (p<0.001) | POOR

Abbreviations: AGB: autograft bone; ALG: allograft bone; ICBG: iliac crest bone graft; mos.: months; no.: number; pt(s); patient(s); USPSTF: U.S. Preventive Services Task Force

These nonrandomized studies reported radiographic fusion success at 24 months. With one exception, all reported radiographic fusion success rates with rhBMP2 that were similar or better than with ICBG. These studies were generally rated as poor quality.

Of note, in one study graft resorption and incorporation appeared to occur earlier and more aggressively with the use of rhBMP2 compared to the use of ICBG.101 The initial osteolytic phase in particular appeared to be accelerated in the rhBMP2 group. In cases of non-union (56 percent), extensive osteolysis of and around the FRA was observed, causing fracture, fragmentation, and collapse of the graft, particularly visible on thin-slice CT with sagittal and 3-dimensional reconstructions. Bone formation eventually ensued in cases of fusion (44 percent), but not in the pseudarthrosis cases. In cases of non-union with ICBG, the structural integrity of the graft remained mostly intact, although some degree of radiolucency surrounded the graft with evidence of instability on flexion-extension.

##### rhBMP7

###### Off-Label Randomized Clinical Trials of rhBMP7 in Lumbar-Sacral Spine

Summary. The best available evidence is a single, good quality RCT94 (Table 27). The evidence is insufficient to draw conclusions on the off-label use of rhBMP7 in fusion of the lumbar-sacral spine.

Table 27 Overall Grade of Strength of Comparative Study Evidence for Off-Label Use of rhBMP7 in the Lumbar-Sacral Spine

Key Question | Study Design | Risk of bias | Consistency | Directness | Precision | Overall Grade/Conclusion
What is the level of evidence and summary of evidence for the off-label use of rhBMP7 in fusion of the lumbar-sacral spine? Outcomes of interest include radiographic fusion, pain, function, satisfaction measures, and adverse events. | The best available evidence for the efficacy of rhBMP7 used off-label for lumbar spinal fusion comes from one RCT. There are three additional small, poor quality trials. | The risk of bias for the larger Vaccaro trial was rated low with respect to fusion and functional outcomes. The three additional trials, small and of poor quality have a high risk of bias. | Consistency cannot be assessed as all but one trial were rated poor quality. | The evidence on fusion and functional outcomes is direct. However, the three poor quality trials did not fully report on functional outcomes. | The evidence is imprecise as no tests of statistical significance are reported. | The evidence is insufficient to draw conclusions on the off-label use of rhBMP7 infusion of the lumbar-sacral spine.

Table 28 shows four RCTs92–94 of off-label use of rhBMP7 for fusion of the lumbar-sacral spine. In all studies summarized in Table 29, radiographic fusion success reflects the presence of bilateral bridging bone or solid fusion.

Table 28 Off-Label Randomized Trials of rhBMP7 for Lumbar-Sacral Spinal Fusion

Indication (ref no.) | No. of studies | Group | Total no. pts | Follow-up (mos.) | BMP dose range (mg/pt) | USPSTF study quality
Degenerative disc disease of the lumbar spine (92, 93, 94, 95) | 4 | rhBMP7 | 250 | 12–66 | 7 | 1 GOOD 3 POOR
Degenerative disc disease of the lumbar spine (92, 93, 94, 95) | 4 | AGB | 118 | 12–66 | 0 | 1 GOOD 3 POOR

Abbreviations: AGB: autograft bone; ICBG: iliac crest bone graft; mos.: months; no.: number; pt(s); patient(s) USPSTF: U.S. Preventive Services Task Force

Table 29 Clinical Outcomes in Off-Label Randomized Trials of rhBMP7 for Lumbar-Sacral Spinal Fusion

Study (ref no.) | Group | No. Pts | BMP dose (mg/pt) | Radiographic fusion success, % | ODI success 24 mos., % | ODI mean point score ↑ 24 mos. | Neurological success, % | USPSTF study quality
Johnsson et al., 2002 (92) | BMP7 | 10 | 7 | 60 | NR | NR | NR | POOR
Johnsson et al., 2002 (92) | ICBG | 10 | 0 | 80 (12 mos.) | NR | NR | NR | POOR
Kanayama et al., 2006 (93) | BMP7 | 9 | 7 | 78 | NR | ~17 | NR | POOR
Kanayama et al., 2006 (93) | AGB/CRM | 10 | 0 | 90 (15 mos.) | NR | ~24 | NR | POOR
Vaccaro et al., 2008 (94) | BMP7 | 207 | 7 | 75 | 69 | 25 | 84 | GOOD
Vaccaro et al., 2008 (94) | ICBG | 86 | 0 | 77 (36 mos.) | 77 (36+ mos.) | 27 (36+ mos.) | 80 (36+ mos.) | GOOD
Vaccaro et al., 2008 (95) | BMP7 | 24 | 7 | 69 | 74 | NR | NR | POOR
Vaccaro et al., 2008 (95) | ICBG | 12 | 0 | 50 (48 mos.) | 57 (48 mos.) | NR | NR | POOR

Abbreviations: AGB: autograft bone; CRM: compression-resistant matrix; ICBG: iliac crest bone graft; mos.: months; no.: number; NR: not reported; ODI: Oswestry Disability Index; pt(s); patient(s); USPSTF: U.S. Preventive Services Task Force

All patients underwent a single-level posterolateral fusion for symptomatic DDD. Fusions in three trials92,94,95 were performed without instrumentation; one was performed with instrumentation and also used a HA-TCP compression-resistant matrix.93

All studies used rhBMP7 at a dose of 7 mg per patient (total N=250) versus AGB (total N=118), with follow-up of 12 to 66 months.

One study94 was graded as “good”, the other three92,93,95 were rated as “poor” according to the USPSTF study quality rating criteria.

The best available evidence for the efficacy of rhBMP7 used off-label for lumbar spinal fusion comes from an open-label (with blinded radiographic assessment), randomized, prospective, multicenter (n=24) trial conducted as an Investigational Device Exemption (IDE) study.94 This study reported similar results for rhBMP7 and autograft bone for radiographic fusion success, ODI success, ODI mean point score improvement, and neurological success, but did not report statistical significance. The three additional trials92,93,95 are small, poor quality, and do not add to nor contradict the results of the largest RCT.94

In the larger Vaccaro study, autograft harvest site pain was persistent and declined slowly. At 12 months, 44% of autograft patients reported pain at the harvest site, which declined to 35% who reported mild to moderate pain at 36 month.94

#### Cervical Spine

##### rhBMP2

Summary. The evidence consists of one randomized trial89 and four nonrandomized comparative studies104–107 of off-label use of rhBMP2 for cervical spinal fusion. Two small studies, a randomized trial and a nonrandomized comparative study,89,107 reported on fusion success and changes in mean neck disability scores. The other 3 nonrandomized studies focused mainly on complications.104–106

There is moderate evidence that off-label use of rhBMP2 in anterior cervical spinal fusion increases cervical swelling and related complications. There is insufficient evidence to draw conclusions about radiographic fusion success or associated changes in neck disability scores.

Table 31 summarizes one randomized89 and four nonrandomized comparative studies104–107 of off-label use of rhBMP2 for fusion of the cervical spine with follow-up of 1.5 to 36 months. Patients underwent single- or multi-level cervical spinal fusion, using an anterior approach89,104,106,107 or posterior approach.105 Additional instrumentation was used in all studies, including all patients in three studies,105–107 but some underwent uninstrumented fusion in 1 study (104). In one RCT, rhBMP2 (0.6 to 1.2 mg per patient) was applied via absorbable collagen sponge (ACS) packed inside a fibular allogeneic (ALG) bone ring, with a comparator of autologous bone graft (AGB) packed inside a fibular ALG ring for DDD of the cervical spine.89

rhBMP2 (total N=180) was applied typically via absorbable collagen sponge in a dose range of 0.9 to 12 mg per patient, combined with a bone graft extender such as cortical ring allograft (CRA) or compression-resistant matrix (CRM) in four studies,89,104–106 and used in PEEK cages in one study.107 Comparators (total N=276) included ICBG alone in two studies,104,105 CRA,89,106 or ALG bone plus demineralized bone matrix (DBM).107

The RCT89 was rated as “fair” and all four nonrandomized studies104–106 were rated as “poor” according to criteria of the USPSTF study quality rating system.

Table 32 shows that two small studies, the RCT89 and a nonrandomized comparative study107 reported on radiographic fusion success and changes in mean neck disability score, that are insufficient to support conclusions. The other three nonrandomized comparative studies were largely focused on complications, which are summarized in Table 33. These nonrandomized, poor quality studies are insufficient to support conclusions on radiographic fusion success or changes in ODI scores in patients undergoing anterior cervical spinal fusion.

Table 30 Overall Grade of Strength of Comparative Study Evidence for Off-Label Use of rhBMP2 (InFUSE) in the Cervical Spine

Key Question | Study Design | Risk of bias | Consistency | Directness | Precision | Overall Grade/Conclusion
What is the level of evidence and summary of evidence for the off-label use of rhBMP2 in fusion of the cervical spine? Outcomes of interest include radiographic fusion, pain, function, satisfaction measures, and adverse events. | Two small studies, an RCT and a nonrandomized comparative study reported on radiographic fusion success and changes in mean neck disability score. The other three nonrandomized comparative studies above were largely focused on complications | The risk of bias for fusion and neck disability outcomes was rated high due to the size and quality of two studies that reported those outcomes. The risk of bias for harms was rated medium. Overall, these studies were more complete than most studies in this literature in reporting harms, based on a modified McHarms scale. | There was insufficient evidence to draw conclusions about radiographic fusion success and neck disability measures. In two studies the frequency of cervical swelling and associated complications was significantly greater in the rhBMP2 arm. In the third study, these complications were similar in both arms, but the frequency was substantially higher in both arms than in the other two studies. Overall, this suggests that cervical swelling, and complications related to swelling, are more frequent with rhBMP2 and are not solely a result of the procedure. | Direct evidence was available for all outcomes reported. | The evidence on fusion and neck disability measures is imprecise. The evidence of swelling complications is precise as the two key studies report results that are highly statistically significant. | There is moderate evidence that off-label use of rhBMP2 in anterior cervical spinal fusion increases cervical swelling and related complications. There is insufficient evidence to draw conclusions about radiographic fusion success or associated changes in neck disability measures.

Table 31 Off-Label Comparative Studies of rhBMP2 (InFUSE) for Cervical Spinal Fusion

Indication (ref no.) | No. of studies | Group | Total no. pts | Follow-up (mos.) | BMP dose range (mg/pt) | USPSTF study quality
Randomized study: DDD of the cervical spine (89) | 1 | rhBMP2 | 18 | 24 | 0.6–1.2 | FAIR
Randomized study: DDD of the cervical spine (89) | 1 | AGB/ALG | 15 | | 0 | FAIR
Nonrandomized studies: DDD of the cervical spine (104, 105, 106, 107) | 4 | rhBMP2/BGE | 162 | 1.5–36 | 0.9–12 | 4 POOR
Nonrandomized studies: DDD of the cervical spine (104, 105, 106, 107) | 4 | ICBG or ALG | 261 | 1.5–36 | 0 | 4 POOR

Abbreviations: AGB: autograft bone; ALG: allograft bone; BGE: bone graft extender; ICBG: iliac crest bone graft; mos.: months; no.: number; pt(s); patient(s); USPSTF: U.S. Preventive Services Task Force

Table 32 Clinical Outcomes in Off-Label Comparative Studies of rhBMP2 (InFUSE) for Cervical Spinal Fusion

Study (ref no.) | Group | No. Pts | BMP dose (mg/pt) | Radiographic fusion success, % | ODI mean score ↑ 24 mos. | USPSTF study quality
Baskin et al., 2003 randomized (89) | rhBMP2/ALG | 18 | 0.6–1.2 | 100 | 53 | FAIR
Baskin et al., 2003 randomized (89) | ICBG/CRA | 15 | 0 | 100 | 37 (p<0.03) neck disability index | FAIR
Butterman et al., 2008 nonrandomized (104) | rhBMP2/CRA | 30 | 0.9–3.7 | NR | ~30 | POOR
Butterman et al., 2008 nonrandomized (104) | ICBG | 36 | 0 | NR | ~31 | POOR
Crawford et al., 2009 nonrandomized (105) | rhBMP2/BGE | 41 | 4.2–12 | NR | NR | POOR
Crawford et al., 2009 nonrandomized (105) | ICBG | 36 | 0 | NR | NR | POOR
Smucker et al., 2006 nonrandomized (106) | rhBMP2/CRA | 69 | mn 1.32 | NR | NR | POOR
Smucker et al., 2006 nonrandomized (106) | CRA | 165 | 0 | NR | NR | POOR
Vaidya et al., 2007 nonrandomized (107) | rhBMP2 | 22 | 1–3 | 100 | 24 | POOR
Vaidya et al., 2007 nonrandomized (107) | ALG/DBM | 24 | 0 | 96 | 33 | POOR

Abbreviations: AGB: autograft bone; ALG: allograft bone; BGE: bone graft extender; CRA: cortical ring allograft; DBM: demineralized bone matrix; ICBG: iliac crest bone graft; mn: mean; mos.: months; no.: number; NR: not reported; pt(s); patient(s); USPSTF: U.S. Preventive Services Task Force

Table 33 Swelling and Related Complications in Off-Label Nonrandomized Comparative Studies of rhBMP2 (InFUSE) for Anterior Cervical Spinal Fusion

Study (ref no.) | Group (n) | Swelling % | Dysphagia % | Hoarseness % | Delayed Discharge %
Butterman et al., 2008 (104) | rhBMP2/CRA (30) | 50 | NR | NR | NR
Butterman et al., 2008 (104) | ICBG (36) | 14 (p<0.01) | NR | NR | NR
Smucker et al., 2006 (106) | rhBMP2/CRA (69) | 28 | 7 | NR | 3
Smucker et al., 2006 (106) | CRA (165) | 4 (p<0.0001) | 1 | NR | 0
Vaidya et al., 2007 (107) | rhBMP2 (22) | 100 | 85 | 60 | NR
Vaidya et al., 2007 (107) | ALG/DBM (24) | 100 | 56 (p=0.0092) | 62 | NR

Abbreviations: ALG: allograft bone; CRA: cortical ring allograft; DBM: demineralized bone matrix; ICBG: iliac crest bone graft; no.: number; NR: not reported;

Cervical neck swelling and dysphagia following anterior cervical fusion surgery were reported in three studies.104,106,107 In two studies104,106 the frequency of swelling was significantly greater in the rhBMP2 arm. In the third study, these complications were similar in both arms, but the frequency was substantially higher than in the other two studies. This suggests that cervical swelling, and complications related to swelling, are more frequent with rhBMP2 and are not solely a result of the procedure.

In the study by Smucker et al.,106 five patients in the rhBMP2 group required hospital readmission for either medical or surgical management of swelling, compared to none of the control group. Results from a multivariate logistic analysis showed the use of rhBMP2 was significantly associated with cervical swelling complications (p<0.0001) with an odds ratio of 10.1 (95% CI: 3.8–26.6), suggesting patients who were treated with rhBMP2 were 10 times more likely to have a swelling complication versus those who did not receive this agent.

Autograft bone harvested from the iliac crest was used in two studies.104,105 One study reported a single deep surgical site infection at the donor site that was successfully treated with irrigation and debridement surgery followed by antibiotics; no other donor site complications were reported.105 The second study reported one patient with donor site infection that required irrigation, debridement, and antibiotics; a second patient experienced pain secondary to avulsion of the superior iliac spine that was addressed by open-reduction internal fixation.104

###### Evidence Summary for Miscellaneous Off-Label Uses of rhBMP2

Table 34 shows two small RCTs in which rhBMP2 (total N=24) was used off-label in comparison to autologous bone graft (AGB) alone or with allogeneic graft (ALG) (total N=27) to enhance bone healing at 12 to 24 months follow-up.90,91 One was rated “fair”90 and the other was rated “poor”91 according to the USPSTF quality rating system.

In one RCT, rhBMP2 (12 mg per patient) was adsorbed on a collagen sponge and admixed with ALG chips to treat open tibial fractures.90 In the second RCT, rhBMP2 (dose unclear) was applied via collagen sponge to undertake repair of unilateral cleft lip and palate defects.91

Table 34 also shows two small, nonrandomized comparative off-label studies of rhBMP2. The first study described treatment of treat acute tibial fractures.108 The second described posterior spinal fusion for ankylosing spondylitis or neuromuscular deformities.109 Both studies were rated as “poor” according to the USPSTF study quality rating system criteria.

In one study, rhBMP2 (n=17) was applied via collagen sponge at a dose of 12 mg per patient, with various bone graft enhancers used as comparator (n=23) with follow-up of 18 months.108 In the second study, rhBMP2 was mixed with AGB, CRM, or ALGB (n=23), in a total dose range of 64 to 320 mg per patient and compared to ICBG (n=32), with follow-up of more than 24 months.109

The evidence from the small, generally poor quality studies shown in Table 34 is insufficient to draw conclusions about the outcomes with rhBMP2 in these settings.

Table 34 Miscellaneous Off-Label Uses of rhBMP2

Indication (ref no.) | No. of studies | Group | Total no. pts | Follow-up (mos.) | BMP dose range (mg/pt) | USPSTF study quality
Diaphyseal tibial fractures with cortical defect (90) randomized trial | 1 | rhBMP2 | 15 | 12 | 12 | FAIR
Diaphyseal tibial fractures with cortical defect (90) randomized trial | 1 | AGB | 15 | 12 | 0 | FAIR
Repair of unilateral cleft lip-palate (91) randomized trial | 1 | rhBMP2 | 9 | 12 | 4.2–12 | POOR
Repair of unilateral cleft lip-palate (91) randomized trial | 1 | AGB | 12 | 12 | 0 | POOR
Acute traumatic tibial plateau fractures (108) nonrandomized, comparative study | 1 | rhBMP2 | 17 | 18 | 12 | POOR
Acute traumatic tibial plateau fractures (108) nonrandomized, comparative study | 1 | BGE | 23 | 18 | 0 | POOR
Posterior spinal fusion for ankylosing spondylitis or neuromuscular deformity (109) nonrandomized, comparative study | 1 | rhBMP2/BGE | 23 | >24 | 64–320 | POOR
Posterior spinal fusion for ankylosing spondylitis or neuromuscular deformity (109) nonrandomized, comparative study | 1 | ICBG | 32 | >24 | 0 | POOR

Abbreviations: AGB: autograft bone; BGE: bone graft extender; mos.: months; no.: number; pt(s); patient(s); USPSTF: U.S. Preventive Services Task Force

###### Evidence Summary for Miscellaneous Off-Label Uses of rhBMP7

Table 35 shows three RCTs that compared off-label use of rhBMP7 in three disparate settings; revision of scaphoid non-union,96 high tibial osteotomy,98 and osteotomy of the distal radius for symptomatic malunion.97 One study96 was rated “good,” one98 was rated “fair,” and one97 was rated “poor” according to the USPSTF study quality rating criteria.

In one RCT, rhBMP7 was applied via collagen sponge at 3.5 mg per patient with AGB or ALG (6 patients each) and compared to AGB (n=6) with 24 months’ follow-up.96 In another trial, rhBMP7 was applied via collagen sponge at 2.5 mg per patient (n=6) and compared to DBM (n=6) and type I collagen (n=6) over 12 months’ follow-up.98 The third trial compared rhBMP7 (dose not reported, n=14) to ICBG (n=16) over 12 months’ follow-up.97

Table 35 also shows three nonrandomized comparative studies82,110,111 of off-label rhBMP7 treatment. In one study, rhBMP7 was applied at a dose of 1 mg per patient via collagen sponge, admixed with ALG (n=21) and compared to ALG bone (n=40) in patients undergoing impaction grafting for revision of hip arthroplasty.111 A follow-up of 60 months was prescribed, but the study was stopped early because of clinical failures. In a second, very small, pilot study, rhBMP7 was applied via collagen sponge at 2.5 mg per patient (n=3) and compared to ICBG (n=3) over 6 months’ follow-up in patients undergoing maxillary sinus floor augmentation.82 A third nonrandomized comparative study was identified in which rhBMP7 (Osigraft, dose not reported, n=20) with external fixation was compared to external fixation alone (n=20) to treat distal acute tibial fractures over follow-up of 12 to 45 months.110

All three nonrandomized comparative studies in Table 35^82,110,111^ were rated as “poor” according to the USPSTF study quality rating criteria.

The evidence from these studies is insufficient to draw conclusions about outcomes with rhBMP7 in these settings.

Table 35 Miscellaneous Off-Label Uses of rhBMP7

Indication (ref no.) | No. of studies | Group | Total no. pts | Follow- up (mos.) | BMP dose range (mg/pt) | USPSTF study quality
Revision of scaphoid bone non-union (96) randomized trial | 1 | rhBMP7 | 12 | 24 | 3.5 | GOOD
Revision of scaphoid bone non-union (96) randomized trial | 1 | AGB | 6 | 24 | 0 | GOOD
High tibial osteotomy (98) randomized trial | 1 | rhBMP7 | 6 | 12 | 2.5 | FAIR
High tibial osteotomy (98) randomized trial | 1 | DBM | 6 | 12 | 0 | FAIR
High tibial osteotomy (98) randomized trial | 1 | Type I collagen | 6 | 12 | 0 | FAIR
Osteotomy of the distal radius for symptomatic malunion (97) randomized trial | 1 | rhBMP7 | 14 | 12 | NR | POOR
Osteotomy of the distal radius for symptomatic malunion (97) randomized trial | 1 | ICBG | 16 | 12 | 0 | POOR
Distal tibial fractures (110) NRC | 1 | rhBMP7 | 20 | 12–45 | NR | POOR
Distal tibial fractures (110) NRC | 1 | External fixation | 20 | 12–45 | 0 | POOR
Impaction grafting for revision of hip arthroplasty (111) NRC | 1 | rhBMP7/ALG | 21 | 60 | 1 | POOR
Impaction grafting for revision of hip arthroplasty (111) NRC | 1 | ALG | 40 | 60 | 0 | POOR
Maxillary sinus floor elevation (82) NRC | 1 | rhBMP7 | 3 | 6 | 2.5 | POOR
Maxillary sinus floor elevation (82) NRC | 1 | ICBG | 3 | 6 | 0 | POOR

Abbreviations: AGB: autograft bone; ALG: allograft bone; DBM: demineralized bone matrix; ICBG: iliac crest bone graft; mos.: months; no.: number; NR: not reported; NRC: nonrandomized comparative study; pt(s); patient(s); USPSTF: U.S. Preventive Services Task Force

### Key Question 7 What is the evidence of adverse events with (a) on-label use of BMP and (b) off-label use of BMP? And, at what dosage and administration do such adverse events occur?

Table 36 summarizes BMP-specific harms. Overall the evidence on BMP-specific harms summarized in Table 36 is insufficient to draw conclusions in most settings. There is moderate evidence that off-label use of rhBMP2 in cervical spinal fusion increases cervical swelling and related complications.

Table 37 summarizes autograft donor harvest site harms. The body of evidence suggests that autograft bone harvest is associated with pain at the harvest site, but it is not possible to systematically assess the frequency, duration, and clinical significance. Overall, autograft harms were inconsistently reported. It is not clear that the absence of reported harms in many studies reflects true absence, or whether the investigators did not seek such data or did not report it.

#### BMP-Related Harms in On-Label Comparative Studies

Six on-label comparative studies71,72,74,75,77,79 describe specific harms attributable to the use of rhBMP2 or rhBMP7 with incidence ranging from 0.7 percent to 82 percent in a total of 630 patients who received a BMP device.

Antibody responses for bovine collagen were reported in five studies, of which four72,72,74,75,77 employed rhBMP2, while one used rhBMP7.^79^ Antibody reaction specific to rhBMP2 or rhBMP7 was observed in four studies,72,74,77,79 ranging from 0.7 percent72 to 2 percent.72,74 These were all transient with no clinical sequelae.

#### BMP-Related Harms in Off-Label Comparative Studies

Twelve off-label comparative studies84,85,88–90,94,97,104,106–108,110 describe specific harms attributable to the use of rhBMP2 or rhBMP7 in a total of 385 patients who received a BMP device.

Cervical neck swelling and dysphagia were reported in three anterior cervical fusion studies.104,106,107 In two studies,104,106 the frequency of swelling was significantly greater in the rhBMP2 arm. In the third study, these complications were similar in both arms, but the frequency was substantially higher than in the other two studies. This suggests that cervical swelling, and complications related to swelling, are more frequent with rhBMP2 and are not solely a result of the procedure.

Three studies reported extraosseous bone formation.97,108,110 One study108 employed rhBMP2 while two97,110 used rhBMP7. Antibody responses for bovine collagen were reported in four studies employing rhBMP2.^85,88–90^ Antibody reaction specific to rhBMP2 or rhBMP7 was observed in two studies,84,94 ranging from 4.5 percent84 to 94 percent.94 These were all transient with no clinical sequelae.

Table 36 Incidence of BMP-Related Adverse Events in Comparative Studies

Study (ref no.) | Study Design | Surgical Intervention | Group | N | BMP dose (mg/pt) | Cervical Swelling % | Facial Edema % | Dysphagia or Hoarseness % | anti-BMP Immune Response % | anti- Collagen Immune Response % | Hetero- topic bone % | Extra- osseous Bone/ Calcification %
Boyne et al., 2005 USA (75) rhBMP2 On-Label | Multicenter randomized dose-comparison, safety and efficacy study | Maxillary sinus floor augmentation | rhBMP2 | 18 | 6–24 | NR | 39 | NR | 12 | 24 | NR | NR
Boyne et al., 2005 USA (75) rhBMP2 On-Label | Multicenter randomized dose-comparison, safety and efficacy study | Maxillary sinus floor augmentation | rhBMP2 | 17 | 15–48 | NR | 82 | NR | 0 | 11 | NR | NR
Boyne et al., 2005 USA (75) rhBMP2 On-Label | Multicenter randomized dose-comparison, safety and efficacy study | Maxillary sinus floor augmentation | AGB/ALG | 13 | 0 | NR | 38 (p=0.0227, 0.0152, BMP high dose versus controls and lower dose, respectively) | NR | 0 | 23 | NR | NR
Triplett et al., 2009 (77) rhBMP2 On-Label | Multicenter, nonblinded RCT | Maxillary sinus floor augmentation | rhBMP2 | 80 | 12–24 | NR | Reported in rhBMP2 group as ”consistent with previous phase II study” (Boyne, above) but not quantified | NR | 2 | 29 | NR | NR
Triplett et al., 2009 (77) rhBMP2 On-Label | Multicenter, nonblinded RCT | Maxillary sinus floor augmentation | AGB/ALG | 80 | 0 | | Reported in rhBMP2 group as ”consistent with previous phase II study” (Boyne, above) but not quantified | NR | 0 | 32 | NR | NR
Govender et al. for the BESTT study group 2002 South Africa (74) rhBMP2 On-Label | Multi-center, single blind, RCT | IM nail fixation and soft tissue management for open tibial fractures | rhBMP2 | 151 | 6 | NR | NR | NR | 2 | 15 | Reported not to have occurred | Reported not to have occurred
Govender et al. for the BESTT study group 2002 South Africa (74) rhBMP2 On-Label | Multi-center, single blind, RCT | IM nail fixation and soft tissue management for open tibial fractures | rhBMP2 | 149 | 12 | | | | 6 | 20 | Reported not to have occurred | Reported not to have occurred
Govender et al. for the BESTT study group 2002 South Africa (74) rhBMP2 On-Label | Multi-center, single blind, RCT | IM nail fixation and soft tissue management for open tibial fractures | Standard care | 150 | 0 | | | | 1 | 6 | Reported not to have occurred | Reported not to have occurred
Burkus et al., 2002 USA (72) rhBMP2 On-Label | Multicenter, nonblinded RCT | Single-level primary anterior lumbar fusion | rhBMP2 | 143 | 4.2–8.4 | NR | NR | NR | 0.7 | NR | NR | NR
Burkus et al., 2002 USA (72) rhBMP2 On-Label | Multicenter, nonblinded RCT | Single-level primary anterior lumbar fusion | ICBG | 136 | 0 | NR | NR | NR | 0.8 | NR | NR | NR
Boden et al., 2000 USA (71) rhBMP2 On-Label | Multicenter, nonblinded RCT | Single-level primary anterior lumbar fusion | rhBMP2 | 11 | 4.2–8.4 | NR | NR | NR | 0 | 27 | NR | NR
Boden et al., 2000 USA (71) rhBMP2 On-Label | Multicenter, nonblinded RCT | Single-level primary anterior lumbar fusion | ICBG | 3 | 0 | NR | NR | NR | 0 | 0 | NR | NR
Haid et al., 2004 USA (88) rhBMP2 Off-Label | Multicenter, nonblinded RCT | Single-level primary posterior lumbar interbody fusion | rhBMP2 | 34 | 4.2–8.4 | NR | NR | NR | 0 | 9 | 71 | NR
Haid et al., 2004 USA (88) rhBMP2 Off-Label | Multicenter, nonblinded RCT | Single-level primary posterior lumbar interbody fusion | ICBG | 33 | 0 | NR | NR | NR | 0 | 15 | 12 (p <0.0001) | NR
Boden et al., 2002 USA (84) rhBMP2 Off-Label | Multicenter nonblinded RCT | Single-level primary instrumented posterolateral lumbar fusion | rhBMP2/BCP | 11 | 40 | NR | NR | NR | 4.5 | NR | NR | NR
Boden et al., 2002 USA (84) rhBMP2 Off-Label | Multicenter nonblinded RCT | Single-level primary instrumented posterolateral lumbar fusion | rhBMP2/BCP | 11 | 40 | NR | NR | NR | 4.5 | NR | NR | NR
Boden et al., 2002 USA (84) rhBMP2 Off-Label | Multicenter nonblinded RCT | Single-level primary instrumented posterolateral lumbar fusion | ICBG | 5 | 0 | NR | NR | NR | 0 | NR | NR | NR
Burkus et al., 2005 USA (85) rhBMP2 Off-Label | Multicenter nonblinded RCT | Single-level primary anterior lumbar fusion | rhBMP2 | 79 | 8–12 | NR | NR | NR | 0 | 9 | NR | NR
Burkus et al., 2005 USA (85) rhBMP2 Off-Label | Multicenter nonblinded RCT | Single-level primary anterior lumbar fusion | ICBG | 52 | 0 | NR | NR | NR | 0 | 8 | NR | NR
Baskin et al., 2003 USA (89) rhBMP2 Off-Label | Multicenter, nonblinded RCT | Single- or two-level primary instrumented ACDF with rhBMP2 | rhBMP2/ALG | 18 | 0.6–1.2 | NR | NR | NR | NR | 6 | NR | NR
Baskin et al., 2003 USA (89) rhBMP2 Off-Label | Multicenter, nonblinded RCT | Single- or two-level primary instrumented ACDF with rhBMP2 | ICBG/ALG | 16 | 0 | NR | NR | NR | NR | 6 | NR | NR
Butterman et al., 2008 USA (104) rhBMP2 Off-Label | Prospective nonrandomized cohorts of consecutive patients | Single- or multi-level primary instrumented or uninstrumented ACDF | rhBMP2/CRA | 30 | 0.9–3.7 | 50 | NR | NR | NR | NR | NR | NR
Butterman et al., 2008 USA (104) rhBMP2 Off-Label | Prospective nonrandomized cohorts of consecutive patients | Single- or multi-level primary instrumented or uninstrumented ACDF | ICBG | 36 | 0 | 14 (p<0.01) | NR | NR | NR | NR | NR | NR
Smucker et al., 2006 USA (106) rhBMP2 Off-Label | Retrospective case-control | Single- or multi-level instrumented ACDF | rhBMP2/CRA | 69 | NR | 28 | NR | 7 | NR | NR | NR | NR
Smucker et al., 2006 USA (106) rhBMP2 Off-Label | Retrospective case-control | Single- or multi-level instrumented ACDF | CRA | 165 | | 4 (p <0.0001) | NR | 1 | NR | NR | NR | NR
Vaidya et al., 2007 USA (107) rhBMP2 Off-Label | Retrospective cohorts of consecutive patients | Single- or multi-level primary instrumented ACDF | rhBMP2 | 22 | 1–3 | 100 | NR | 85 | NR | NR | NR | NR
Vaidya et al., 2007 USA (107) rhBMP2 Off-Label | Retrospective cohorts of consecutive patients | Single- or multi-level primary instrumented ACDF | ALG/DBM | 24 | 0 | 100 | NR | 39 (p=0.0092) | NR | NR | NR | NR
Friedlander et al., 2001 USA (79) rhBMP7 On-Label | Multicenter, partially blinded RCT | IM rod fixation | rhBMP7/BCC | 61 | 3.5–7.0 | NR | NR | NR | 10 | 5 | NR | NR
Friedlander et al., 2001 USA (79) rhBMP7 On-Label | Multicenter, partially blinded RCT | IM rod fixation | AGB | 61 | 0 | NR | NR | NR | 0 | 0 | NR | NR
Vaccaro et al., 2008 USA (94) rhBMP7 Off-Label | Multicenter, nonblinded RCT | Single-level primary uninstrumented posterolateral lumbar fusion | rhBMP7 | 207 | 7 | NR | NR | NR | 26 | NR | NR | NR
Vaccaro et al., 2008 USA (94) rhBMP7 Off-Label | Multicenter, nonblinded RCT | Single-level primary uninstrumented posterolateral lumbar fusion | ICBG | 86 | 0 | NR | NR | NR | 1 | NR | NR | NR
Jones et al., 2006 USA (90) rhBMP2 Off-Label | Multi-center prospective RCT | Reconstruction of diaphyseal tibial fractures with cortical defect | rhBMP2/ALG | 15 | 12 | NR | NR | NR | 0 | 6.7 | NR | NR
Jones et al., 2006 USA (90) rhBMP2 Off-Label | Multi-center prospective RCT | Reconstruction of diaphyseal tibial fractures with cortical defect | AGB | 15 | 0 | NR | NR | NR | 0 | 27 | NR | NR
Ekrol et al., 2008 UK (97) rhBMP7 Off-Label | Prospective randomized cohort | Osteotomy of the distal radius for symptomatic malunion (with and without external fixation) | rhBMP7 | 4 | NR | NR | NR | NR | NR | NR | NR | 0
Ekrol et al., 2008 UK (97) rhBMP7 Off-Label | Prospective randomized cohort | Osteotomy of the distal radius for symptomatic malunion (with and without external fixation) | AGB | 6 | NR | NR | NR | NR | NR | NR | NR | 0
Ekrol et al., 2008 UK (97) rhBMP7 Off-Label | Prospective randomized cohort | Osteotomy of the distal radius for symptomatic malunion (with and without external fixation) | rhBMP7 external fixation | 10 | NR | NR | NR | NR | NR | NR | NR | 10
Ekrol et al., 2008 UK (97) rhBMP7 Off-Label | Prospective randomized cohort | Osteotomy of the distal radius for symptomatic malunion (with and without external fixation) | AGB external fixation | 10 | NR | NR | NR | NR | NR | NR | NR | 0
Ristiniemi et al., 2007 Finland (110) rhBMP7 Off-Label | Retrospective cohort of matched patients | Distal tibial fracture | rhBMP7 | 20 | 3.5–7 | NR | NR | NR | NR | NR | NR | 5
Ristiniemi et al., 2007 Finland (110) rhBMP7 Off-Label | Retrospective cohort of matched patients | Distal tibial fracture | External fixation | 20 | NR | NR | NR | NR | NR | NR | NR | 0
Boraiah et al., 2009 USA (108) rhBMP2 Off-Label | Retrospective case series | Acute traumatic tibial plateau fractures | rhBMP2/ALG DBM/CaP | 17 | 12 | NR | NR | NR | NR | NR | 59 | NR
Boraiah et al., 2009 USA (108) rhBMP2 Off-Label | Retrospective case series | Acute traumatic tibial plateau fractures | ALG/DBM/CaP | 23 | 0 | NR | NR | NR | NR | NR | 4 (p <0.001) | NR

Abbreviations: AGB: autograft bone; ALG: allograft bone; BCP: biphasic calcium phosphate; CaP: calcium phosphate; CRA: cortical ring allograft; CRM: compression-resistant matrix; DBM: demineralized bone matrix; ICBG: iliac crest bone graft; IM: intramedullary; mos.: months; no.: number; NR: not reported; pt(s); patient(s); RCT: randomized, controlled trial;

#### Summary of Evidence from Noncomparative On- and Off-Label Studies Reporting BMP-related Harms

Fourteen noncomparative studies describe specific harms attributable to the off-label use of rhBMP2 or rhBMP7 (total rhBMP N=463) with an incidence ranging from 2 to 100 percent. Six reports of heterotopic bone formation were found, two using rhBMP7 and four using rhBMP2 of varied doses.114,134,138,148,150,158 Four of these were lumbar studies, the fifth158 was a femur study and the sixth a humeral non-union study.155

Ectopic bone formation occurred in two studies of rhBMP2.^139,186^

Dysphagia was reported in five rhBMP2 studies113,114,116,119,125 (N=260) with varying degrees of severity. Four were cervical spine studies113,114,119,125 and the fifth was a lumbar spine study.116

A case report of a patient undergoing a TLIF with rhBMP2 and autograft had a systemic immune response after treatment.147 Subsequent treatment of a revision surgery resulted in an increased response to the re-exposure of rhBMP2.

Because of the noncomparative design of these studies, it is not possible to strictly associate the use of a BMP device with an adverse event.

#### Autograft Donor Site Harms Reported in Comparative Studies

Table 37 shows a summary of harms reported at the autograft donor site in comparative BMP studies. As shown in Table 37, among 41 studies in this technology assessment, 20 (43 percent) reported the occurrence of donor site harms.

The body of evidence suggests that autograft bone harvest is associated with pain at the harvest site, but it is not possible to systematically assess the frequency, duration, and clinical significance. Overall, autograft harms were inconsistently reported. It is not clear that the absence of reported harms in many studies reflects true absence, or whether the investigators did not seek such data or did not report it.

Seven of 10 (70 percent) lumbar fusion studies72,73,86–88,92,95,100,182 reported pain at some point following surgery, four (40 percent) reported infection at the donor site72,73,86,182 , one reported the occurrence of hematoma.88

Two of three (67 percent) cervical fusion studies89,104 reported pain at the donor site, two (67 percent) reported infection.104,105

Three of 3 (100 percent) maxillofacial studies75,77,91 reported pain at autograft donor sites, one reported rash and edema.75

Among the other four studies, pain was reported in two96,97 (50 percent), infection in one83 (25 percent), with other events in three.83,90,97

Detailed information on these harms is reported in Appendix 4 Tables B and C.

Table 37 Autograft Donor Site Harms Reported in Comparative Studies

Study | Design | Comparison | No. Patients | Clinical Setting | Pain | Infection | Other
Dawson et al., 2009; USA (73) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | rhBMP2/BCP | 25 | Single-level primary instrumented posterolateral lumbar fusion | | x
Dawson et al., 2009; USA (73) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | ICBG | 21 | Single-level primary instrumented posterolateral lumbar fusion | | x
Burkus et al., 2003; USA (182) Lumbar-Sacral Fusion | Retrospective combined comparative analysis | rhBMP2 | 277 | Single-level primary anterior lumbar fusion with interbody fusion cages | x (32% at 2 years) | x
Burkus et al., 2003; USA (182) Lumbar-Sacral Fusion | Retrospective combined comparative analysis | ICBG | 402 | Single-level primary anterior lumbar fusion with interbody fusion cages | x (32% at 2 years) | x
Burkus et al., 2002; USA (72) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | rhBMP2 | 143 | Single-level primary anterior lumbar fusion with interbody fusion cages | x (32% at 2 years) | x
Burkus et al., 2002; USA (72) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | ICBG | 136 | Single-level primary anterior lumbar fusion with interbody fusion cages | x (32% at 2 years) | x
Dimar et al., 2009; USA (86) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | rhBMP2/BCP | 239 | Single-level primary instrumented posterolateral lumbar fusion | x | x
Dimar et al., 2009; USA (86) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | ICBG | 224 | Single-level primary instrumented posterolateral lumbar fusion | x | x
Glassman et al., 2008; USA (87) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | rhBMP2 | 50 | Single- or multi-level primary instrumented posterolateral lumbar fusion
Glassman et al., 2008; USA (87) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | ICBG | 52 | Single- or multi-level primary instrumented posterolateral lumbar fusion
Haid et al., 2004; USA (88) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | rhBMP2 | 34 | Single-level primary posterior lumbar interbody fusion with interbody fusion cages | x | | hematoma
Haid et al., 2004; USA (88) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | ICBG | 33 | Single-level primary posterior lumbar interbody fusion with interbody fusion cages | x | | hematoma
Mummaneni et al., 2004; USA (100) Lumbar-Sacral Fusion | Retrospective single-center cohort study | rhBMP2/AGB | 25 | Single- or multi-level primary transforaminal lumbar interbody fusion with interbody fusion cages | x (58% at 6 mos.)
Mummaneni et al., 2004; USA (100) Lumbar-Sacral Fusion | Retrospective single-center cohort study | ICBG | 19 | Single- or multi-level primary transforaminal lumbar interbody fusion with interbody fusion cages | x (58% at 6 mos.)
Vaccaro et al., 2008; USA (94) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | rhBMP7 | 207 | Single-level primary uninstrumented posterolateral lumbar fusion | x (45% at 2 years)
Vaccaro et al., 2008; USA (94) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | ICBG | 86 | Single-level primary uninstrumented posterolateral lumbar fusion | x (45% at 2 years)
Vaccaro et al., 2008; USA (95) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | rhBMP7 | 24 | Single-level primary uninstrumented posterolateral lumbar fusion
Vaccaro et al., 2008; USA (95) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | ICBG | 12 | Single-level primary uninstrumented posterolateral lumbar fusion
Johnsson et al., 2002; Sweden (92) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | rhBMP7 | 10 | Single-level primary uninstrumented posterolateral lumbar fusion | x
Johnsson et al., 2002; Sweden (92) Lumbar-Sacral Fusion | Multicenter nonblinded RCT | ICBG | 10 | Single-level primary uninstrumented posterolateral lumbar fusion | x
Crawford et al., 2009; USA (105) Cervical Fusion | Retrospective cohort of consecutive patients | rhBMP2/BGE | 41 | Single- or multi-level instrumented posterior cervical spinal fusion | | x
Crawford et al., 2009; USA (105) Cervical Fusion | Retrospective cohort of consecutive patients | ICBG | 36 | Single- or multi-level instrumented posterior cervical spinal fusion | | x
Butterman et al., 2008; USA (104) Cervical Fusion | Prospective nonrandomized cohorts of consecutive patients | rhBMP2/CRA | 30 | Single- or multiple-level cervical ACDF | x | x
Butterman et al., 2008; USA (104) Cervical Fusion | Prospective nonrandomized cohorts of consecutive patients | ICBG | 36 | Single- or multiple-level cervical ACDF | x | x
Baskin et al., 2003; USA (89) Cervical Fusion | Multicenter nonblinded RCT | rhBMP2/ALG | 18 | Single- or two-level primary instrumented ACDF | x
Baskin et al., 2003; USA (89) Cervical Fusion | Multicenter nonblinded RCT | ICBG/ALG | 15 | Single- or two-level primary instrumented ACDF | x
Dickinson et al., 2008; USA (91) Maxillofacial Procedures | Single-center RCT | rhBMP2 | 9 | Repair of unilateral cleft lip-palate with an alveolar cleft defect | x (25% at 6 mos.)
Dickinson et al., 2008; USA (91) Maxillofacial Procedures | Single-center RCT | ICBG | 12 | Repair of unilateral cleft lip-palate with an alveolar cleft defect | x (25% at 6 mos.)
Boyne et al., 2005; USA (75) Maxillofacial Procedures | Multicenter randomized dose-comparison, safety and efficacy study | rhBMP2 | 18 | Staged bilateral or unilateral maxillary sinus floor augmentation | x | | rash, edema
Boyne et al., 2005; USA (75) Maxillofacial Procedures | Multicenter randomized dose-comparison, safety and efficacy study | rhBMP2 | 17 | Staged bilateral or unilateral maxillary sinus floor augmentation | x | | rash, edema
Boyne et al., 2005; USA (75) Maxillofacial Procedures | Multicenter randomized dose-comparison, safety and efficacy study | AGB | 13 | Staged bilateral or unilateral maxillary sinus floor augmentation | x | | rash, edema
Triplett et al., 2009; USA (77) Maxillofacial Procedures | Multicenter nonblinded RCT | rhBMP2/ACS | 80 | Staged bilateral or unilateral maxillary sinus floor augmentation | x
Triplett et al., 2009; USA (77) Maxillofacial Procedures | Multicenter nonblinded RCT | AGB | 80 | Staged bilateral or unilateral maxillary sinus floor augmentation | x
Jones et al., 2006; USA (90) Miscellaneous Uses | Multicenter prospective RCT | rhBMP2/ALG | 15 | Reconstruction of diaphyseal tibial fractures with cortical defect | x (93% at 4.5 mos.) | | pustules, drainage
Jones et al., 2006; USA (90) Miscellaneous Uses | Multicenter prospective RCT | AGB | 15 | Reconstruction of diaphyseal tibial fractures with cortical defect | x (93% at 4.5 mos.) | | pustules, drainage
Bilic et al., 2006 Croatia, Netherlands (96) Miscellaneous Uses | Single-center unblinded RCT | rhBMP7/AGB | 6 | Revision of non-union | x (100% postop)
Bilic et al., 2006 Croatia, Netherlands (96) Miscellaneous Uses | Single-center unblinded RCT | rhBMP7/ALG | 6 | Revision of non-union | x (100% postop)
Bilic et al., 2006 Croatia, Netherlands (96) Miscellaneous Uses | Single-center unblinded RCT | ICBG | 6 | Revision of non-union | x (100% postop)
Ekrol et al., 2008; UK (97) Miscellaneous Uses | Prospective randomized cohort | rhBMP2/ext | 4 | Osteotomy of the distal radius for symptomatic malunion | | | hematoma
Ekrol et al., 2008; UK (97) Miscellaneous Uses | Prospective randomized cohort | AGB/ext fix | 6 | Osteotomy of the distal radius for symptomatic malunion | | | hematoma
Ekrol et al., 2008; UK (97) Miscellaneous Uses | Prospective randomized cohort | rhBMP2/int | 10 | Osteotomy of the distal radius for symptomatic malunion | | | hematoma
Ekrol et al., 2008; UK (97) Miscellaneous Uses | Prospective randomized cohort | AGB/int fix | 10 | Osteotomy of the distal radius for symptomatic malunion | | | hematoma
Dahabreh et al., 2008 UK, Italy (83) Miscellaneous Uses | Retrospective cohort study | rhBMP7/BCC | 15 | Open reduction internal fixation, exchange intramedullary nailing or Ilizarov | | x | abscess
Dahabreh et al., 2008 UK, Italy (83) Miscellaneous Uses | Retrospective cohort study | ICBG | 12 | Open reduction internal fixation, exchange intramedullary nailing or Ilizarov | | x | abscess

The symbol “x” in the study report means the harm occurred but numerical frequency was not reported

Abbreviations: ACS: absorbable collagen sponge; AGB: autograft bone; ALG: allograft bone; CRA: cortical ring allograft; CRM: compression-resistant matrix; DBM: demineralized bone matrix; ext fix: external fixation; ICBG: iliac crest bone graft; IM: intramedullary; int fix: internal fixation; mos.: months; no.: number; NR: not reported; pt(s); patient(s); postop: postoperative; RCT: randomized, controlled trial;

### Key Question 8 What is the quality of reporting of adverse events in publications? Provide summary to support conclusion

This question was addressed specifically with respect to BMP-specific harms in comparative studies, using a modification of the McHarms survey64 outlined in the Methods section of this technology assessment. The quality of reporting is summarized in Table 38; more specific information is compiled in Appendix 5 Tables A (on-label) and B (off-label).

The quality of reporting in the 41 comparative studies reviewed in this technology assessment is variable and inconsistent, in particular with respect to attribution of harms to BMP use and the use of standardized or validated instruments to collect harms.

Table 38 Summary of BMP-Specific Harms Reporting in Comparative Studies

A. On-Label Studies (n=13)
Study Type | Explanation of how harms identified (% studies) | Standard/valid instrument used (% studies) | Ascertainment similar in all groups (% studies) | Measure of severity reported (% studies) | Were harms attributed to intervention likely causally associated (% studies) | Were harms (# and type) reported separately for each study group (% studies)
Yes | 62 | 16 | 92 | 15 | 8 | 77
No | 38 | 62 | 8 | 85 | 69 | 23
Uncl/Unk | 0 | 23 | 0 | 0 | 23 | 0
Abbreviations: Uncl/Unk: Unclear/Unknown

B. Off-Label Studies (n=28)
Study Type | Explanation of how harms identified (% studies) | Standard/valid instrument used (% studies) | Ascertainment similar in all groups (% studies) | Measure of severity reported (% studies) | Were harms attributed to intervention likely causally associated (% studies) | Were harms (# and type) reported separately for each study group (% studies)
Yes | 54 | 7 | 68 | 4 | 21 | 64
No | 46 | 50 | 4 | 89 | 58 | 36
Uncl/Unk | 0 | 43 | 28 | 7 | 21 | 0
Abbreviations: Uncl/Unk: Unclear/Unknown

Overall, the quality of reporting on BMP-related harms amongst comparative studies was inconsistent. It also is not clear that the absence of reported harms in many studies reflects true absence, or that the investigators did not seek such data or did not report it.

### Key Question 9 What is the incremental cost effectiveness of the use of BMP for spinal fusion and open tibial fracture?

Our focus was to implement Markov models in cost-effectiveness analyses of the use of BMP in open tibial fracture and spinal fusion. Markov models allow an explicit examination of the impact of changes in health state probabilities over time. We were unable to identify any prior Markov-based cost-effectiveness analyses of these topics.

Garrison et al.26 reported two cost-effectiveness analyses for the U.K. National Health Service Health Technology Assessment Programme. The analyses, open tibial fracture and anterior lumbar interbody spinal fusion, had been performed by ABACUS International, a European consulting firm funded by a BMP manufacturer. The way in which ABACUS models calculated quality-adjusted life years (QALYs) is opaque and would be difficult to reproduce. A request to examine the MS Excel® files used by ABACUS before completion of this analysis was declined. A decision tree cost utility analysis was published by Carreon et al.,187 focusing on single or multilevel posterolateral lumbar spinal fusion, in contrast with single-level anterior lumbar interbody fusion. These articles served as an impetus for the present analyses.

#### Methods

Characteristics of our cost-effectiveness analysis are summarized in Table 39. Analyses were performed from a payer perspective. The specific perspective was that of the Centers for Medicaid and Medicare Services (CMS), as all cost estimates were payments by Medicare.

For the open tibial fracture (OTF) analysis, the relevant population is represented by patients selected for the “BMP2 Evaluation in Surgery for Tibial Trauma” (BESTT) randomized trial (Govender et al., 2002^74^). Such patients had open tibial shaft fractures within Gustilo-Anderson severity types I, II, IIIA and IIIB. The BESTT trial treatment group received intramedullary nail fixation and routine soft-tissue management (standard of care) plus an implant with either 0.75 mg/mL or 1.50 mg/mL of rhBMP2. This analysis only uses outcomes reported for the group receiving the higher dose. Control group patients received standard of care alone.

The spinal fusion (SF) analysis focused on the randomized trial by Burkus et al.72 Relevant patients are those with single-level degenerative lumbar disc disease and disabling symptoms of at least 6 months duration that had not responded to nonoperative treatments. The Burkus trial treatment group underwent open single-level anterior interbody lumbar fusion (ALIF), including an LT-Cage device filled with an absorbable collagen sponge infused with rhBMP2. Control patients had the same procedure with autogenous iliac crest bone graft instead of BMP.

Short time horizons were chosen based on limited follow-up evidence provided in the two randomized trials: 52 weeks (1 year) for open tibial fracture and 104 weeks (2 years) for spinal fusion.

Table 39 Cost-Effectiveness Analysis Characteristics

Characteristic | Description
Perspective | Payer (CMS; obtained cost estimates were payments by Medicare).
Population | OTF: The population reflects patient selection in the BMP2 Evaluation in Surgery for Tibial Trauma (BESTT) randomized trial (Govender et al., 2002). Such patients had open tibial shaft fractures within Gustilo-Anderson severity types I, II, IIIA and IIIB. SF: Based on the randomized trial by Burkus et al. [ref 72], relevant patients are those with single-level degenerative lumbar disc disease and disabling symptoms of at least 6 months duration that had not responded to nonoperative treatments.
Strategies | OTF: The BESTT trial treatment group received intramedullary nail fixation and routine soft-tissue management (standard of care) plus an implant with either 0.75 mg/mL or 1.50 mg/mL of rhBMP2. This analysis uses outcomes reported for the group receiving the higher dose. Control group patients received standard of care alone. SF: The Burkus trial treatment group underwent open single-level anterior interbody lumbar fusion (ALIF), including an LT-CAGE device filled with an absorbable collagen sponge infused with rhBMP2. Control patients had the same procedure with autogenous iliac crest bone graft instead of BMP.
Time Horizon | Short time horizons were chosen based on limited follow-up evidence provided in the two randomized trials: 52 weeks (1 year) for OTF and 104 weeks (2 years) for SF.
Type of Model | For both analyses, stationary Markov models were used (constant transition probabilities) with a cycle length of one week. OTF: There were three health states for both treatment and control groups: preunion, secondary intervention and union. SF: There were three states for the treatment group: prefusion, secondary intervention and fusion. The control group had six health states, the same three states as the treatment group, combined with bone graft donor site pain (DSP) or no DSP. Minimum time to both union and fusion was assumed to be six weeks.
Modeling Details | MS Excel was the main software program. Analyses used two approaches producing identical results: 1) area partitioned by separate exponential survival curves for health states and 2) cohort simulations (see transition probability matrices). Engauge Digitizer software was used to create area calibration sources for time to union for OTF and time to fusion and time to resolved DSP for SF. Model hazard rates were adjusted until follow-up area matched that from calibration sources. Having a secondary intervention was treated as a temporary state lasting one week; area spent in this state was calculated as the proportion of individuals having secondary interventions divided by the total number of weeks past the minimum time to union (n=46) or fusion (n=98).
Included Costs | Analyses included direct health care costs reported as Medicare payments from free publicly available sources, valued in 2007 US dollars. Cost categories included initial hospitalization (hospital and physician costs) and secondary interventions (hospital/outpatient surgical center and physician costs). In separate analyses, BMP was treated as a bundled part of DRG payments and as a separate added payment amount. Secondary intervention costs were identified for specific subcategories of procedures: for OTF, most invasive (bone graft, exchange nailing, plate fixation, fibular osteotomy or bone transport) versus less invasive (nail dynamization or exchange from internal fixation to functional brace) and for SF, removals, supplemental fixations and reoperations. A noninvasive category reported in the OTF trial was not included in this analysis because only two patients were represented. Indirect costs were excluded.
Effectiveness Metric/Analytic Output | Quality-adjusted life-year (QALY) is the effectiveness metric. The key analytic output is the incremental cost-effectiveness ratio (ICER), calculated as the difference in total costs between treatment and control divided by the between-group difference in QALYs.
Discounting | Given the short time horizons, discounting was not used for either costs or utilities.
Sensitivity Analyses | Both OTF and SF: BMP added to costs Utilities Non-BMP costs Secondary intervention costs Hazard ratio of rates of achieving union/fusion Risk ratio of having secondary interventions BMP costs SF only Probability of DSP in control patients Disutility of health states with DSP

Abbreviations: OTF: open tibial fracture; SF: spinal fusion;

For both analyses, stationary Markov models were used (constant transition probabilities) with a cycle length of one week. In the open tibial fracture analysis, there were three health states for both treatment and control groups: preunion, secondary intervention, and union (Figure 1). In the spinal fusion analysis, there were three states for the treatment group: prefusion, secondary intervention and fusion. The control group had six health states, the same three states as the treatment group, combined with bone graft donor site pain (DSP) or no donor site pain (Figure 2). For both analyses, the minimum time to both union and fusion was assumed to be six weeks.

Analyses were carried out with Microsoft Excel®. Two modeling approaches produced identical results: 1) area partitioned by separate exponential survival curves for health states and 2) cohort simulations. Engauge Digitizer software was used to create area calibration sources for time to union for open tibial fracture as well as time to fusion and time to resolved bone graft donor site pain among control group patients for spinal fusion.

Tables 40A–C provides utility and outcome parameter estimates for the open tibial fracture analysis. Open tibial fracture utility values were obtained from a study by Sprague and Bhandari188 on treatment of closed tibial fracture and were based on expert opinion. Sensitivity analyses were performed with utilities 25 percent lower or 25 percent higher than base case values, with a limit of 0.99 for the highest valued state.

A rate of fracture healing graph reported by Govender et al.(BESTT trial74) was processed by Engauge Digitizer software to derive probability estimates of union at the six observed follow-up points. These probabilities allowed creation of curves by Microsoft Excel®. The Excel® curves were then digitized to give derived probability estimates at all points from 6 to 52 weeks. Derived probability estimates were used to create area calibration sources for partitioning follow-up area for preunion and union by the Markov model. Model hazard rates were adjusted until partitioned areas matched the calibration source. Transition probability matrices for open tibial fracture treatment and control are shown in Table 41.

For both open tibial fracture and spinal fusion, having a secondary intervention was treated as a temporary state lasting one week; area spent in this state was calculated as the proportion of individuals having secondary interventions divided by the total number of weeks past the minimum time to union (46 weeks) or fusion (98 weeks). These values served as area calibration sources for modeling this health state.

In the spinal fusion analysis (Table 42), utility values for the prefusion without donor site pain and fusion without donor site pain health states were based on preoperative and 6 month unpublished data collected by Burkus et al.72,182 and described in Garrison et al.26 SF-36 data from treatment and control patients were transformed into utilities using the Brazier et al.189 index. Treatment and control utilities cited by the Garrison analysis26 were similar, although this analysis assumes a 0.02 disutility among control patients for states involving donor site pain. A sensitivity analysis is performed with a larger disutility value for donor site pain (0.05). The utility for intervention without donor site pain was estimated as 0.05 lower than the prefusion without donor site pain. Sensitivity analyses were conducted with utilities that were 25 percent lower and 25 percent higher than base case values.

Figure 1 Open Tibial Fracture Markov Model

Figure 1 is a Markov state-transition diagram depicting the health states and between-state transitions involved in the Markov model used in the open tibial fracture cost-effectiveness analysis. Both treatment and control patients begin in the preunion state and may transition to either the secondary intervention state or the union state. The model assumes that patients stay in the secondary intervention state for only one week and then return to the preunion state. The model also assumes that once patients enter the union state, they remain there.

Figure 2 Spinal Fusion Markov Model

Figure 2 is a Markov state-transition diagram depicting the health states and between-state transitions involved in the Markov model used in the spinal fusion cost-effectiveness analysis. It is assumed that treatment patients transition between three states without bone graft donor site pain (DSP): prefusion, secondary intervention and fusion. The model assumes for treatment patients that may transition from the prefusion state to either the secondary intervention state or the fusion state. The model assumes that patients stay in the secondary intervention state for only one week and then return to the prefusion state. The model also assumes that once patients enter the fusion state, they remain there. Control patients begin in the prefusion with DSP state. Additional transitions that control patients may make are to secondary intervention with DSP, fusion with DSP, prefusion without DSP and fusion without DSP. Otherwise, assumptions for control patients are the same as those for treatment patients.

Table 40 Utility and Outcome Parameter Estimates and Sources, Open Tibial Fracture

40A. Utility Estimates*
State | Utility | Source
Preunion | 0.60 | Sprague et al. 2002 [ref 188] (cited by Garrison et al. 2007[ref 26]), delayed union
Secondary intervention | 0.50 | Sprague et al. 2002 [ref 188] (cited by Garrison et al. 2007[ref 26]), postoperative complication
Union | 0.90 | Sprague et al. 2002 [ref 188] (cited by Garrison et al. 2007[ref 26]), returning to normal activities
*Sensitivity analysis was performed for all utilities either 25% lower or 25% higher

40B. Estimates of Probability of Union**
Week | Treatment % | Control %
10 | 14.9% | 6.9%
14 | 35.4% | 14.1%
20 | 51.8% | 27.7%
26 | 58.4% | 38.1%
39 | 66.3% | 48.7%
52 | 71.2% | 51.4%
**Source: Govender et al. 2002 (BESTT trial [ref 74]); rate of fracture healing graph was digitized to derive probability estimates at the follow-up points at left, curve created with these points by MS Excel, Excel curve digitized to give derived probability estimates at all points from 6 to 52 weeks. Derived probability estimates used to create area calibration source for partitioning follow-up area by Markov model. Derived hazard ratio (HR) for preunion state was 1.89. Arbitrary lower limit HR of 0.99 (treatment worse) was chosen, determining a comparably extreme counterpart value, in the log scale, of 3.61. Two intermediate HRs of 1.37 and 2.62 were also chosen.

40C. Risk Ratio of Probability of Secondary Intervention***
Group | # | n | % | Risk Ratio | RR 95% CI Lower | RR 95% CI Upper
Treatment | 30 | 135 | 22.2% | 0.533 | 0.367 | 0.772
Control | 58 | 139 | 41.7%
***Govender et al. 2002 (BESTT trial [ref 74]); area spent in secondary intervention state was calculated as the proportion of individuals having secondary interventions divided by the total number of weeks past the minimum time to union (n=46).

Table 41 Transition Probability Matrices, Open Tibial Fracture

41A. Transition Probability Matrices: Treatment
States | Preunion (S1) | Secondary Intervention (S2) | Union (S3)
Preunion (S1) | 0.962663205 | 0.000012754 | 0.037324041
Secondary Intervention (S2) | 0.0 | 0.962675959 | 0.037324041
Union (S3) | 0.0 | 0.0 | 1.0

41B. Transition Probability Matrices: Control
States | Preunion (S1) | Secondary Intervention (S2) | Union (S3)
Preunion (S1) | 0.980082713 | 0.000014956 | 0.019902331
Secondary Intervention (S2) | 0.0 | 0.980097669 | 0.019902331
Union (S3) | 0.0 | 0.0 | 1.0

Table 42 Utility and Outcome Parameter Estimates and Sources, Spinal Fusion

42A. Utility Estimates*
State | Utility | Source
S1 Prefusion w/o donor site pain (DSP) | 0.54 | Garrison et al. 2007 [ref 36], from Burkus unpublisheddata, SF-36 Brazier index, preoperative mean
S2 Prefusion w/ DSP | 0.52 | S1 reduced by 0.02
S3 Secondary Intervention w/o DSP | 0.49 | S1 reduced by 0.05
S4 Secondary Intervention w/ DSP | 0.47 | S3 reduced by 0.02
S5 Fusion w/ DSP | 0.60 | S6 reduced by 0.02
S6 Fusion w/o DSP | 0.62 | Garrison et al. 2007 [ref 26], from Burkus unpublisheddata, SF-36 Brazier index, 6 month mean
*Disutility associated with DSP assumed to be 0.02 for all three key health states (prefusion, secondary intervention and fusion).
Sensitivity analysis also performed for larger disutility magnitude (0.05), and all utilities either 25% lower or 25% higher.

42B. Estimates of Radiographic Fusion Success
Group | 6-month Radiographic Fusion Success | 12-month Radiographic Fusion Success | 24-month Radiographic Fusion Success
Treatment | 128/132 (97.0%) | 127/131 (96.9%) | 120/127 (94.5%)
Control | 115/120 (95.8%) | 112/121 (92.6%) | 102/115 (88.7%)
Source: Burkus et al. 2002 randomized trial; prefusion probabilities derived from radiographic fusion success probabilities, prefusion area between 6 weeks and 6 months estimated with exponential survival curves matched on observed 6 month fusion probabilities. Exponential curves were combined with linearly interpolated areas between 6 and 24 months to produce area calibration sources for partitioning follow-up area by Markov models. Derived hazard ratio (HR) for prefusion state was 1.45. Arbitrary lower limit HR of 0.99 (treatment worse) was chosen, determining a comparably extreme counterpart value, in the log scale, of 2.13. Two intermediate HRs of 1.20 and 1.76 were also chosen.

42C. Estimates of Donor-Site Pain
Week | Donor-Site Pain
0 | 100%
6 | 83%
13 | 56%
26 | 43%
52 | 35%
104 | 32%
Source: Burkus et al. 2002 [ref 72] randomized trial; probabilities of donor site pain (DSP) observed at the follow-up times at left used to create curve by MS Excel®, Excel® curve digitized to give derived probability estimates at all points from 6 to 104 weeks. Derived probability estimates used to create area calibration source for partitioning by Markov model. Area spent in DSP state in calibration source was 41.7%. This fraction was applied to pairs of health states with and without DSP (e.g., prefusion with DSP, prefusion without DSP). The exact binomial 95% confidence limits of that proportion (31.3%, 52.1%) were used in sensitivity analysis.

42D. Risk Ratio of Probability of Intervention
| # | n | % | Risk Ratio | RR 95% CI Lower | RR 95% CI Upper
Treatment | 18 | 143 | 12.6% | 0.9510 | 0.5169 | 1.7498
Control | 18 | 136 | 13.2%
Source: Burkus et al. 2002 [ref 72] trial; area spent in secondary intervention state calculated as the proportion of individuals having secondary interventions divided by the number of weeks past the minimum time to fusion (n=98).

Prefusion probabilities were derived from clinical and radiographic fusion success probabilities reported by the Burkus et al.72 randomized trial. The prefusion area between 6 weeks and 6 months was estimated with exponential survival curves intersecting observed 6 month fusion probabilities. Exponential curves were combined with linearly interpolated areas between 6 and 24 months to produce area calibration sources for partitioning follow-up area by Markov models. Probabilities of donor site pain observed at the six observed follow-up times were used to create a curve by Microsoft Excel®; The Excel curve was digitized to give derived probability estimates at all points from 6 to 104 weeks. Derived probability estimates were used to create area calibration sources for partitioning by the Markov model. Area spent in the donor site pain state in the calibration source was 41.7 percent. This fraction was applied to pairs of health states with and without donor site pain (e.g., prefusion with DSP, prefusion without DSP). Transition probability matrices for spinal fusion treatment and control are shown in Table 43.

Analyses included direct health care costs reported as Medicare payments from free publicly available sources, valued in 2007 U.S. dollars (Tables 44–49). Cost categories included initial hospitalization (hospital and physician costs) and secondary interventions (hospital/outpatient surgical center and physician costs). It was assumed that initial hospitalization was paid according to the diagnosis-related groups (DRG) system. Thus, base case analyses assume identical initial hospitalization costs whether BMP was used or not. In separate analyses, BMP was treated as a bundled part of DRG payments and as a separate added payment amount. Approximate cost of BMP was based on two published sources: $3,000^190^ and $5,000^191^, serving as the base case (mean) and upper value, respectively. A lower value of $1,000 and an extreme high value of $8,000 were also used for sensitivity analyses.

Secondary intervention costs were identified for specific subcategories of procedures: for open tibial fracture, most invasive (bone graft, exchange nailing, plate fixation, fibular osteotomy or bone transport) versus less invasive (nail dynamization or exchange from internal fixation to functional brace) and for spinal fusion, removals, supplemental fixations and reoperations. A noninvasive subcategory reported in the open tibial fracture trial was not included in this analysis because only two patients were represented. Costs for secondary interventions were calculated as weighted averages based on specific type of secondary intervention and proportions of type for both treatment and control groups. Indirect costs were excluded.

The quality-adjusted life-year (QALY) is the effectiveness metric. The key analytic output is the incremental cost-effectiveness ratio (ICER), calculated as the difference in total costs between treatment and control divided by the between-group difference in QALYs. The ICER is interpreted as the additional cost incurred to attain one additional QALY by choosing treatment over control. Given the short time horizons, discounting was not used for either costs or utilities.

Sensitivity analyses were performed for both open tibial fracture and spinal fusion for these variables: BMP added to costs, utilities, non-BMP costs, secondary intervention costs, the hazard ratio of rates of achieving union/fusion, risk ratio of having secondary interventions, and BMP costs. Additional sensitivity analyses for spinal fusion were performed on the probability of donor site pain in control patients, and the disutility of health states with donor site pain. One-way and selected two-way and three-way sensitivity analyses were performed.

Table 43 Transition Probability Matrices, Spinal Fusion

43A. Transition Probability Matrices: Treatment
States | Prefusion without donor-site pain (S1) | Secondary intervention without donor-site pain (S3) | Fusion without donor site pain (S6)
Prefusion without donor-site pain (S1) | 0.8901701 | 0.0000155 | 0.1098144
Secondary intervention without donor-site pain (S3) | 0.0 | 0.8901856 | 0.1098144
Fusion without donor site pain (S6) | 0.0 | 0.0 | 1.0

43B. Transition Probability Matrices: Control
States | Prefusion without donor-site pain (S1) | Prefusion with donor- site pain (S2) | Secondary intervention without donor-site pain (S3) | Secondary intervention with donor- site pain (S4) | Fusion with donor-site pain (S5) | Fusion without donor-site pain (S6)
Prefusion without donor-site pain (S1) | 0.8747582 | 0.0482304 | 0.0000047 | 0.0000033 | 0.0604576 | 0.0165458
Prefusion with donor-site pain (S2) | 0.0 | 0.9229886 | 0.0000047 | 0.0000033 | 0.0604576 | 0.0165458
Secondary intervention without donor-site pain (S3) | 0.0 | 0.0 | 0.9229933 | 0.0000033 | 0.0604576 | 0.0165458
Secondary intervention with donor-site pain (S4) | 0.0 | 0.0 | 0.0 | 0.9229966 | 0.0604576 | 0.0165458
Fusion with donor-site pain (S5) | 0.0 | 0.0 | 0.0 | 0.0 | 0.9834542 | 0.0165458
Fusion without donor-site pain (S6) | 0.0 | 0.0 | 0.0 | 0.0 | 0.0 | 1.0

Table 44 Cost Parameter Estimates and Sources, Open Tibial Fracture

Procedure Type | Code Type | Code | Data Source | Cost Category | Mean | 95CIL | 95CIU
Internal fixation (initial) | DRG | 218 | HCUPnet Nationwide Inpatient Sample | Hospital | 12,914 | 12,482 | 13,345
Internal fixation (initial) | DRG | 219 | HCUPnet Nationwide Inpatient Sample | Hospital | 9,164 | 8,729 | 9,598
Internal fixation (initial) | DRG | 218+219 | HCUPnet Nationwide Inpatient Sample | Hospital | 11,487 | 11,055 | 11,920
Internal fixation (initial) | CPT | 27759 | CMS National Payment Amount-Physician Fee Schedule | Physician | 959 | 941 | 976
Internal fixation (initial) | | | | Hosp+MD | 12,446 | 11,996 | 12,896
BMP (initial) | | | Polly et al. (2003), Glassman et al. (2008) | Supplier | 3,000 | 1,000 | 5,000
Bone graft (secondary) | CPT | 20900 | CMS Outpatient Prospective Payment System | Hospital | 3,941 | 3,763 | 4,119
Bone graft (secondary) | CPT | 20900 | CMS National Payment Amount-Physician Fee Schedule | Physician | 564 | 552 | 577
Bone graft (secondary) | | | | Hosp+MD | 4,505 | 4,314 | 4,696
Exchange nailing (secondary) | CPT | 27759 | CMS Outpatient Prospective Payment System | Hospital | 4,690 | 4,366 | 5,014
Exchange nailing (secondary) | CPT | 27759 | CMS National Payment Amount-Physician Fee Schedule | Physician | 959 | 941 | 976
Exchange nailing (secondary) | | | | Hosp+MD | 5,648 | 5,307 | 5,990
Plate fixation (secondary) | CPT | 27758 | CMS Outpatient Prospective Payment System | Hospital | 3,513 | 3,076 | 3,951
Plate fixation (secondary) | CPT | 27758 | CMS National Payment Amount-Physician Fee Schedule | Physician | 842 | 826 | 857
Plate fixation (secondary) | | | | Hosp+MD | 4,355 | 3,902 | 4,808
Fibular osteotomy (secondary) | CPT | 27707 | CMS Outpatient Prospective Payment System | Hospital | 2,023 | 1,873 | 2,173
Fibular osteotomy (secondary) | CPT | 27707 | CMS National Payment Amount-Physician Fee Schedule | Physician | 373 | 366 | 381
Fibular osteotomy (secondary) | | | | Hosp+MD | 2,396 | 2,238 | 2,554
Bone transport (secondary) | CPT | 20692 | CMS Outpatient Prospective Payment System | Hospital | 6,869 | 6,408 | 7,330
Bone transport (secondary) | CPT | 20692 | CMS National Payment Amount-Physician Fee Schedule | Physician | 398 | 391 | 405
Bone transport (secondary) | | | | Hosp+MD | 7,267 | 6,799 | 7,735
Nail dynamization (secondary) | CPT | 27750 | CMS Outpatient Prospective Payment System | Hospital | 159 | 130 | 189
Nail dynamization (secondary) | CPT | 27750 | CMS National Payment Amount-Physician Fee Schedule | Physician | 310 | 303 | 317
Nail dynamization (secondary) | | | | Hosp+MD | 470 | 434 | 506
Internal fixation to brace (secondary) | CPT | 27750 | CMS Outpatient Prospective Payment System | Hospital | 159 | 130 | 189
Internal fixation to brace (secondary) | CPT | 27750 | CMS National Payment Amount-Physician Fee Schedule | Physician | 310 | 303 | 317
Internal fixation to brace (secondary) | | | | Hosp+MD | 470 | 434 | 506

Table 45 Procedure Code Descriptions for Cost Parameter Estimates, Open Tibial Fracture

Procedure Type | DRG Code | Description | CPT Code | Description
Initial | 218 | Lower extremity & humerus procedure except hip, foot, femur with complications or comorbidities | 27759 | Treatment of tibial shaft fracture (with or without fibular fracture) by intramedullary implant, with or without interlocking screws and/or cerclage
Initial | 219 | Lower extremity & humerus procedure except hip, foot, femur without complications or comorbidities | 27759 | Treatment of tibial shaft fracture (with or without fibular fracture) by intramedullary implant, with or without interlocking screws and/or cerclage
Secondary: bone graft | | | 20900 | Bone graft, any donor area; minor or small (e.g., dowel or button)
Secondary: exchange nailing | | | 27759 | Treatment of tibial shaft fracture (with or without fibular fracture) by intramedullary implant, with or without interlocking screws and/or cerclage
Secondary: plate fixation | | | 27758 | Open treatment of tibial shaft fracture, (with or without fibular fracture) with plate/screws, with or without cerclage
Secondary: fibular osteotomy | | | 27707 | Osteotomy; fibula
Secondary: bone transport | | | 20692 | Application of a multiplane (pins or wires in more than 1 plane), unilateral, external fixation system (e.g., Ilizarov, Monticelli type)
Secondary: nail dynamization | | | 27750 | Closed treatment of tibial shaft fracture (with or without fibular fracture); without manipulation
Secondary: internal fixation to brace | | | 27750 | Closed treatment of tibial shaft fracture (with or without fibular fracture); without manipulation

Table 46 Calculation of Secondary Intervention Costs, Open Tibial Fracture

46A. Costs of Secondary Intervention
Secondary Intervention | Mean | Lower | Upper
Mean most invasive | 4,834 | 4,512 | 5,157
Mean less invasive | 470 | 434 | 506

46B. Secondary Intervention Rates, Treatment
Component | # | %
Treatment most invasive | 12 | 40.0%
Treatment less invasive | 18 | 60.0%
Total | 30

46C. Weighted Average, Treatment
Weighted Average | Mean | Lower | Upper
Treatment | 2,216 | 2,065 | 2,366

46D. Secondary Intervention Rates, Control
Component | # | %
Control, most invasive | 29 | 50.0%
Control, less invasive | 29 | 50.0%
Total | 58

46E. Weighted Average, Control
Weighted Average | Mean | Lower | Upper
Control weighted average | 2,652 | 2,473 | 2,831

Table 47 Cost Parameter Estimates and Sources, Spinal Fusion

Procedure Type | Code Type | Code | Data Source | Cost Category | Mean | 95CIL | 95CIU
Spinal fusion (initial) | DRG | 497 | HCUPnet Nationwide Inpatient Sample | Hospital | 29,104 | 27,823 | 30,385
Spinal fusion (initial) | DRG | 498 | HCUPnet Nationwide Inpatient Sample | Hospital | 23,997 | 22,993 | 25,000
Spinal fusion (initial) | DRG | 497+498 | HCUPnet Nationwide Inpatient Sample | Hospital | 27,071 | 25,901 | 28,242
Spinal fusion (initial) | CPT | 22558 | CMS National Payment Amount-Physician Fee Schedule | Physician | 1,410 | 1,386 | 1,433
Spinal fusion (initial) | | | | Hosp+MD | 28,481 | 27,287 | 29,675
BMP (initial) | | | Polly et al. (2003 [ref 190]), Glassman et al. (2008 [ref 191]) | Supplier | 3,000 | 1,000 | 5,000
Reoperation (secondary) | DRG | 497+498 | HCUPnet Nationwide Inpatient Sample | Hospital | 27,071 | 25,901 | 28,242
Reoperation (secondary) | CPT | 22558 | CMS National Payment Amount-Physician Fee Schedule | Physician | 1,410 | 1,386 | 1,433
Reoperation (secondary) | | | | Hosp+MD | 28,481 | 27,287 | 29,675
Removal (secondary) | ICD-9-CM | 78.69 | HCUPnet Nationwide Inpatient Sample | Hospital | 11,035 | 9,596 | 12,474
Removal (secondary) | CPT | 22855 | CMS National Payment Amount-Physician Fee Schedule | Physician | 1,036 | 1,016 | 1,055
Removal (secondary) | | | | Hosp+MD | 12,071 | 10,612 | 13,530
Supplemental fixation (secondary) | ICD-9-CM | 84.82 | HCUPnet Nationwide Inpatient Sample | Hospital | 24,117 | 18,375 | 29,860
Supplemental fixation (secondary) | CPT | 22840 | CMS National Payment Amount-Physician Fee Schedule | Physician | 764 | 750 | 778
Supplemental fixation (secondary) | | | | Hosp+MD | 24,882 | 19,125 | 30,638
Supplemental fixation (secondary) | ICD-9-CM | 84.80 | HCUPnet Nationwide Inpatient Sample | Hospital | 11,974 | 10,831 | 13,118
Supplemental fixation (secondary) | CPT | 22840 | CMS National Payment Amount-Physician Fee Schedule | Physician | 764 | 750 | 778
Supplemental fixation (secondary) | | | | Hosp+MD | 12,738 | 11,581 | 13,896

Table 48 Procedure Code Descriptions for Cost Parameter Estimates, Spinal Fusion

Procedure Type | DRG Code | Description | CPT Code | Description | ICD-9- CM Code | Description
Initial | 497 | Spinal fusion except cervical with complications or comorbidities | 22558 | Arthrodesis, anterior interbody technique, including minimal discectomy to prepare interspace (other than for decompression); lumbar
Initial | 498 | Spinal fusion except cervical without complications or comorbidities | 22558 | Arthrodesis, anterior interbody technique, including minimal discectomy to prepare interspace (other than for decompression); lumbar
Secondary: reoperation | 497 | Spinal fusion except cervical with complications or comorbidities | 22558 | Arthrodesis, anterior interbody technique, including minimal discectomy to prepare interspace (other than for decompression); lumbar
Secondary: reoperation | 498 | Spinal fusion except cervical without complications or comorbidities | 22558 | Arthrodesis, anterior interbody technique, including minimal discectomy to prepare interspace (other than for decompression); lumbar
Secondary: removal | | | 22855 | Removal of anterior instrumentation | 78.69 | Removal of implanted devices from bone, other (vertebrae)
Secondary: supplemental Instrumentation | | | 22840 | Posterior non-segmental instrumentation (e.g., Harrington rod technique, pedicle fixation across one interspace, atlantoaxial transarticular screw fixation, sublaminar wiring at C1, facet screw fixation) | 84.82 | Insertion or replacement of pedicle-based dynamic stabilization device(s)

Table 49 Calculation of Secondary Intervention Costs, Spinal Fusion

Table 49A. Costs of Secondary Intervention
Secondary Intervention | Mean | Lower | Upper
Mean supplemental fixation | 18,810 | 15,353 | 22,267

Table 49B. Secondary Intervention Rates, Treatment
Component | # | %
Treatment removal | 2 | 11.1%
Treatment supplemental fixation | 10 | 55.6%
Treatment reoperation | 6 | 33.3%
Total | 18

Table 49C. Weighted Average, Treatment
Weighted Average | Mean | Lower | Upper
Treatment | 21,285 | 18,804 | 23,765

Table 49D. Secondary Intervention Rates, Control
| # | %
Control removal | 0 | 0.0%
Control supplemental fixation | 14 | 77.8%
Control reoperation | 4 | 22.2%
Total | 18

Table 49E. Weighted Average, Control
Weighted Average | Mean | Lower | Upper
Control weighted average | 20,959 | 18,005 | 23,913

#### CEA Results

##### Open Tibial Fracture

The base case analysis (Table 50), with all parameters at mean or middle values, yields a cost saving for BMP over control of $612 and a gain of 0.048 QALYs, making BMP a dominant strategy. The total cost for 52 weeks is $12,938 for treatment and $13,552 for control. Total QALYs is 0.742 for the treatment group and 0.694 QALYs for the control group. Cost savings is due to the lower probability of secondary intervention in the treatment group and higher QALYs is due to the higher treatment group transition rate from preunion to union. It should be noted that the base case analysis assumes that the cost of BMP does not add to the overall DRG cost for the initial hospitalization, so initial costs for treatment and control groups are identical.

Table 50 also shows results of one-way sensitivity analyses. Adding a BMP value of $3,000 to costs results in a cost gain of $2,386 and an ICER of $49,204 per QALY gained. Lower and upper estimates of utilities produce smaller QALY differences favoring treatment, compared with the base case, but the cost savings is the same so BMP still dominates control. BMP-dominant results were also observed when analyses used lower and upper non-BMP costs and lower and upper secondary intervention costs. In both of these sets of analyses, the degree of cost savings and QALY differences were similar to the base case. When the lowest hazard ratio value for preunion is entered (0.99, favoring control), BMP is less cost-effective than control, as it less costly by $164 and results in a loss of 0.001 QALYs. If the hazard ratio for preunion is allowed to be higher than the base case, between-group differences in QALYs become greater: 0.074 when the hazard ratio is 2.62 and 0.098 when the hazard ratio is 3.61. Lower and upper values for the risk ratio of secondary intervention have a modest impact on results.

Table 51 shows the findings when BMP cost is added to two-way sensitivity analyses. For all analyses, the cost in the treatment group exceeds that for the control group. The middle BMP cost value of $3,000 is used in all but two of these analyses. Analyses on utilities, non-BMP costs, secondary intervention costs and risk ratio for secondary interventions produced ICERs in the range of $48,217 to $64,181 per QALY gained. The hazard ratio value for preunion had a strong impact on results. When the hazard ratio favors control, treatment is dominated. At an intermediate low hazard ratio, the ICER is $103,631 per QALY gained, while the highest hazard ratio yields an ICER of $24,471 per QALY gained. Cost of BMP also has a strong influence on results. When BMP is assumed to cost $1,000, the ICER is $7,960 per QALY gained, but when it takes a value of $5,000, the ICER is $90,449 per QALY gained. At an extreme high value of $8,000 for BMP, the ICER becomes $152,317 per QALY gained.

Three-way sensitivity analyses are presented in Table 52. When the cost of BMP is assumed to be $1,000, the BMP strategy is cost-effective in all cases except when the hazard ratio of preunion favors control, resulting in lower cost and lower QALYs. The ICERs for all other analyses were between $3,958 and $12,532 per QALY gained. When BMP is assumed to cost $5,000, ICERs are consistently higher. Excluding analyses on the hazard ratio for preunion, ICERs range from $89,598 to $117,979 per QALY gained. When the cost of BMP is assumed to take an extreme high value ($8,000), ICERs for analyses other than those for the hazard ratio of preunion were between $151,465 and $198,677 per QALY gained.

Table 50 Cost-Effectiveness Analysis Results, Base Case and One-Way Sensitivity Analyses, Open Tibial Fracture

Analyses | Tx Cost | Ctrl Cost | Tx-Ctrl Cost | Tx QALY | Ctrl QALY | Tx-Ctrl QALY | ICER
Base case | 12,938 | 13,552 | −614 | 0.742 | 0.694 | 0.048 | dominant
BMP added to costs | 15,938 | 13,552 | 2,386 | 0.742 | 0.694 | 0.048 | 49,204
Lower utilities | 12,938 | 13,552 | −614 | 0.559 | 0.522 | 0.037 | dominant
Upper utilities | 12,938 | 13,552 | −614 | 0.864 | 0.825 | 0.039 | dominant
Lower non-BMP costs | 12,455 | 13,028 | −573 | 0.742 | 0.694 | 0.048 | dominant
Upper non-BMP costs | 13,422 | 14,077 | −655 | 0.742 | 0.694 | 0.048 | dominant
Lower secondary intervention costs | 12,905 | 13,478 | −573 | 0.742 | 0.694 | 0.048 | dominant
Upper secondary intervention costs | 12,972 | 13,627 | −655 | 0.742 | 0.694 | 0.048 | dominant
Lowest HR preunion | 12,938 | 13,102 | −164 | 0.693 | 0.694 | −0.001 | less CE
Low HR preunion | 12,938 | 13,552 | −614 | 0.717 | 0.694 | 0.023 | dominant
High HR preunion | 12,938 | 13,552 | −614 | 0.768 | 0.694 | 0.074 | dominant
Highest HR preunion | 12,938 | 13,552 | −614 | 0.791 | 0.694 | 0.098 | dominant
Lower secondary intervention RR | 12,785 | 13,552 | −767 | 0.742 | 0.696 | 0.046 | dominant
Upper secondary intervention RR | 13,160 | 13,552 | −392 | 0.742 | 0.694 | 0.048 | dominant

Abbreviations: Ctrl: control; HR: hazard ratio; ICER: incremental cost-effectiveness ratio; QALY: quality-adjusted life years; RR: relative risk; Tx: treatment;

Table 51 Cost-Effectiveness Analysis Results, Two-Way Sensitivity Analysis, BMP Cost Added, Open Tibial Fracture

Analyses | Tx Cost | Ctrl Cost | Tx-Ctrl Cost | Tx QALY | Ctrl QALY | Tx-Ctrl QALY | ICER
BMP added, lower utilities | 15,938 | 13,552 | 2,386 | 0.559 | 0.522 | 0.037 | 64,181
BMP added, upper utilities | 15,938 | 13,552 | 2,386 | 0.864 | 0.825 | 0.039 | 61,500
BMP added, lower non-BMP costs | 15,455 | 13,028 | 2,427 | 0.742 | 0.694 | 0.048 | 50,056
BMP added, upper non-BMP costs | 16,422 | 14,077 | 2,345 | 0.742 | 0.694 | 0.048 | 48,353
BMP added, lower secondary intervention costs | 15,905 | 13,478 | 2,427 | 0.742 | 0.694 | 0.048 | 50,056
BMP added, upper secondary intervention costs | 15,972 | 13,627 | 2,345 | 0.742 | 0.694 | 0.048 | 48,353
BMP added, lowest HR preunion | 15,938 | 13,552 | 2,386 | 0.693 | 0.694 | −0.001 | dominated
BMP added, low HR preunion | 15,938 | 13,552 | 2,386 | 0.717 | 0.694 | 0.023 | 103,631
BMP added, high HR preunion | 15,938 | 13,552 | 2,386 | 0.768 | 0.694 | 0.074 | 32,151
BMP added, highest HR preunion | 15,938 | 13,552 | 2,386 | 0.791 | 0.694 | 0.098 | 24,471
BMP added, lower secondary intervention RR | 15,785 | 13,552 | 2,233 | 0.742 | 0.696 | 0.046 | 48,217
BMP added, upper secondary intervention RR | 16,160 | 13,552 | 2,608 | 0.742 | 0.694 | 0.048 | 53,780
BMP added, lower BMP costs | 13,938 | 13,552 | 386 | 0.742 | 0.694 | 0.048 | 7,960
BMP added, upper BMP costs | 17,938 | 13,552 | 4,386 | 0.742 | 0.694 | 0.048 | 90,449
BMP added, extreme high BMP costs | 20,938 | 13,552 | 7,386 | 0.742 | 0.694 | 0.048 | 152,317

Abbreviations: Ctrl: control; HR: hazard ratio; ICER: incremental cost-effectiveness ratio; QALY: quality-adjusted life years; RR: relative risk; Tx: treatment;

Table 52 Cost-Effectiveness Analysis Results, Three-Way Sensitivity Analysis, BMP Cost Added, BMP Cost Levels, Open Tibial Fracture

Analyses | Tx Cost | Ctrl Cost | Tx-Ctrl Cost | TxQALY | CtrlQALY | Tx-Ctrl QALY | ICER
BMP added, lower BMP costs, lower utilities | 13,938 | 13,552 | 386 | 0.559 | 0.522 | 0.037 | 10,382
BMP added, lower BMP costs, upper utilities | 13,938 | 13,552 | 386 | 0.864 | 0.825 | 0.039 | 9,949
BMP added, lower BMP costs, lower non-BMP costs | 13,455 | 13,028 | 427 | 0.742 | 0.694 | 0.048 | 8,811
BMP added, lower BMP costs, upper non-BMP costs | 14,422 | 14,077 | 345 | 0.742 | 0.694 | 0.048 | 7,108
BMP added, lower BMP costs, lower secondary intervention costs | 13,905 | 13,478 | 427 | 0.742 | 0.694 | 0.048 | 8,811
BMP added, lower BMP costs, upper secondary intervention costs | 13,972 | 13,627 | 345 | 0.742 | 0.694 | 0.048 | 7,108
BMP added, lower BMP costs, lowest HR preunion | 13,938 | 13,552 | 386 | 0.693 | 0.694 | −0.001 | dominated
BMP added, lower BMP costs, lowest HR preunion | 12,938 | 13,552 | −614 | 0.693 | 0.694 | −0.001 | less CE
BMP added, lower BMP costs, low HR preunion | 13,938 | 13,552 | 386 | 0.717 | 0.694 | 0.023 | 16,771
BMP added, lower BMP costs, high HR preunion | 13,938 | 13,552 | 386 | 0.768 | 0.694 | 0.074 | 5,201
BMP added, lower BMP costs, highest HR preunion | 13,938 | 13,552 | 386 | 0.791 | 0.694 | 0.098 | 3,958
BMP added, lower BMP costs, lower secondary intervention RR | 13,785 | 13,552 | 233 | 0.742 | 0.696 | 0.046 | 5,033
BMP added, lower BMP costs, upper secondary intervention RR | 14,160 | 13,552 | 608 | 0.742 | 0.694 | 0.048 | 12,532
BMP added, upper BMP costs, lower utilities | 17,938 | 13,552 | 4,386 | 0.559 | 0.522 | 0.037 | 117,979
BMP added, upper BMP costs, upper utilities | 17,938 | 13,552 | 4,386 | 0.864 | 0.825 | 0.039 | 113,052
BMP added, upper BMP costs, lower non-BMP costs | 17,455 | 13,028 | 4,427 | 0.742 | 0.694 | 0.048 | 91,301
BMP added, upper BMP costs, upper non-BMP costs | 18,422 | 14,077 | 4,345 | 0.742 | 0.694 | 0.048 | 89,598
BMP added, upper BMP costs, lower secondary intervention costs | 17,905 | 13,478 | 4,427 | 0.742 | 0.694 | 0.048 | 91,301
BMP added, upper BMP costs, upper secondary intervention costs | 17,972 | 13,627 | 4,345 | 0.742 | 0.694 | 0.048 | 89,598
BMP added, upper BMP costs, lowest HR preunion | 17,938 | 13,552 | 4,386 | 0.693 | 0.694 | −0.001 | dominated
BMP added, upper BMP costs, low HR preunion | 17,938 | 13,552 | 4,386 | 0.717 | 0.694 | 0.023 | 190,491
BMP added, upper BMP costs, high HR preunion | 17,938 | 13,552 | 4,386 | 0.768 | 0.694 | 0.074 | 59,101
BMP added, upper BMP costs, highest HR preunion | 17,938 | 13,552 | 4,386 | 0.791 | 0.694 | 0.098 | 44,983
BMP added, upper BMP costs, lower secondary intervention RR | 17,785 | 13,552 | 4,233 | 0.742 | 0.696 | 0.046 | 91,401
BMP added, upper BMP costs, upper secondary intervention RR | 18,160 | 13,552 | 4,608 | 0.742 | 0.694 | 0.048 | 95,029
BMP added, extreme high BMP costs, lower utilities | 20,938 | 13,552 | 7,386 | 0.559 | 0.522 | 0.037 | 198,677
BMP added, extreme high BMP costs, upper utilities | 20,938 | 13,552 | 7,386 | 0.864 | 0.825 | 0.039 | 190,380
BMP added, extreme high BMP costs, lower non-BMP costs | 20,455 | 13,028 | 7,427 | 0.742 | 0.694 | 0.048 | 153,168
BMP added, extreme high BMP costs, upper non-BMP costs | 21,422 | 14,077 | 7,345 | 0.742 | 0.694 | 0.048 | 151,465
BMP added, extreme high BMP costs, lower 2° interv costs | 20,905 | 13,478 | 7,427 | 0.742 | 0.694 | 0.048 | 153,168
BMP added, extreme high BMP costs, upper 2° interv costs | 20,972 | 13,627 | 7,345 | 0.742 | 0.694 | 0.048 | 151,465
BMP added, extreme high BMP costs, lowest HR preunion | 20,938 | 13,552 | 7,386 | 0.693 | 0.694 | −0.001 | dominated
BMP added, extreme high BMP costs, low HR preunion | 20,938 | 13,552 | 7,386 | 0.717 | 0.694 | 0.023 | 320,780
BMP added, extreme high BMP costs, high HR preunion | 20,938 | 13,552 | 7,386 | 0.768 | 0.694 | 0.074 | 99,525
BMP added, extreme high BMP costs, highest HR preunion | 20,938 | 13,552 | 7,386 | 0.791 | 0.694 | 0.098 | 75,751
BMP added, extreme high BMP costs, lower 2° interv RR | 20,785 | 13,552 | 7,233 | 0.742 | 0.696 | 0.046 | 156,176
BMP added, extreme high BMP costs, upper 2° interv RR | 21,160 | 13,552 | 7,608 | 0.742 | 0.694 | 0.048 | 156,902

Abbreviations: Ctrl: control; HR: hazard ratio; ICER: incremental cost-effectiveness ratio; QALY: quality-adjusted life years; RR: relative risk; Tx: treatment;

##### Spinal Fusion

Table 53 shows base case and one-way sensitivity analysis results. For the base, case, all parameters were set at mean or middle values, yielding a cost saving for BMP over control of $94 and an increase in QALYs of 0.024, making BMP the dominant strategy over control. Over 104 weeks, the total cost for the treatment group was $31,159, compared with $31,253 for control. Total QALYs was 1.218 in the treatment group and 1.194 in the control group. Lower cost in the treatment group was due to the slightly lower probability of secondary intervention in the treatment group. Higher QALYs are attributable primarily to the disutility of DSP in the control group. Base case analysis assumes that BMP costs are bundled into DRG payments, so initial hospitalization costs are the same in treatment and control groups.

One-way sensitivity analyses are also shown in Table 53. Again, BMP cost is excluded from treatment group costs except in one of these analyses. When BMP is assumed to be an added cost of $3,000, the total cost in the treatment group rises to $34,159, resulting in a cost excess for the treatment group of $2,906 and an ICER or $121,160 per QALY gained. BMP is the dominant strategy in all other one-way sensitivity analyses except one. When the upper value of the risk ratio for secondary intervention is entered, the cost difference between strategies is $2,153 and the ICER is $89,765 per QALY gained.

Table 54 shows two-way sensitivity analyses defined by adding BMP to treatment group costs. In all but two instances, the middle value for BMP cost of $3,000 is used. Among analyses using the $3,000 amount, when the disutility of donor-site pain is assumed to be larger (a decrement of 0.05) than the base case value (0.02), the lowest ICER is observed: $56,959 per QALY gained. Other analyses using the $3,000 value produce results for the ICER between $70,467 and $214,834 per QALY gained. If BMP cost is assumed to be $1,000, the ICER is $37,785 per QALY gained, in contrast to a result of $204,536 per QALY gained when the cost is $5,000 and $329,599 per QALY gained when the cost is $8,000.

Three-way sensitivity analyses on the level of BMP cost are presented in Table 55. Among analyses assuming a BMP cost of $1,000, the most influential variable was the risk ratio of secondary intervention. At the low risk ratio value of 0.52 (favoring the treatment group), the treatment group strategy is dominant, but at the high value of 1.75 (favoring the control group), the ICER is $131,455 per QALY gained. All other sensitivity analyses with the $1,000 BMP amount produce ICERs between $17,763 and $50,557 per QALY gained. When BMP is assumed to cost $5,000, the BMP strategy becomes much less cost-effective. ICERs are between $96,155 (larger DSP disutility) and $298,213 per QALY gained (upper risk ratio for secondary intervention). At an extreme high value of $8,000 for the cost of BMP, ICERs range between $154,948 and $443,385 per QALY gained.

##### Key Question 9, Discussion and Conclusion

The use of the Medicare DRG payment system in the initial hospitalization of open tibial fracture and spinal fusion patients presents a challenge for interpreting the cost-effectiveness analyses presented here. Base case and one-way sensitivity analyses largely assume that BMP cost is bundled into the DRG payment. Based on this assumption, initial costs were identical for treatment and control groups, forcing results that use of BMP is a dominant strategy. A more plausible assumption may be that DRG payments for patients receiving BMP will be higher than DRGs for patients treated without it, for example, using additional outlier payments. Thus, emphasis should be placed on this report’s analyses that assume added BMP costs (at amounts of $1,000, $3,000, $5,000 and $8,000).

Table 53 Cost-Effectiveness Analysis Results, Base Case and One-Way Sensitivity Analyses, Spinal Fusion

Analyses | Tx Cost | Ctrl Cost | Tx-Ctrl Cost | Tx QALY | Ctrl QALY | Tx-Ctrl QALY | ICER
Base case | 31,159 | 31,253 | −94 | 1.218 | 1.194 | 0.024 | dominant
BMP added to costs | 34,159 | 31,253 | 2,906 | 1.218 | 1.194 | 0.024 | 121,160
Lower utilities | 31,159 | 31,253 | −94 | 0.924 | 0.901 | 0.022 | dominant
Upper utilities | 31,159 | 31,253 | −94 | 1.533 | 1.498 | 0.034 | dominant
Large DSP disutility | 31,159 | 31,253 | −94 | 1.218 | 1.167 | 0.051 | dominant
Lower non-BMP costs | 29,653 | 29,668 | −15 | 1.218 | 1.194 | 0.024 | dominant
Upper non-BMP costs | 32,665 | 32,837 | −172 | 1.218 | 1.194 | 0.024 | dominant
Lower secondary intervention costs | 30,847 | 30,862 | −15 | 1.218 | 1.194 | 0.024 | dominant
Upper secondary intervention costs | 31,471 | 31,644 | −172 | 1.218 | 1.194 | 0.024 | dominant
Lowest prefusion HR | 31,159 | 31,253 | −94 | 1.212 | 1.194 | 0.018 | dominant
Low prefusion HR | 31,159 | 31,253 | −94 | 1.216 | 1.194 | 0.021 | dominant
High prefusion HR | 31,159 | 31,253 | −94 | 1.221 | 1.194 | 0.026 | dominant
Highest prefusion HR | 31,159 | 31,253 | −94 | 1.223 | 1.194 | 0.028 | dominant
Lower secondary intervention RR | 29,943 | 31,253 | −1,310 | 1.218 | 1.194 | 0.024 | dominant
Upper secondary intervention RR | 33,406 | 31,253 | 2,153 | 1.218 | 1.194 | 0.024 | 89,765
Lower DSP risk | 31,159 | 31,253 | −94 | 1.218 | 1.198 | 0.020 | dominant
Upper DSP risk | 31,159 | 31,253 | −94 | 1.218 | 1.190 | 0.028 | dominant

Abbreviations: Ctrl: control; DSP: donor-site pain; HR: hazard ratio; ICER: incremental cost-effectiveness ratio; QALY: quality-adjusted life years; RR: relative risk; Tx: treatment;

Table 54 Cost-Effectiveness Analysis Results, Two-Way Sensitivity Analysis, BMP Cost Added, Spinal Fusion

| Tx Cost | Ctrl Cost | Tx-Ctrl Cost | Tx QALY | Ctrl QALY | Tx-Ctrl QALY | CER
BMP added, lower utilities | 34,159 | 31,253 | 2,906 | 0.924 | 0.901 | 0.022 | 129,188
BMP added, upper utilities | 34,159 | 31,253 | 2,906 | 1.533 | 1.498 | 0.034 | 84,264
BMP added, larger DSP disutility | 34,159 | 31,253 | 2,906 | 1.218 | 1.167 | 0.051 | 56,959
BMP added, lower non-BMP costs | 32,653 | 29,668 | 2,985 | 1.218 | 1.194 | 0.024 | 124,435
BMP added, upper non-BMP costs | 35,665 | 32,837 | 2,828 | 1.218 | 1.194 | 0.024 | 117,885
BMP added, lower secondary intervention costs | 33,847 | 30,862 | 2,985 | 1.218 | 1.194 | 0.024 | 124,435
BMP added, upper secondary intervention costs | 34,471 | 31,644 | 2,828 | 1.218 | 1.194 | 0.024 | 117,885
BMP added, lowest prefusion HR | 34,159 | 31,253 | 2,906 | 1.212 | 1.194 | 0.018 | 162,994
BMP added, low prefusion HR | 34,159 | 31,253 | 2,906 | 1.216 | 1.194 | 0.021 | 136,953
BMP added, high prefusion HR | 34,159 | 31,253 | 2,906 | 1.221 | 1.194 | 0.026 | 110,479
BMP added, highest prefusion HR | 34,159 | 31,253 | 2,906 | 1.223 | 1.194 | 0.028 | 103,079
BMP added, lower secondary intervention RR | 32,943 | 31,253 | 1,690 | 1.218 | 1.194 | 0.024 | 70,467
BMP added, upper secondary intervention costs RR | 36,406 | 31,253 | 5,153 | 1.218 | 1.194 | 0.024 | 214,834
BMP added, lower DSP risk | 34,159 | 31,253 | 2,906 | 1.218 | 1.198 | 0.020 | 144,827
BMP added, upper DSP risk | 34,159 | 31,253 | 2,906 | 1.218 | 1.190 | 0.028 | 104,142
BMP added, lower BMP | 32,159 | 31,253 | 906 | 1.218 | 1.194 | 0.024 | 37,785
BMP added, upper BMP | 36,159 | 31,253 | 4,906 | 1.218 | 1.194 | 0.024 | 204,536
BMP added, extreme high BMP | 39,159 | 31,253 | 7,906 | 1.218 | 1.194 | 0.024 | 329,599

Abbreviations: Ctrl: control; DSP: donor-site pain; HR: hazard ratio; ICER: incremental cost-effectiveness ratio; QALY: quality-adjusted life years; RR: relative risk; Tx: treatment;

Table 55 Cost-Effectiveness Analysis Results, Three-Way Sensitivity Analysis, BMP Cost Added, BMP Cost Levels, Spinal Fusion

Analyses | Tx Cost | Ctrl Cost | Tx-Ctrl Cost | Tx QALY | Ctrl QALY | Tx-Ctrl QALY | ICER
BMP added, lower BMP costs, lower utilities | 32,159 | 31,253 | 906 | 0.924 | 0.901 | 0.022 | 40,288
BMP added, lower BMP costs, upper utilities | 32,159 | 31,253 | 906 | 1.533 | 1.498 | 0.034 | 26,279
BMP added, lower BMP costs, larger DSP disutility | 32,159 | 31,253 | 906 | 1.218 | 1.167 | 0.051 | 17,763
BMP added, lower BMP costs, lower non-BMP costs | 30,653 | 29,668 | 985 | 1.218 | 1.194 | 0.024 | 41,060
BMP added, lower BMP costs, upper non-BMP costs | 33,665 | 32,837 | 828 | 1.218 | 1.194 | 0.024 | 34,510
BMP added, lower BMP costs, lower secondary intervention costs | 31,847 | 30,862 | 985 | 1.218 | 1.194 | 0.024 | 41,060
BMP added, lower BMP costs, upper secondary intervention costs | 32,471 | 31,644 | 828 | 1.218 | 1.194 | 0.024 | 34,510
BMP added, lower BMP costs, lowest HR prefusion | 32,159 | 31,253 | 906 | 1.212 | 1.194 | 0.018 | 50,838
BMP added, lower BMP costs, low HR prefusion | 32,159 | 31,253 | 906 | 1.216 | 1.194 | 0.021 | 42,691
BMP added, lower BMP costs, high HR prefusion | 32,159 | 31,253 | 906 | 1.221 | 1.194 | 0.026 | 34,437
BMP added, lower BMP costs, highest HR prefusion | 32,159 | 31,253 | 906 | 1.223 | 1.194 | 0.028 | 32,138
BMP added, lower BMP costs, lower secondary intervention RR | 30,943 | 31,253 | −310 | 1.218 | 1.194 | 0.024 | dominant
BMP added, lower BMP costs, upper secondary intervention RR | 34,406 | 31,253 | 3,153 | 1.218 | 1.194 | 0.024 | 131,455
BMP added, lower BMP costs, lower DSP risk | 32,159 | 31,253 | 906 | 1.218 | 1.198 | 0.020 | 45,165
BMP added, lower BMP costs, upper DSP risk | 32,159 | 31,253 | 906 | 1.218 | 1.190 | 0.028 | 32,477
BMP added, upper BMP costs, lower utilities | 36,159 | 31,253 | 4,906 | 0.924 | 0.901 | 0.022 | 218,088
BMP added, upper BMP costs, upper utilities | 36,159 | 31,253 | 4,906 | 1.533 | 1.498 | 0.034 | 142,250
BMP added, upper BMP costs, larger DSP disutility | 36,159 | 31,253 | 4,906 | 1.218 | 1.167 | 0.051 | 96,155
BMP added, upper BMP costs, lower non-BMP costs | 34,653 | 29,668 | 4,985 | 1.218 | 1.194 | 0.024 | 207,810
BMP added, upper BMP costs, upper non-BMP costs | 37,665 | 32,837 | 4,828 | 1.218 | 1.194 | 0.024 | 201,261
BMP added, upper BMP costs, lower secondary intervention costs | 35,847 | 30,862 | 4,985 | 1.218 | 1.194 | 0.024 | 207,810
BMP added, upper BMP costs, upper secondary intervention costs | 36,471 | 31,644 | 4,828 | 1.218 | 1.194 | 0.024 | 201,261
BMP added, upper BMP costs, lowest HR prefusion | 36,159 | 31,253 | 4,906 | 1.212 | 1.194 | 0.018 | 275,150
BMP added, upper BMP costs, low HR prefusion | 36,159 | 31,253 | 4,906 | 1.216 | 1.194 | 0.021 | 231,215
BMP added, upper BMP costs, high HR prefusion | 36,159 | 31,253 | 4,906 | 1.221 | 1.194 | 0.026 | 186,521
BMP added, upper BMP costs, highest HR prefusion | 36,159 | 31,253 | 4,906 | 1.223 | 1.194 | 0.028 | 174,020
BMP added, upper BMP costs, lower secondary intervention RR | 34,943 | 31,253 | 3,690 | 1.218 | 1.194 | 0.024 | 153,841
BMP added, upper BMP costs, upper secondary intervention RR | 38,406 | 31,253 | 7,153 | 1.218 | 1.194 | 0.024 | 298,213
BMP added, upper BMP costs, lower DSP risk | 36,159 | 31,253 | 4,906 | 1.218 | 1.198 | 0.020 | 244,489
BMP added, upper BMP costs, upper DSP risk | 36,159 | 31,253 | 4,906 | 1.218 | 1.190 | 0.028 | 175,806
BMP added, extreme high BMP costs, lower utilities | 39,159 | 31,253 | 7,906 | 0.924 | 0.901 | 0.022 | 351,437
BMP added, extreme high BMP costs, upper utilities | 39,159 | 31,253 | 7,906 | 1.533 | 1.498 | 0.034 | 229,229
BMP added, extreme high BMP costs, larger DSP disutility | 39,159 | 31,253 | 7,906 | 1.218 | 1.167 | 0.051 | 154,948
BMP added, extreme high BMP costs, lower non-BMP costs | 37,653 | 29,668 | 7,985 | 1.218 | 1.194 | 0.024 | 332,874
BMP added, extreme high BMP costs, upper non-BMP costs | 40,665 | 32,837 | 7,828 | 1.218 | 1.194 | 0.024 | 326,324
BMP added, extreme high BMP costs, lower 2° interv costs | 38,847 | 30,862 | 7,985 | 1.218 | 1.194 | 0.024 | 332,874
BMP added, extreme high BMP costs, upper 2° interv costs | 39,471 | 31,644 | 7,828 | 1.218 | 1.194 | 0.024 | 326,324
BMP added, extreme high BMP costs, lowest HR prefusion | 39,159 | 31,253 | 7,906 | 1.212 | 1.194 | 0.018 | 443,385
BMP added, extreme high BMP costs, low HR prefusion | 39,159 | 31,253 | 7,906 | 1.216 | 1.194 | 0.021 | 372,609
BMP added, extreme high BMP costs, high HR prefusion | 39,159 | 31,253 | 7,906 | 1.221 | 1.194 | 0.026 | 300,584
BMP added, extreme high BMP costs, highest HR prefusion | 39,159 | 31,253 | 7,906 | 1.223 | 1.194 | 0.028 | 280,432
BMP added, extreme high BMP costs, lower 2° interv RR | 37,943 | 31,253 | 6,690 | 1.218 | 1.194 | 0.024 | 278,901
BMP added, extreme high BMP costs, upper 2° interv RR | 41,406 | 31,253 | 10,153 | 1.218 | 1.194 | 0.024 | 423,281
BMP added, extreme high BMP costs, lower DSP risk | 39,159 | 31,253 | 7,906 | 1.218 | 1.198 | 0.020 | 393,981
BMP added, extreme high BMP costs, upper DSP risk | 39,159 | 31,253 | 7,906 | 1.218 | 1.190 | 0.028 | 283,302

Abbreviations: Ctrl: control; DSP: donor-site pain; HR: hazard ratio; ICER: incremental cost-effectiveness ratio; QALY: quality-adjusted life years; RR: relative risk; Tx: treatment;

Table 56 Summary Table of Open Tibial Fracture Cost-Effectiveness Analysis Results

BMP Cost | Mean ICER^*^ | Restricted Range of ICERs^**^
$1,000 | 7,960 | 5,201–16,771
$3,000 | 49,204 | 24,471–64,181
$5,000 | 90,449 | 59,101–190,491
$8,000 | 152,317 | 99,525–198,677

* ICER values are treatment minus control difference in cost in US$ divided by difference in QALYs (dollar amount needed to gain one extra QALY by choosing treatment over control).

** The range of ICERs across sensitivity analyses excluded the lowest and highest hazard ratios for preunion.

Analyses of open tibial fracture consistently found higher quantities of QALYs and higher costs for the group receiving BMP. Differences in QALYs between treatment and control are largely attributable to the faster rate of achieving union in the treatment group. The summary table above shows that the ICER for choosing treatment over control is very sensitive to the added cost of BMP. These data exclude the lowest and highest values of the hazard ratio for preunion, which also had a strong influence on results.

Table 57 Summary Table of Spinal Fusion Cost-Effectiveness Analysis Results

BMP Cost | Mean ICER | Restricted Range of ICERs^***^
$1,000 | 37,785 | 17,763–50,557
$3,000 | 121,160 | 56,959–162,714
$5,000 | 204,536 | 96,155–274,870
$8,000 | 329,599 | 154,948–443,385

*** The range of ICERs across sensitivity analyses excluding the lower and upper risk ratios for secondary intervention.

Spinal fusion analyses also found that the group treated with BMP had higher QALYs and higher costs. However, compared with open tibial fracture, the QALY difference was generally smaller and the cost difference greater, accounting for less favorable ICERs. Differences in QALYs were largely attributable to the disutility of DSP in the control group. Results in the summary table above show that ICERs were very sensitive to the assumed added cost of BMP. The results exclude the lower and upper values of this risk ratio for secondary intervention, a variable that was very influential on results.

A key strength of these cost-effectiveness analyses is the use of Markov models, explicitly taking into account changes in health states over time, in contrast with than simpler modeling techniques. Another strength is the use of area calibration sources, facilitated by short time horizons, which allowed modeled time in health states to precisely match estimates of observed time. In the spinal fusion analyses, one strength was inclusion of states in which patients experienced donor site pain.

One limitation of these analyses is the use of free publicly available cost estimates. While more limited access cost sources may provide more accurate cost estimates, it is unlikely that they would have a substantial impact on the results of these analyses. Another limitation is the exclusion of health state and cost estimates for infection in the open tibial fracture analyses. While the BESTT trial reported significantly lower infection rates for BMP patients, no data were given about the distribution of durations of infection, so the Markov model used here did not include it. There was a limited evidence base for both open tibial fracture and spinal fusion, each consisting of a single randomized controlled trial. Biases may have existed in the source studies, for example possibly biased assessment of outcomes would result in inaccurate transition probabilities. Probabilistic sensitivity analyses were not performed, but would be unlikely to affect the interpretation of these analyses’ findings.

The results of these cost-effectiveness analyses are consistent with finding of this technology assessment’s systematic review. Preceding discussion of the effects of rhBMP2 in on-label treatment of acute open tibial shaft fracture concludes evidence is moderate that healing is enhanced and need for secondary intervention is reduced, and these outcomes are reflected in QALY differences captured in the Markov model. Evidence is also moderate for on-label lumbar spinal fusion consistently showing similar and possibly better frequency of fusion and avoidance of bone graft harvest adverse events. The spinal fusion cost-effectiveness analysis relies primarily in the effectiveness component results on the avoidance of bone graft donor site pain.

### Key Question 10 What is the age distribution of study patients compared to the Medicare population (age 65 and older)?

The age range of study populations in the comparative studies compiled in this assessment is abstracted in detail in Appendix 1 Table C (on-label studies) and Appendix 1 Table D (off-label studies).

Among all studies the mean reported age was typically in the mid- to upper-50 years range. The lowest mean age for a group of patients in any study arm was 16 years for patients who underwent surgery to repair unilateral cleft lip with an alveolar cleft defect.91 The highest mean age reported for any group was 70 years for patients who underwent posterolateral lumbar spinal fusion.87 Considering all patients in comparative studies, individual ages ranged from a minimum 16 years to a maximum 87 years.74 Among 28 comparative studies compiled in this assessment, 9 reported the proportion of patients who were at least 65 years old, which ranged from 0 percent82,91,92,96 to 50 percent.94

#### What are the considerations in generalizing evidence from trials to the age 65 and older Medicare populations (such as comorbid conditions in the Medicare population and this population’s susceptibility to adverse events)

A randomized trial performed by Glassman and colleagues87 is the study identified as most relevant to the age 65 years and older Medicare population. All patients in the trial underwent a lumbar spinal fusion, were older than 60 years, with mean age 69 +/− 6 years in rhBMP2 recipients and 70 +/− 6 years in ICBG recipients.

The radiographic fusion success rate at 24 months (Table 58) was numerically larger with rhBMP2 than autograft bone, but statistical significance was not reported. All other outcomes with autograft bone reported in the Glassman study87 are similar to those achieved with rhBMP2. The patient characteristics in the Glassman study were not well described, nor were any comorbid conditions that could affect fusion outcomes in this age group. The investigators reported use of undefined bone graft extender or filler in 100 percent of BMP cases and 67 percent of ICBG cases, plus local bone shavings in 100% of cases in both groups. They also presented pooled outcome data from multilevel and single-level fusion patients.

Table 58 Clinical Outcomes in Off-Label Randomized Trial of rhBMP2 for Lumbar-Sacral Spinal Fusion in Medicare Age Patients

Study (ref no.) | Grp | No. Pts | BMP dose (mg/pt) | Radio- graphic fusion success 24 mos., % | ODI success 24 mos. % | ODI mean point score ↑ 24 mos. | Leg pain mean point score ↑ 24 mos. | SF-36 PCS mean point score ↑ 24 mos. | USPSTF study quality
Glassman et al., 2008 (87) | BMP2 | 50 | 8–12 (InFUSE) | 86 | NR | 15 | 3.6 | 7 | POOR
Glassman et al., 2008 (87) | ICBG | 52 | 0 | 71 | NR | 13 | 3.1 | 7 | POOR

Abbreviations: ICBG: iliac crest bone graft; mos.: months; NR: not reported; ODI: Oswestry Disability Index; SF: short form;

The study by Glassman87 illustrates the considerations relevant to generalizing from studies in the non-Medicare population. These include patient age and presence of comorbidities such as osteoporosis or diabetes. However in generalizing from available studies to the Medicare population, BMP dose and surgical methods should also be considered.