# METHODS

As detailed below, certain aspects of Methods and Materials may vary to satisfy requirements of each question. However, the Methods are generally applicable to all Key Questions, including Methods of the Review, Evidence Tables, Identifying Additional Studies, and Assessing Study Quality.

## Database Search Strategies

The following electronic databases were searched for citations (search strategy can be found in Appendix 6).

- MEDLINE® (January 1, 1998, through July 28, 2009)
- EMBASE® (January 1, 1998, through July 28, 2009)
- Cochrane Controlled Trials Register (no date restriction)

The searches were updated in February 2010. At that time, we became aware of a report of 6-years results from two earlier trials of rhBMP2 (InFUSE®) in lumbar-sacral spinal fusion.^*^ These data do not change the conclusions of this technology assessment.

* Burkus JK, Gornet MF, Schuler TC, et al. Six-year outcomes of anterior lumbar interbody arthrodesis with use of interbody fusion cages and recombinant human bone morphogenetic protein-2. J Bone Joint Surg Am. 2009;91:1181–1189.

The search was not limited to English-language references, but because the non-English articles that were identified did not add to the analysis or conclusions, they were excluded . Because the review of on-label uses primarily focused on RCTs, the Cochrane Handbook search strategy for controlled trials58 was applied.

The MEDLINE® search resulted in 1,606 unique citations (2 duplicates were found within the 1,608 citations total). The EMBASE search resulted in 499 citations and the Cochrane search resulted in 54 citations. The total number of citations, due to overlap between the searches, was 1,992 citations.

In addition to the electronic database searches, we examined the bibliographies of all retrieved articles for citations to any RCT that was missed in the database searches. We did not seek or include studies published in conference proceedings and abstracts.

## Patient Populations

The populations of interest for all key questions comprise patients with a skeletal bone defect or bone-related condition for which intervention is undertaken to effect or augment correction of such a defect.

## Interventions

The interventions of interest for all Key Questions are the use of either of two BMP products, rhBMP2 (InFUSE®) and rhBMP7 (OP-1®) that are licensed for marketing and use in the U.S.

Interventions will be considered to be delivered on-label only when administered alone (without additional entities such as autograft bone, allograft bone, other osteoconductive or osteoinductive agents such as platelet-rich plasma (PRP), demineralized bone matrix or other such carriers) according to the indication specified in the FDA-approved marketing label. Dose will only be addressed if it is a primary objective in a study, but will be abstracted from primary studies.

All other uses and applications of BMP products will be considered off-label.

## Comparators

Comparators may include other osteoconductive, osteoblastic, or osteoinductive agents, (including, but not limited to, autologous bone, allogeneic bone, bone marrow, demineralized bone matrix, stem cells, or others that are used to augment bone remodeling and healing processes), a placebo (e.g., BMP or bovine collagen placebo), or standard surgical care.

## Outcomes of Interest

Outcome measures should be standard, valid, reliable, and clinically meaningful, with defined minimally detectable change (in a statistical sense) and minimally important clinical difference (a change patients perceive as beneficial). Durability and outcomes (short- and long-term effects) will be examined according to the time frame of study reporting.

The primary outcomes of interest are subdivided according to type of skeletal bone defect, but because the technology assessment sought to assess off-label uses, not all were prespecified in the workplan.

### Fractures

A consistent definition of fracture healing that is clinically and biologically accurate has been difficult to develop.59 A wide range of clinical and radiographic criteria have been used to assess fracture non-union, for example tibial fractures, with non-union defined as ranging from 2 to 12 months. Available methods include radiographic technologies, mechanical property assessment, and patient-centered and health-related quality-of-life (QoL) outcomes.

Several radiographic measures can be used to assess fracture healing, including conventional radiography, absorptiometry, and photodensitometry, bone scintigraphy, ultrasound, and computed tomography. The oldest and most common is conventional radiography, which allows qualitative assessment of callus formation, cortical bridging, loss of the fracture line, and trabecular crossing at the fracture site. This method is widely available, relatively inexpensive, and delivers a low dose of radiation to the patient. However, the relationship between radiographic features and mechanical strength is not well established. Furthermore, it is unclear how any radiographic measures correspond to outcomes that are important to the patient, such as pain, function, or QoL.

Mechanical property testing to assess fracture healing includes vibrational analysis and biomechanical testing to determine true measures of stiffness and strength. These have been introduced for bedside use, but neither is commonly used or well-validated clinically in typical settings.

### Patient-Reported and Health-Related Outcomes

Several classes of health-related QoL measurement instruments are available. General health instruments, such as the Short Form-36 (SF-36) address a broad spectrum of domains surrounding physical and mental health. The SF-36 survey is widely validated in a variety of conditions; however, it may not be sufficiently responsive to detect smaller functional changes secondary to orthopedics procedures.

Changes in disability, pain, or function of an extremity or body region may be assessed using specific instruments, such as the Disability of the Arm, Shoulder and Hand (DASH60), which can be more responsive than general health instruments.

Pain severity or intensity (typically measured by either visual analog scale (VAS) or a numeric rating scale (NRS) at the site of a fracture, in conjunction with the ability to bear weight, walk, or perform activities of daily living are commonly used criteria to assess fracture healing. A combination of conventional radiography and clinical questions on pain and weight-bearing was the most commonly used approach to assessing fracture healing in a recent survey of published articles.59 The need for subsequent surgical interventions secondary to treatment failure also may be considered a clinical outcome.

### Spinal Fusion

As outlined above, radiographic methods are used to evaluate bone healing in spinal fusion procedures. In addition, clinical outcomes of treatments for back pain are compared using a variety of techniques. Most common are pain scales measured on a visual analog scale. Various questionnaires have been developed to additionally capture measures of physical functioning. These types of clinical findings may be combined with radiographic assessment in composite measures, often referred to as overall success.

One of the more common measurement scales in use specific to patients with back pain is the Oswestry Disability Index (ODI), originally developed in 1976. The validity, consistency, and reproducibility of the ODI were extensively reviewed by Roland and Fairbank.61 This review cites an article by Meade and co-workers,62 which suggests that a 4-point difference in the ODI is the minimum clinically significant difference. The Roland and Fairbank article also cites a personal communication from the FDA, which states that the FDA has chosen a minimum 15-point change in spinal surgery patients as a clinically meaningful difference in the ODI.

Three primary outcome variables used to assess outcomes of cervical spinal fusion include the Neck Disability Index (NDI), neurological status, and functional spinal unit height (FSU). The NDI is a validated multidimensional instrument that measures the effects of pain and disability on a patient’s ability to manage everyday life.63 It is a modification of the Oswestry Low Back Pain Index, based on the response to 10 questions that focus on neck pain intensity, personal care, lifting, reading, headaches, concentration, work, driving, sleeping, and recreation. The response to each question ranges from 1 to 5, with a lower numeric score representing a better pain and disability status for that variable. A total NDI score is obtained by adding individual question scores and dividing by the maximum total of 50 if all questions are answered. Therefore, NDI scores range from 0 percent to 100 percent, with a lower percentage indicating less pain and disability.

The neurological status is a composite measure of motor function, sensory function, and deep tendon reflexes. It is used to judge if patients are within normal parameters for those categories based on physiological measurement. Neurological success may be based on postoperative maintenance or improvement of condition as compared to preoperative status for each component.

The anterior FSU height is a radiographic measure of interdiscal space. Comparison of the immediate postoperative FSU height with the 6-week postoperative value shows whether or not the disc space has decreased, which indicates graft or device subsidence has occurred.

Secondary outcome measures include the Medical Outcomes Study 36-Item Short Form Health Survey (SF-36) mental (MCS) and physical (PCS) component summaries, neck and arm pain status, patient satisfaction, patient global perceived effect, gait assessment, foraminal compression test, adjacent level stability and measurements, return to work, and physician’s perception. In addition to disability and QoL instruments, the need for subsequent surgical interventions secondary to treatment failure also may be considered a clinical health outcome in spinal fusion patients.

### Alveolar Ridge and Sinus Augmentation

Outcomes in these studies will be as defined in the FDA-approved marketing label, based on the pivotal trials for these uses. Thus, a successful outcome of sinus augmentation is defined as successful dental implant borne restoration after 6 months of functional loading. A secondary outcome would be the achievement of clinical osseointegration and maintained functional restoration after 6, 12, 18, and 24 months of functional loading

### Off-label Uses

Because the results of this analysis could not be predicted a priori, it was not possible to specify outcomes to be compiled. However, whenever possible, we compiled outcomes deemed to be clinically relevant to the patient, ideally based on validated criteria for each use.

### Harms

Specific harms secondary to the use of BMP products have been reported (e.g., excessive or ectopic bone formation, antibody response to BMP or bovine collagen, neck swelling, etc). We will use the FDA-approved marketing labels for rhBMP2 (InFUSE®) and rhBMP-7 (OP-1®) as guidance for collection of information on harms (including dose information) reported in the primary literature. While the absence of information on harms is not construed as evidence that none occurred in any particular study, we are unaware of any established method to efficiently systematically review and compile this type of information.

There are no validated standard tools to assess either reporting bias or completeness for harms. Consequently, reporting was assessed using an empirically derived set of questions informed by the McMaster Quality Assessment Scale for Harms (McHarm64) and the Agency for Healthcare Research and Quality (AHRQ) draft Methods Manual guidance.65

▪ Is there an explanation of how harms were identified?
▪ Was a standardized or validated instrument or scale used?
▪ Was ascertainment similar and complete in all study groups?
▪ Was a measure of severity reported?
▪ Were harms attributed to the study intervention likely causally associated?
▪ Were the number and type of harmful events reported separately for study groups?

## Practice Settings

Interventions relevant to all key questions are used in hospitals or outpatient surgical centers.

## Study Selection Criteria

Studies were selected to address the following 10 Key Questions identified for this technology assessment (see Introduction). One reviewer screened titles and abstracts of identified studies using the following eligibility criteria. If this could not be done satisfactorily from the title and abstract, we obtained a full text version for assessment. Articles published in a language other than English were not included in this technology assessment.

### Key Questions 1–6

We abstracted data from full-length RCTs that utilized BMP therapy in patients with a bony defect that required intervention and reported at least one health benefit of interest. If RCT evidence was unavailable, data from nonrandomized comparative studies (quasi-experimental) was sought to assess clinical efficacy.

### Key Questions 7 and 8

We retrieved studies and abstracted data on harms from full-length reports with English-language abstracts, including all RCTs and nonrandomized comparative studies, and other observational studies with more than 50 patients in which the specified aim of the study was to evaluate harms attributable to BMP use.

### Key Question 9

Economic evaluation was addressed by: 1) identifying and appraising published economic evaluations and 2) developing economic decision models for spinal fusion and tibia fractures. To identify economic evaluations, the search strategy was modified using economics as a keyword. Databases of economic evaluations were also searched, including:

- CEA Registry at Tufts (https://research.tufts-nemc.org/cear/default.aspx),
- National Health Service Economic Evaluation Database (http://www.crd.york.ac.uk/crdweb/Home.aspx?DB=NHS%20EED)
- Health Economic Evaluations Database (http://www3.interscience.wiley.com/cgi-bin/mrwhome/114130635/HOME? CRETRY=1&SRETRY=0)

Quality of economic evaluations was assessed using the checklist developed by Drummond et al.66:

▪ Was a well-defined question posed in answerable form?
▪ Was a comprehensive description of the competing alternatives given (i.e. can you tell who did what to whom, where, and how often)?
▪ Was the effectiveness of the program or services established?
▪ Were all the important and relevant costs and consequences for each alternative identified?
▪ Were costs and consequences measured accurately in appropriate physical units (e.g. hours of nursing time, number of physician visits, lost work-days, gained life years)?
▪ Were the cost and consequences valued credibly?
▪ Were costs and consequences adjusted for differential timing?
▪ Was an incremental analysis of costs and consequences of alternatives performed?
▪ Was allowance made for uncertainty in the estimates of costs and consequences?
▪ Did the presentation and discussion of study results include all issues of concern to users?

Economic decision models were developed for spinal fusion and tibia fractures relevant to the Medicare population. Evidence used to inform the cost-effectiveness analyses were derived from two sources. Outcome probabilities came from this technology assessment, published systematic reviews, and meta-analyses. Cost estimates came from payor databases and published sources. Utilities used in the systematic review by Garrison et al.26 were to be employed if more recent values could not be identified.

### Key Question 10

We abstracted and compiled data on the age distribution of patients included in studies selected for inclusion in this technology assessment.

## Data Analysis and Presentation

Electronic search results were stored in a ProCite® database and the number of references retrieved and included in the technology assessment was documented. Using the final study selection criteria for screening titles and abstracts, a single reviewer marked each citation as 1) eligible for review as a full-text article, 2) ineligible for full-text review, or 3) uncertain. A second reviewer reviewed all citations marked as uncertain by the first reviewer, and the two reviewers formed a consensus opinion.

Detailed records of the results of this evaluation were kept for each paper retrieved in full text, including the reason for exclusion of each excluded study. A listing of excluded studies with reasons for exclusion is available in Appendix 6. Any disagreement about the inclusion or exclusion of a particular article was resolved by consultation with a third reviewer to achieve a consensus.

The following data elements of primary studies were abstracted as available from the articles meeting all selection criteria.

a. General information: title, authors, source, year of publication, duplicate publications, setting, funding.
b. Trial characteristics: method of randomization, concealment of allocation, blinding of patients and clinicians.
c. Patients: sampling, exclusion criteria, sample size, baseline characteristics, similarity of groups at baseline, diagnostic criteria, withdrawals, losses to follow up.
d. Interventions: dose, dosing regimen, duration, route, co-medications with dose, timing.
e. Analytical methods
f. Outcomes: outcomes as specified above
g. Data on costs (if applicable)

## Evidence Tables

We created templates for evidence tables in Microsoft Excel® and Microsoft Word®. One reviewer performed primary data abstraction of all data elements into the evidence tables, and a second reviewer performed accuracy checks on the evidence tables.

## Assessment of Study Quality

The quality (internal validity) of included studies (RCTs and other comparative designs) was assessed on the basis of the general approach to grading evidence developed by the U.S. Preventive Services Task Force (USPSTF67). The quality of the abstracted studies was assessed by two independent reviewers. Discordant quality assessments were resolved with input from a third reviewer, if necessary. Quality criteria were as follows:

a. Initial assembly of comparable groups: adequate randomization, including concealment and whether potential confounders (e.g., other concomitant care) were distributed equally among groups
b. Maintenance of comparable groups (includes attrition, crossovers, adherence contamination)
c. Important differential loss to follow-up or overall high loss to follow-up
d. Measurements: equal, reliable, and valid (includes masking of outcome assessment)
e. Clear definition of interventions
f. All important outcomes considered
g. Analysis: adjustment for potential confounders, intention-to-treat analysis
h. The rating of intervention studies encompasses the three quality categories described here:

Studies were rated as “good” if they met all criteria: Comparable groups were assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments were used and applied equally to the groups; interventions were spelled out clearly; all important outcomes are considered; and appropriate attention was given to confounders in analysis. In addition, for RCTs, intention-to-treat analysis was used.

Studies were rated as “fair” if any or all of the following problems occurred, without the fatal flaws noted in the “poor” category below: In general, comparable groups were assembled

initially but some question remained as to whether some (although not major) differences occurred with follow-up; measurement instruments were acceptable (although not the best) and generally applied equally; some but not all important outcomes were considered; and some but not all potential confounders were accounted for. In addition, for RCTs, intention-to-treat analysis was used.

Studies were graded “poor” if any of the following fatal flaws existed: Groups assembled initially were not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments was used or not applied at all equally among groups (including not masking outcome assessment); and key confounders were given little or no attention. For RCTs, intention-to-treat analysis was lacking.

## Assessment of Applicability

Applicability of findings in this review will be assessed within the EPICOT framework (Evidence, Population, Intervention, Comparison, Outcome, Time stamp68). Selected studies were assessed for relevance against target populations, interventions of interest and outcomes of interest.

## Data Synthesis

This evidence review did not incorporate quantitative data synthesis using meta-analysis. Rather, the synthesis emphasized comparative studies sorted by interventions, specific patient characteristics, specific outcomes and status relative to the evidence hierarchy/study quality assessment.

## Rating the Body of Evidence

The system used for rating the strength of the overall body of evidence was developed by AHRQ69 for the EPC Methods Guide, based on a system developed by the GRADE Working Group.70 This system explicitly addresses the following domains: risk of bias, consistency, directness and precision. Grade of evidence strength was classified into the following four categories:

▪ High: High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
▪ Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
▪ Low: Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
▪ Insufficient: Evidence is either unavailable or does not permit estimation of an effect.