# INTRODUCTION

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report regarding on-label and off-label uses of bone morphogenetic protein from the Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the following Evidence-based Practice Center (EPC): Blue Cross and Blue Shield Association Technology Evaluation Center (via Duke EPC Sub-Contract Number: HHSA 290 2007 10066 I). The specific questions to be addressed are described at the end of the Introduction.

## Biology of Bone Repair

Bone remodeling is a complex process by which old bone is continuously replaced by new tissue, requiring the interaction of various cell phenotypes and regulation by a variety of factors. Remodeling allows bone to maintain its shape, quality and size of the skeleton through the repair of microfractures and modifications of structure in response to stress and other biomechanical forces.1,2

### Types and Composition of Bone

Two types of bone are found in the normal mature human skeleton: cortical and trabecular. Cortical bone is dense and compact and comprises 80 percent of the human skeleton. It has a slow turn over rate, a high resistance to bending and torsion, and constitutes the outer portion of all skeletal structures. Cortical bone provides mechanical strength and protection, but can participate in metabolic responses, especially during prolonged mineral deficit.

Trabecular bone is 20 percent of the skeletal mass, but 80 percent of the bone surfaces. It is less dense, more elastic and has a higher turnover rate than cortical bone. Trabecular bone provides mechanical support to the vertebrae and provides mineral supplies during acute deficiency states.1,2

Bone is composed of cells and an extracellular matrix. The extracellular matrix is comprised of type I collagen fibers and noncollagenous proteins, and it represents approximately 90% of the organic bone tissue. Cells, osteoblasts, osteocytes and osteoclasts work within the matrix to perform their functions.

Osteoblasts are derived from mesenchymal stem cells and occupy spaces called lacunae. They are responsible for bone formation. Upon cell activation, they secrete extracellular matrix around themselves forming new bone matrix called osteoid. These are nondividing cells and connect to other cells via gap junctions. Upon termination of bone matrix synthesis, osteoblasts either undergo cell death by apoptosis or differentiate into osteocytes or bone-lining cells, which are inactive osteoblasts. Osteocytes form a network of thin canaliculi, permeating the entire bone matrix. The exact function of these cells remains unclear. It is likely that osteocytes respond to bone tissue strain and enhance bone-remodeling activity by recruiting osteoclasts to sites where bone remodeling is required,3 but there is no direct evidence for osteocytes signaling to other cells. Bone formation begins with irregular-shaped pieces of bone called a spicule. These form into trabeculae when osteoblasts deposit additional matrix onto the surface of the spicule. Eventually, a network of trabeculae forms a spongy bone (cancellous bone). Osteoblasts on the surface of the trabeculae continue to add new layers of bone. Compact bones are formed in a process called bone remodeling, which involves the concerted action of osteoblasts and osteoclasts that have the capacity to erode bone surfaces (bone resorption).

Osteoclasts are the bone-lining cells derived from hematopoietic stem cells; they are multinucleated cells whose function is bone resorption. They reside in bone resorption pits (Howship’s lacunae). Osteoclasts resorb bone by acidification and proteolysis of the bone matrix and the hydroxyapatite crystals encapsulated within the sealing zone. Osteoclast function is regulated by locally acting cytokines and by systemic hormones. Parathyroid hormone stimulates receptors on osteoblasts that activate osteoclastic bone resorption.

### Fracture Healing

A fracture is a broken bone. The rate of fracture healing (union) depends on many factors, including the presence of an adequate blood supply and achieving mechanical stability of the fracture. While immobilization and surgery may facilitate healing, a fracture ultimately heals through physiological processes occurring in three distinct but overlapping stages: 1) the early inflammatory stage; 2) the repair stage; and 3) the late remodeling stage.4,5

In the inflammatory stage, a hematoma develops within the fracture site during the first few hours and days. Inflammatory cells (macrophages, monocytes, lymphocytes, and polymorphonuclear cells) and fibroblasts infiltrate the bone under prostaglandin mediation. This results in the formation of granulation tissue, ingrowth of vascular tissue, and migration of mesenchymal cells. Cancellous bone and muscle provide the primary nutrient and oxygen supply of this early process. The use of anti-inflammatory or cytotoxic medication during this first week may alter the inflammatory response and inhibit bone healing.

Repair begins as fibroblasts lay down a stroma that helps support vascular ingrowth. As vascular ingrowth progresses, a collagen matrix is laid down while osteoid is secreted and subsequently mineralized, which leads to the formation of a soft callus around the repair site. This callus is very weak in the first four to six weeks of the healing process and requires adequate protection in the form of bracing or internal fixation. Eventually, the callus ossifies, forming a bridge of woven bone between the fracture fragments. Failing to provide proper immobilization, ossification of the callus may not occur, and an unstable fibrous union may develop instead.

The healing process is completed during the remodeling stage in which the healing bone is restored to its original shape, structure, and mechanical strength. Remodeling of the bone occurs slowly over months to years and is facilitated by mechanical stress placed on the bone. As the fracture site is exposed to an axial loading force, bone is generally laid down where it is needed and resorbed from where it is not needed. Adequate strength is typically achieved in three to six months.

### Regulation of Bone Healing

When a fracture occurs, fracture healing restores tissue to its original physical and mechanical properties influenced by both systemic and local factors. Bone integrity seems to be controlled by hormones and other proteins secreted by hemopoietic bone marrow cells and bone cells.1,2 Parathyroid hormone (PTH) is the most important regulator of calcium homeostasis. Intermittent PTH stimulates bone formation and bone resorption when secreted continuously.6 Thyroid hormones stimulate both bone formation and resorption. Calcitriol by enhancing intestinal calcium and phosphorus absorption promotes bone mineralization. Growth hormones IGF-1 and IGF-2 are important for skeletal growth, specifically at the cartilaginous end plates and are among the major determinates of adult mass through their effect on regulation of bone formation and resorption. Glucocorticoids are essential for osteoblasts maturation and they sensitize bone cells to regulators of bone remodeling. Gonadal steroids (estrogen and testosterone) play key roles in maintaining skeletal mass. They suppress the production of signals promoting osteoclastogenesis, and stimulate fracture healing through a receptor mediated mechanism.

The molecular control of bone remodeling has been studied extensively and is well understood. On the other hand, local signaling in bones is far less understood and recent studies have indicated that signals directly between bone cells are highly important for the control of bone remodeling.7–9 In addition to these local signals, other cellular systems, such as the sympathetic nervous system, hematopoietic stem cells, the immune system, the vasculature and even articular cartilage, also appear to exert control over bone turnover.10

### Factors Affecting Bone Healing

Local anatomic factors such as soft tissue injury, interruption of the local blood supply, and interposition of soft tissue at the fracture site can have a dramatic effect on the ability of bone to heal. Likewise, bone death from radiation, thermal, or chemical burns can affect healing. Infection causes necrosis and edema, taking energy away from fracture healing.

Systemic factors such as nutrition, smoking, diabetes, and older age can all interfere with the fracture healing response. Nutritional deficiencies have an impact on bone healing due to the increase in metabolism requirements during fracture healing. The influence of malnutrition seems to be seen on the later phase of callus formation. The lack of nutritional contribution does not cause significant delay in union, but in the mechanical strength of the boney callus thus requiring a longer period before mineralization is completed.11 A significantly decreased union rate has been consistently demonstrated among tobacco users.12–14 During the repair stage the presence of nicotine can inhibit capillary ingrowth,15–18 decreasing the vascularization of the fracture site. Diabetes mellitus is often associated with delayed fracture union, due to both vascular and neuropathy problems. In diabetic patients, a clear reduction in the formation of collagen in the bone callus and a marked reduction of the cells involved in the repair process have been noted.19

Potentially, the largest influence on a person’s ability to heal a fracture is age. 20 The aging process and osteoporosis have a profound impact and while not all elderly are osteoporotic, it is generally accepted that if one lives long enough, one will become osteoporotic.20 Osteoporosis is the result of progressive catabolic changes, mainly but not exclusively, occurring in the skeleton, that alter the balance of bone remodeling. Bone strength depends on bone size and density; bone density is a function of the amount of calcium, phosphorus and other minerals that are contained within bone. Depletion of these minerals below normal levels reduces bone strength, so they eventually lose their internal supporting structure. Other factors, such as hormone levels, also affect bone density. In women, when estrogen levels drop at menopause, bone loss increases dramatically. In men, low estrogen and testosterone levels can cause a loss of bone mass.

Osteoporosis increases the risk of fracture.21,22 Fractures of the femoral neck, vertebrae, and distal radius as a result of falls and low-energy trauma occur almost exclusively in the geriatric population, being hallmarks of osteoporosis.23,24 Histological and radiological measures show that age-related decreases in bone quality can at least partially explain the high fracture incidence in those with osteoporosis.25 Additionally, the repair mechanisms are compromised with age. As a consequence with increasing age there is an increase in fracture incidence and a compromised ability to heal those fractures.20

### Bone Grafts

The choice of bone material for enhancing bony union has important clinical implications. Currently, autogenous iliac crest bone graft is considered the gold standard graft for bone induction.26 Since the bone is taken from the patient, it is both histocompatible and non-immunogenic,27 and it has the three properties required for bone formation: osteogenicity, osteoinductivity, and osteoconductivity. A material is osteogenic if it causes bone formation due to the implantation of viable cells, osteoinductive if it induces bone to form in an extraskeletal site, such as within skeletal muscle, and osteoconductive if due to its composition, shape or surface texture, it promotes bone formation along its surface when it is placed in bone.28 These properties are relative and understanding the bioactive properties of a material is essential in determining its appropriateness for a given clinical application.

While it represents the current gold standard, the use of autograft bone has potentially substantial morbidities at the harvest site, generally the iliac crest.13 These morbidities include moderate-to-severe, sometimes prolonged pain; deep infection; adjacent nerve and artery damage; and increased risk of stress fracture. Although there may be slight differences between autograft and allograft sources in the postoperative rate of union, clinical studies demonstrate similar rates of postoperative fusion (90–100 percent) and satisfactory outcomes for single-level, anterior-plated anterior cervical discectomy and fusion, using either bone source.14,29–31 There is a limited supply of autogenous bone, which usually becomes important if the patient has had previous bone grafts and therefore no longer has an adequate quantity requiring bone to be harvested from sites other than the iliac crest or supplemented with bone graft substitutes.32 Morbidity at the donor site has been commonly reported and seems to be enduring. Complication rates are variable but have been reported to occur anywhere from 9–49 percent of the time,26,33–41 with pain at the harvest site still present in 26 percent of patients at 48 months post-harvest.42 In the case of anterior cervical fusion surgery, pain at the donor site often overshadows the pain at the primary surgical site.42 The high rates of donor site pain have been a major force behind the search for alternatives to autograft.

Allograft bone, bone from another person, represents approximately one-third of all bone grafts used in North America.43 Allograft bone has osteoconductive and weak osteoinductive properties representing an attractive alternative to the morbidity associated with an autograft. There are several drawbacks, including a small (albeit, unproven) risk of infectious disease transmission; possible immunological reaction to the allograft, and possible limited commercial availability of appropriate graft material.12 Demineralized bone matrix (DBM) is made from allograft bone and is a composite of collagen, noncollagenous proteins and growth factors.26 The extensive processing required makes this the least immunogenic of all types of allograft bone.

Thus, the choice of graft material involves a trade-off between the risks specific to autograft harvest versus those specific to use of allograft material. This choice is usually left to the patient, based on thorough explanation and discussion of the relative risks and benefits with the surgeon.

## Bone Morphogenetic Proteins (BMP)

Bone morphogenetic proteins (BMP) were discovered in 1965 by Urist; he also was the first to describe osteoinduction.44 Urist observed new local bone formation in rodents after they were given intramuscular implantation of bone cylinders decalcified with hydrochloric acid. This phenomenon was attributed to BMP, a protein in the bone matrix. Having realized the osteoinductive properties of BMPs and having identified their genetic sequences, recombinant gene technology has been used to produce BMPs for clinical application––most commonly, as alternatives or adjuncts in the treatment of cases in which fracture healing is compromised.

BMPs are members of the family of the larger transforming growth factors-beta (TGF-beta) and play an important role in embryonic development including brain45 and bone formation.46,47 At present, some 20 different BMPs have been identified, but only BMPs 2, 4, 6, and 7 have been shown to have significant osteoinductive properties. BMP signal transduction is induced via interaction with the heterodimeric complex of two transmembrane serine/threonine kinase receptors.48,49 BMPs encourage bone production through two pathways. They recruit mesenchymal cells from surrounding tissue and differentiate the cells into either osteoblasts that make bone directly or cartilage cells which subsequently change to bone cells.26

Recombinant human bone morphogenetic proteins (rhBMP) are delivered to the bone grafting site as part of a surgical procedure; a variety of carrier and delivery systems has been investigated. Carrier systems, which are absorbed over time, function to maintain the concentration of the rhBMP at the treatment site, provide temporary scaffolding for osteogenesis, and prevent extraneous bone formation. Carrier systems have included inorganic material, synthetic polymer, natural polymers, and bone allograft. The rhBMP and carrier may be inserted via a delivery system, which may also function to provide mechanical support. For interbody spinal fusion, delivery systems include interbody fusion cages, whereas pedicle and screw devices are more commonly used for intertransverse fusion. Therefore, the carrier and delivery system are important variables in the clinical use of rhBMPs. For example, different clinical applications, such as long bone non-union, or interbody or intertransverse fusion, may require different dosages of rhBMP with different carriers and delivery systems. Therefore, the results of one clinical application cannot always be extrapolated to others.

Currently, two rhBMPs and four associated carrier/delivery systems (one of which has been voluntarily withdrawn from the U.S. market) have received approval as devices from the U.S. Food and Drug Administration (FDA). The InFUSE® system (Medtronic Sofamor Danek, Inc.) consists of rhBMP2 on an absorbable collagen sponge carrier.50–53 Osteogenic Protein 1 or OP-1® (Stryker Biotech) consists of rhBMP-7 and bovine collagen, which is reconstituted with saline to form a paste.54,55 The addition of carboxymethylcellulose forms putty.

### Clinical Applications of BMP

Clinical applications of BMP2 (InFUSE®) and BMP7 (OP-1®) products according to FDA-approved marketing labels are presented in Table 1 by device.

Table 1 Indications in FDA-Approved Marketing Labels for BMP Devices

Product/FDA Approval Mechanism | Carrier/scaffold | Indication(s) | Comments
InFUSE® (50, 51) PMA (P000054; tibial) (P050053; dental) | Collagen sponge | 1) Treating acute, open tibial shaft fractures that have been stabilized with [intramedullary] nail fixation after appropriate wound management. The device must be applied within 14 days after the initial fracture. 2) An alternative to autogenous bone graft for sinus augmentations, and for localized alveolar ridge augmentations for defects associated with extraction sockets
InFUSE® (52) PMA (P00058) | LT-Cage or Inter Fix Threaded Fusion devices | Spinal fusion procedures in skeletally mature patients with degenerative disc disease (DDD) at one level from L4-S1. DDD is defined as discogenic back pain with degeneration of the disc confirmed by patient history and radiographic studies. These DDD patients may also have up to Grade I spondylolisthesis at the involved level. | Patients receiving the InFUSE Bone Graft/LT-Cage Lumbar Tapered Fusion Device should have had at least six months of nonoperative treatment prior to treatment with the InFUSE Bone Graft/LT-Cage device. The InFUSE Bone Graft/LT-Cage Lumbar Tapered Fusion Device is to be implanted via an anterior open or an anterior laparoscopic approach.
InFUSE® (53) HDE (H040004) | Mastergraft/CD HORIZON | Revision/repair of symptomatic, posterolateral lumbar spine pseudarthrosis Note: The HDE approval for this product was voluntarily withdrawn by Medtronic in early 2010. | This device is intended to “address a small subset of patients for whom autologous bone and/or bone marrow harvest are not feasible or are not expected to promote fusion” (i.e., patients who smoke or have diabetes). This device is indicated to treat two or more levels of the lumbar spine. Must be used with a posterior fixation device such as CD HORIZON spinal system.
OP-1 Implant® HDE (H010002) | N/A | Indicated for use as an alternative to autograft in recalcitrant long bone non-unions where use of autograft is unfeasible and alternative treatments have failed | Must be used with fixation including cast, external fixation, IM rod and internal plate
OP-1 Putty® HDE (H020008) | N/A | Indicated for use as an alternative to autograft in compromised patients requiring revision posterolateral (intertransverse) lumbar spinal fusion, for whom autologous bone and bone marrow harvest are not feasible or are not expected to promote fusion | Examples of compromising factors include osteoporosis, smoking and diabetes.

Abbreviations: FDA: U.S. Food and Drug Administration; HDE: Humanitarian Device Exemption; N/A: not applicable; PMA: Premarket Application

#### InFUSE®

InFUSE® (rhBMP-2) is available as a lyophilized powder in vials containing either 4.2 mg or 12 mg of protein. After reconstitution, both configurations result in the same concentration (1.5 mg/mL). After reconstitution, the solution should then be applied to the collagen sponge (“carrier”) provided, and should be used immediately.

In July 2002, the FDA approved via its Premarket Application (PMA) device approval process, the InFUSE® bone graft in conjunction with the LT-Cage Lumbar Tapered Fusion device for spinal fusion procedures via an anterior approach; the Agency has subsequently approved other interbody devices (e.g., Inter Fix RP Threaded Fusion device) for this use. The current specific indication is for spinal fusion procedures in skeletally mature patients with degenerative disc disease (DDD) at one level from L2-S1. DDD is defined as discogenic back pain with degeneration of the disc confirmed by patient history, function deficit, and/or neurological deficit and radiographic studies. These DDD patients may also have up to Grade I spondylolisthesis at the involved level or retrolisthesis. The InFUSE® Bone Graft/LT-Cage® devices are to be implanted via an anterior open or a laparoscopic approach. The InFUSE™ Bone Graft/Inter Fix® Threaded Fusion Device; and InFUSE® Bone Graft/Inter Fix® RP Threaded Fusion Device are to be implanted via an anterior open approach only. Patients should have had at least six months of nonoperative treatment prior to treatment with the InFUSE® Bone Graft/Interbody Fusion Device.

In April 2004, InFUSE® received PMA approval for treatment of acute, open fractures of the tibial shaft that have been stabilized with intramedullary (IM) nail fixation following appropriate wound management. In March 2007, the device received PMA approval as an alternative to autogenous bone grafts for sinus augmentations, and for localized alveolar ridge augmentations for defects associated with extraction sockets. In both cases, the device must be used with the absorbable collagen sponge carrier.

In October 2008, InFUSE® received FDA device approval via a special approval process called a humanitarian device exemption (HDE) for use as part of a three-part component system (InFUSE® bone graft plus Mastergraft Granules plus supplemental posterior fixation system, e.g., the CD HORIZON spinal system) for:

Symptomatic, posterolateral lumbar spine pseudoarthrosis among patients for whom autologous bone and/or bone marrow harvest are not feasible or are not expected to promote fusion, such as diabetics and smokers. The device is indicated to treat two or more levels in the lumbar spine. Patients receiving the InFUSE®/Mastergraft should be skeletally mature (≥ 21).

The HDE process is available to devices intended for fewer than 4,000 patients per year in the U.S.; as part of this process, the manufacturer is not required to demonstrate unequivocal benefit, but only “probable” benefit. It should be noted that the HDE approval was voluntarily withdrawn by Medtronic in early 2010 (Jason E. Kemner, Medtronic Inc. Spinal and Biologics, personal communication, May 7, 2010).

#### OP-1®

OP-1 Implant® is supplied as a vial containing one gram of the device as a dry powder comprised of rhBMP-7 and bovine bone collagen. OP-1 Putty® is provided as 2 units. Each unit is comprised of one 20-mL vial of OP-1® Implant containing one gram of a sterile dry powder consisting of bovine collagen and OP-1® and a 10 mL vial of putty additive containing 230 mg of sterile carboxymethylcellulose. One vial of OP-1® Implant and one vial of putty additive must be combined with sterile saline to produce one unit of OP-1® Putty. One unit of OP-1 Putty is used for each side of the spine.55

OP-1® has received two FDA approvals through the HDE approval process. In October 2001, OP-1 Implant® received HDE approval for “…use as an alternative to autograft in recalcitrant long bone non-unions where use of autograft is unfeasible and alternative treatments have failed.” In April 2004, OP-1 Putty® received HDE approval for “…use as an alternative to autograft in compromised patients requiring revision posterolateral (intertransverse) lumbar spinal fusion, for whom autologous bone and bone marrow harvest are not feasible or are not expected to promote fusion. Examples of compromising factors include osteoporosis, smoking and diabetes.”

Stryker Biotech recently sought FDA permission to expand use of OP-1 Putty® to include use in uninstrumented posterolateral lumbar spinal fusion for the treatment of lumbar spondylolisthesis. In March 2009, an FDA advisory committee voted 6-1 against recommending the expanded approval.56

### Safety

OP-1® and InFUSE® Bone Graft are contraindicated in patients who are pregnant, who may be allergic to any of the materials contained in the devices, who have an infection near the area of the surgical incision, who have had a tumor removed from the area of the implantation site or currently have a tumor in that area, or who are skeletally immature.

In July 2008, the FDA issued a public health notification regarding life-threatening complications associated with recombinant human bone morphogenetic protein in cervical spine fusion.57 The FDA has received reports of complications with the use of rhBMP in cervical spine fusion. These complications were associated with swelling of neck and throat tissue, which resulted in compression of the airway and/or neurological structures in the neck. Some reports describe difficulty swallowing, breathing or speaking. Severe dysphagia following cervical spine fusion using rhBMP products has also been reported in the literature. As stated in the public health notification, the safety and effectiveness of rhBMP in the cervical spine have not been demonstrated, and these products are not approved by FDA for this use.

Few documented adverse events can be attributed to BMP. Nonetheless, certain complications and safety issues are of concern. Adverse events that have been reported include but are not limited to inflammation, ectopic bone formation, infection, immune responses, vertebral osteolysis and vertebral edema.50–54

### Clinical Guidelines

The literature search conducted for this technology assessment did not identify any evidence-based guidelines for the use of any BMP device.

### Summary

Bone remodeling is a complex process by which old bone is continuously replaced by new tissue. Remodeling allows bone to maintain its shape, quality and size of the skeleton through the repair of microfractures and modifications of structure in response to stress and other biomechanical forces.1,2 After a fracture both local and systemic factors affect bone healing or fusion. Age may be the factor exerting the largest influence on bone fusion.

Under certain circumstances it may be necessary to enhance the likelihood of fusion. Currently, autogenous iliac crest bone graft is considered the gold standard graft for bone induction.26 However, the use of autograft bone has potentially substantial morbidities at the harvest site, generally the iliac crest.13 Allograft bone, bone from another person, represents approximately one-third of all bone grafts used in North America.43 Allograft bone has osteoconductive and weak osteoinductive properties representing an attractive alternative to the morbidity associated with an autograft, but this is not without some risk including a small (albeit, unproven) risk of infectious disease transmission; possible immunological reaction to the allograft, and possible limited commercial availability of appropriate graft material of infection.

BMPs are members of the family of the larger transforming growth factors-beta (TGF-beta). At present, some 20 different BMPs have been identified, but only BMPs 2, 4, 6, and 7 have been shown to have significant osteogenic properties. Currently, two rhBMPs and four associated carrier/delivery systems have received approval via different approval mechanisms from the. FDA. The InFUSE® system consists of rhBMP2 on an absorbable collagen sponge carrier and was approved for marketing via the PMA process for acute, open shaft fractures, lumbar spinal fusion (used with specific approved cage devices) or sinus or alveolar ridge augmentation; the product was approved for use via HDE for lumbar spine pseudarthrosis (with Mastergraft/CD HORIZON spinal system). OP-1® products consist of rhBMP7 and bovine collagen, which is reconstituted with saline to form a paste or with the addition of carboxymethylcellulose forms putty. These products were approved for use via HDE for long bone non-union and revision lumbar spinal fusion.

Few documented adverse events can be directly attributed to BMP. Adverse events that have been reported include but are not limited to inflammation, ectopic bone formation, infection, immune responses, vertebral osteolysis and vertebral edema.

## Key Questions to be Addressed by this Technology Assessment

Key Question 1. What evidence of improved outcomes is associated with the on-label use of InFUSE for fusion of the lumbar-sacral spine?

Key Question 2. What evidence of improved outcomes is associated with the on-label use of OP-1 for fusion in the lumbar spine?

Key Question 3. What evidence of improved outcomes is associated with the on-label use of OP-1 in recalcitrant long bone non-unions?

Key Question 4. What evidence of improved outcomes is associated with the on-label use of InFUSE for the treatment of acute, open shaft fractures?

Key Question 5. What is the level of evidence and summary of evidence for the on-label use of InFUSE for sinus augmentation?

Key Question 6. For which indications are there clinical studies in which BMP is used off-label? In such studies, what is the evidence of the effectiveness of BMP?

Key Question 7. What evidence of adverse events is associated with (a) the on-label use of BMP and (b) the off-label use of BMP? And, at what dosage and administration do such adverse events occur?

Key Question 8. What is the quality of reporting of adverse events in publications? Provide summary to support conclusion.

Key Question 9. What is the incremental cost effectiveness of the use of BMP for spinal fusion and open tibial fracture?

Key Question 10. What is the age distribution of study patients compared to the Medicare population (age 65 and older)? What are the issues associated with generalizing evidence from trials to the age 65+ Medicare populations (such as co-morbid conditions in the Medicare population and this population’s susceptibility to adverse events).