# Excluded Studies

## BMP General ProCite Review Guide

Instructions: In field 12, enter Retrieval code after initial screen, and Selection Decision code after full article review. For those coded DNG in first review, or EXC in second review, enter 1-2 Full Review codes as initial entries in field 42, to explain basis of decision. Next, enter at least 1 Full Review code of each other type (as many as apply). Additional codes not needed for ANM, LTR. For COM, EDT, GUI, NRA add code for general content, from IV, V, VI, and VII as appropriate.

[underlined: Retrieval Code] (field 12)

DNG do not retrieve full copy

GET retrieve full copy

UNC uncertain; needs check by second reviewer

[underlined: Selection Decision Code]

(after reviewing retrieved article, enter into field 12)

INC include

EXC exclude (with codes for exclusion reasons)

[underlined: Full Review Codes] (field 42)

I. Key Question (KQ) Codes

NRQ not relevant question (note if ANM, NDE, NRD, NRO, NRT)

Q1-5 on-label efficacy

Q6 off-label efficacy

Q7 adverse effects

Q8 Quality of adverse effects reporting

Q9 Cost effectiveness

Q10 Age distribution

Q#? unclear KQ relevance

II. Study Design Codes

ADB administrative database

ANM animal study

CEA cost/cost-effectiveness analysis

CCS case-control study

COH cohort study

COM commentary

CR case report (n≤5)

CS case series

D? design unclear/possibly relevant

EDT editorial

FLA Foreign language article

GUI guideline

INV in vitro

LTR letter

MA meta-analysis

NAB no abstract

NDE not relevant design

NPD no primary data

NRA narrative review article

NRD not relevant disease

PI phase I trial

PII phase II trial

PRO prospective single-arm

QEX quasi-experimental study

RCT randomized controlled trial

REG registry

RET retrospective study

SR systematic review

III. Sample Size Code (single-arm only)

FEW n < 10

N10 10 ≤ n < 25

N25 25 ≤ n < 50

N50 50 ≤ n < 100

N100 n ≥ 100

N? n unclear

IV. Intervention Codes

BMP2 Infuse

BMP7 OP-1

BMP? Not specified in abstract

OTH Other

V. Comparator Codes

ABG Autologous bone graft

ALG Allogeneic bone graft

BGU Bone graft, unspecified

BMA Bone marrow aspirate

COL Collagen

COM? Comparator unclear

COR Coralline

CPH Calcium phosphate

CSF Calcium sulfate

DBM Demineralized bone matrix

ESW Extracorporeal shock wave

FIX Fixation alone

GTX Gene therapy

LPU Low-intensity pulsed ultrasound

NBS Nonbiological substance

PEF Pulsed electric field

PRP Platelet-rich plasma

PTH Parathyroid hormone

SUR Surgery alone

TCP Tricalcium phosphate

TEN Tissue engineering

VI. Basic Disease Codes

ALV Alveolar ridge

BDS Bone density study

CRN Craniofacial

CSP Cervical spine

DEL Delayed union

FRC Fracture

GEX Gene expression study

HST Bone healing study

LSP Lumbar spine

MAX Maxillofacial

NON Non-union

OTH Other site

PSD Pseudarthrosis

SIN Sinus augmentation

SPN Spine (not specified)

VII. Disease Code Modifiers

ANK Ankle

ANT Anterior spinal approach

DDD Degenerative disc disease

FEM Femur

FIB Fibula

FIN Finger

FOT Foot

HIP Hip

HND Hand

HUM Humerus

MAN Mandible

MLC Multi-level cervical spine

MLL Multi-level lumbar spine

PAL Palate

PEL Pelvis

POS Posterior spinal approach

RAD Radial

SCH Scaphoid

SLC Single-level cervical spine

SLL Single-level lumbar spine

SPN1 Spondolysthesis grade 1

SPN2 Spondolysthesis > grade 1

STN Sternum

TIB Tibia

TLIF Transforaminal LIF

TRM Traumatic

ULN Ulna

VIII. Label Status

LBL? Unclear if on- or off-label

OFL Clearly off-label use

ONL Clearly on-label use

IX. Outcome Codes

ADL Activity of daily living

AEF Adverse effect

ECT Ectopic bone

FCN Functional

MOB Mobility

OST Osteolysis

PER Perioperative outcomes

PN Pain

QOL Quality of life

RAD Radiographic healing

SIV Secondary interventions

WTB Weight bearing

Ackerman SJ, Mafilios MS, Polly DW Jr. Economic evaluation of bone morphogenetic protein versus autogenous iliac crest bone graft in single-level anterior lumbar fusion: an evidence-based modeling approach. Spine (Phila Pa 1976). 2002;27(16 Suppl 1):S94-S99. [pmid: 12205426]. Rec # 11840 Notes: CEA
Alt V, Chhabra A, Franke J, Cuche M, Schnettler R, Le Huec JC. An economic analysis of using rhBMP-2 for lumbar fusion in Germany, France and UK from a societal perspective. Eur Spine J. 2009;18(6):800-806. [pmid: 19301041]. Rec # 550 Notes: CEA
Alt V, Donell ST, Chhabra A, Bentley A, Eicher A, Schnettler R. A health economic analysis of the use of rhBMP-2 in Gustilo-Anderson grade III open tibial fractures for the UK, Germany, and France. Injury. 2009. Rec # 140 Notes: CEA
Alt V, Eicher A, Bitschnau A, Schnettler R. Cost-benefit analysis of the use of rhBMP-2in open tibial fractures. Savings from a health insurer's perspective: Kosten-nutzen-betrachtung des einsatzes vonrhBMP-2bei offenen tibiafrakturen. Nettoeinsparungen aus krankenkassensicht erzielbar. Unfallchirurg. 2006;109(6):463-470. Rec # 18930 Notes: CEA FLA
Alt V, Haas H, Rauschmann MA, et al. Health-economic considerations for the use of BMP-2 for spinal surgery in Germany: Gesundheitsokonomische uberlegungen fur den einsatz des knochenwachstumsfaktorsBMP-2 in der wirbelsaulenchirurgie fur das Deutsche gesundheitssystem. Z. Orthop. Ihre Grenzgeb. 2006;144(6):577-582. [pmid: 17187331]. Rec # 18580 Notes: CEA FLA
Alt V, Heissel A. Economic considerations for the use of recombinant human bone morphogenetic protein-2 in open tibial fractures in Europe: the German model. Curr Med Res Opin. Suppl 1. 2006;22:S19-S22. [pmid: 16882366]. Rec # 5920 Notes: CEA
Axelsson P, Johnsson R, Stromqvist B. Radiostereometry in lumbar spine research. Acta Orthop Suppl. 2006;77(323):1-42. [pmid: 17299895]. Rec # 4980 Notes: NRQ
Barrios JMR, Collado FA, Contreras DS, Tudela LL. Economic evaluation of the rhBMP-2(Inductos) in the treatment of vertebral fusion for chronic low back pain in Spain: Evaluacion economica de larhBMP-2(Inductos(registered trademark)) en el tratamiento de lafusionvertebral para la lumbalgia cronica en Espana. Pharmacoecon. Span. Res. Artic. 2008;5(4):109-118. Rec # 16930 Notes: CEA
Bauer TW. An overview of the histology of skeletal substitute materials. Arch Pathol Lab Med. 2007;131(2):217-224. [pmid: 17284105]. Rec # 5000 Notes: NRA
Benglis D, Wang MY, Levi AD. A comprehensive review of the safety profile of bone morphogenetic protein in spine surgery. Neurosurgery. 2008;62(5 Suppl 2):ONS423-ONS431. discussion ONS431. [pmid: 18596525]. Rec # 2060 Notes: SR
Bianchi J, Fiorellini JP, Howell TH, et al. Measuring the efficacy of rhBMP-2 to regenerate bone: a radiographic study using a commercially available software program. Int J Periodontics Restorative Dent. 2004;24(6):579-587. [pmid: 15626320]. Rec # 8960 Notes: NDE
Biasibetti A, Salomone C, Di Gregorio A, Navas MM, Gallinaro P. Clinical treatment with bone morphogenetic proteins (BMP-7; OP-1). The Journal of Bone and Joint Surgery (Proceedings). Suppl I. 2006;88-B:130-d. Rec # 16240 Notes: Abstract
Bibbo C. Talar fractures. Curr. Orthop. Pract. 2008;19(3):234-241. Rec # 17570 Notes: NRA
Bishop GB, Einhorn TA. Current and future clinical applications of bone morphogenetic proteins in orthopaedic trauma surgery. Int Orthop. 2007;31(6):721-727. [pmid: 17668207]. Rec # 3950 Notes: NRA
Block MS, Achong R. Bone morphogenetic protein for sinus augmentation. Atlas Oral Maxillofac Surg Clin North Am. 2006;14(1):99-105. [pmid: 16522512]. Rec # 6850 Notes: NRA
Burkus JK, Dorchak JD, Sanders DL. Radiographic assessment of interbody fusion using recombinant human bone morphogenetic protein type 2. Spine (Phila Pa 1976). 2003;28(4):372-377. [pmid: 12590213]. Rec # 11280 Notes: Subset of REC# 11160
Burkus JK, Gornet MF, Schuler TC, Kleeman TJ, Zdeblick TA. Six-year outcomes of anterior lumbar interbody arthrodesis with use of interbody fusion cages and recombinant human bone morphogenetic protein-2. J Bone Joint Surg Am. 2009;91(5):1181-1189. [pmid: 19411467]. Rec # 330 Notes: Postmarketing follow-up, large dropout
Burkus JK, Heim SE, Gornet MF, Zdeblick TA. The effectiveness of rhBMP-2 in replacing autograft: an integrated analysis of three human spine studies. Orthopedics. 2004;27(7):723-728. [pmid: 15315042]. Rec # 9380 Notes: NRA
Burkus JK, Sandhu HS, Gornet MF. Influence of rhBMP-2 on the healing patterns associated with allograft interbody constructs in comparison with autograft. Spine (Phila Pa 1976). 2006;31(7):775-781. [pmid: 16582851]. Rec # 6640 Notes: Different analysis of same patients as REC# 8320
Burkus JK, Transfeldt EE, Kitchel SH, Watkins RG, Balderston RA. Clinical and radiographic outcomes of anterior lumbar interbody fusion using recombinant human bone morphogenetic protein-2. Spine (Phila Pa 1976). 2002;27(21):2396-2408. [pmid: 12438990]. Rec # 11510 Notes: Subset of REC# 8320
Burkus JK. Bone morphogenetic proteins in anterior lumbar interbody fusion: old techniques and new technologies. Invited submission from the Joint Section Meeting on Disorders of the Spine and Peripheral Nerves, March 2004. J Neurosurg Spine. 2004;1(3):254-260. [pmid: 15478362]. Rec # 9160 Notes: NRA
Cahill KS, Chi JH, Day A, Claus EB. Prevalence, complications, and hospital charges associated with use of bone-morphogenetic proteins in spinal fusion procedures. JAMA. 2009;302(1):58-66. [pmid: 19567440]. Rec # 110 Notes: CEA
Calori GM, D'Avino M, Tagliabue L, Albisetti W, d'Imporzano M, Peretti G. An ongoing research for evaluation of treatment with BMPs or AGFs in long bone non-union: protocol description and preliminary results. Injury. Suppl 3. 2006;37:S43-S50. [pmid: 16963360]. Rec # 5720 Notes: Preliminary study
Carlisle E, Fischgrund JS. Bone morphogenetic proteins for spinal fusion. Spine J. 2005;5(6 Suppl):240S-249S. [pmid: 16291119]. Rec # 7580 Notes: NRA
Carreon LY, Glassman SD, Djurasovic M, et al. RhBMP-2 versus iliac crest bone graft for lumbar spine fusion in patients over 60 years of age: a cost-utility study. Spine (Phila Pa 1976). 2009;34(3):238-243. [pmid: 19179918]. Rec # 830 Notes: CEA
Cochran DL, Jones AA, Lilly LC, Fiorellini JP, Howell H. Evaluation of recombinant human bone morphogenetic protein-2 in oral applications including the use of endosseous implants: 3-year results of a pilot study in humans. J Periodontol. 2000;71(8):1241-1257. [pmid: 10972640]. Rec # 14030 Notes: CS
Cook SD, Barrack RL, Shimmin A, Morgan D, Carvajal JP. The use of osteogenic protein-1 in reconstructive surgery of the hip. J Arthroplasty. 2001;16(8 Suppl 1):88-94. [pmid: 11742457]. Rec # 12700 Notes: NRA
Csimma C, Swiontkowski MF. Large clinical trials in musculoskeletal trauma: are they possible? Lessons learned from the international study of the use of rhBMP-2 in open tibial fractures. J Bone Joint Surg Am. 2005;87(1):218-222. [pmid: 15634835]. Rec # 8950 Notes: NRA
Daentzer D. The efficacy ofrhBMP-2for posterolateral lumbarfusionin smokers: Comment: Die wirksamkeit vonrhBMP-2auf die posterolumbalefusionbei rauchern. Z. Orthop. Unfallchir. 2007;145(5):552. Rec # 18010 Notes: FLA
Dahabreh Z, Calori GM, Kanakaris NK, Nikolaou VS, Giannoudis PV. A cost analysis of treatment of tibial fracture nonunion by bone grafting or bone morphogenetic protein-7. Int Orthop. 2008. Rec # 1090 Notes: CEA
Dahabreh Z, Dimitriou R, Giannoudis PV. Health economics: a cost analysis of treatment of persistent fracture non-unions using bone morphogenetic protein-7. Injury. 2007;38(3):371-377. [pmid: 17070526]. Rec # 5370 Notes: CEA
De Long WG Jr, Einhorn TA, Koval K, et al. Bone grafts and bone graft substitutes in orthopaedic trauma surgery. A critical analysis. J Bone Joint Surg Am. 2007;89(3):649-658. [pmid: 17332116]. Rec # 4900 Notes: NRA
Desmyter S, Goubau Y, Benahmed N, de Wever A, Verdonk R. The role of bone morphogenetic protein-7 (Osteogenic Protein-1) in the treatment of tibial fracture non-unions. An overview of the use in Belgium. Acta Orthop Belg. 2008;74(4):534-537. [pmid: 18811040]. Rec # 1560 Notes: Survey, CS
Dickerman RD, Reynolds AS, Morgan BC, Tompkins J, Cattorini J, Bennett M. rh-BMP-2 can be used safely in the cervical spine: dose and containment are the keys!. Spine J. 2007;7(4):508-509. [pmid: 17521966]. Rec # 4310 Notes: COM
Dimar JR, Glassman SD, Burkus KJ, Carreon LY. Clinical outcomes and fusion success at 2 years of single-level instrumented posterolateral fusions with recombinant human bone morphogenetic protein-2/compression resistant matrix versus iliac crest bone graft. Spine (Phila Pa 1976). 2006;31(22):2534-2539. discussion 2540. [pmid: 17047540]. Rec # 5480 Notes: Subset of REC# 250
Dimitriou R, Dahabreh Z, Katsoulis E, Matthews SJ, Branfoot T, Giannoudis PV. Application of recombinant BMP-7 on persistent upper and lower limb non-unions. Injury. Suppl 4. 2005;36:S51-S59. [pmid: 16291324]. Rec # 7550 Notes: CS NDE
Dinopoulos H, Giannoudis PV. (iv) The use of bone morphogenetic proteins (BMPs) in long-bone non-unions. Curr. Orthop. 2007;21(4):268-279. Rec # 18100 Notes: NRA
Evans RO, Goldberg JA, Bruce WJ, Walsh W. Reoperated clavicular nonunion treated with osteogenic protein 1 and electrical stimulation. J Shoulder Elbow Surg. 2004;13(5):573-575. [pmid: 15383819]. Rec # 9260 Notes: CR
Friedlaender GE. Osteogenic protein-1 in treatment of tibial nonunions: current status. Surg Technol Int. 2004;13:249-252. [pmid: 15744697]. Rec # 8700 Notes: NPD
Garrison K, Shemilt I, Donell S, et al. Bone morphogenetic protein (BMP) forfracturehealing in adults. Cochrane Database Syst. Rev. 2008;(1). Rec # 17440 Notes: CEA
Garrison KR, Donell S, Ryder J, et al. Clinical effectiveness and cost-effectiveness of bone morphogenetic proteins in the non-healing of fractures and spinal fusion: a systematic review. Health Technol Assess. 2007;11(30):1-150. iii. iv. [pmid: 17669279]. Rec # 3930 Notes: SR CEA
Gautschi OP, Frey SP, Zellweger R. Bone morphogenetic proteins in clinical applications. ANZ J Surg. 2007;77(8):626-631. [pmid: 17635273]. Rec # 4030 Notes: NRA
Ghodadra N, Singh K. Recombinant human bone morphogenetic protein-2 in the treatment of bone fractures. Biologics. 2008;2(3):345-354. [pmid: 19707367]. Rec # 21290 Notes: NRA
Giannoudis P, Psarakis S, Kontakis G. Can we accelerate fracture healing? A critical analysis of the literature. Injury. Suppl 1. 2007;38:S81-S89. [pmid: 17383489]. Rec # 4720 Notes: NRA
Giannoudis PV, Kanakaris NK, Dimitriou R, Gill I, Kolimarala V, Montgomery RJ. The Synergistic Effect of Autograft and BMP-7 in the Treatment of Atrophic Nonunions. Clin Orthop Relat Res. 2009. Rec # 340 Notes: NDE
Giltaij LR. BMP-7 in orthopedic applications: A review. J. Musculoskelet. Res. 2002;6(1):55-62. Rec # 20750 Notes: NRA
Glassman SD, Carreon LY, Campbell MJ, et al. The perioperative cost of Infuse bone graft in posterolateral lumbar spine fusion. Spine J. 2008;8(3):443-448. [pmid: 17526436]. Rec # 4280 Notes: CEA
Glassman SD, Dimar JR 3rd, Burkus K, et al. The efficacy of rhBMP-2 for posterolateral lumbar fusion in smokers. Spine (Phila Pa 1976). 2007;32(15):1693-1698. [pmid: 17621221]. Rec # 4040 Notes: Subset of REC# 250
Glassman SD, Dimar JR, Carreon LY, Campbell MJ, Puno RM, Johnson JR. Initial fusion rates with recombinant human bone morphogenetic protein-2/compression resistant matrix and a hydroxyapatite and tricalcium phosphate/collagen carrier in posterolateral spinal fusion. Spine (Phila Pa 1976). 2005;30(15):1694-1698. [pmid: 16094268]. Rec # 8040 Notes: Subset of REC# 250
Groeneveld EH, van den Bergh JP, Holzmann P, ten Bruggenkate CM, Tuinzing DB, Burger EH. Histomorphometrical analysis of bone formed in human maxillary sinus floor elevations grafted with OP-1 device, demineralized bone matrix or autogenous bone. Comparison with non-grafted sites in a series of case reports. Clin Oral Implants Res. 1999;10(6):499-509. [pmid: 10740459]. Rec # 14410 Notes: CS
Gruber R, Koch H, Doll BA, Tegtmeier F, Einhorn TA, Hollinger JO. Fracture healing in the elderly patient. Exp Gerontol. 2006;41(11):1080-1093. [pmid: 17092679]. Rec # 5320 Notes: NRA
Gupta MC, Khan SN. Application of bone morphogenetic proteins in spinal fusion. Cytokine Growth Factor Rev. 2005;16(3):347-355. [pmid: 15878841]. Rec # 8450 Notes: NRA
Harwood PJ, Giannoudis PV. Application of bone morphogenetic proteins in orthopaedic practice: their efficacy and side effects. Expert Opin Drug Saf. 2005;4(1):75-89. [pmid: 15709900]. Rec # 8780 Notes: NRA
Heliotis M, Lavery KM, Ripamonti U, Tsiridis E, di Silvio L. Transformation of a prefabricated hydroxyapatite/osteogenic protein-1 implant into a vascularised pedicled bone flap in the human chest. Int J Oral Maxillofac Surg. 2006;35(3):265-269. [pmid: 16257511]. Rec # 7650 Notes: CR
Hsu WK, Wang JC. The use of bone morphogenetic protein in spine fusion. Spine J. 2008;8(3):419-425. [pmid: 18375186]. Rec # 2610 Notes: NRA
Huang YH, Polimeni G, Qahash M, Wikesjo UM. Bone morphogenetic proteins and osseointegration: current knowledge - future possibilities. Periodontol 2000. 2008;47:206-223. [pmid: 18412583]. Rec # 2490 Notes: NRA
Jeppsson C, Saveland H, Rydholm U, Aspenberg P. OP-1 for cervical spine fusion: bridging bone in only 1 of 4 rheumatoid patients but prednisolone did not inhibit bone induction in rats. Acta Orthop Scand. 1999;70(6):559-563. [pmid: 10665719]. Rec # 14610 Notes: CR
Jiang Q, Wei L-C, Liu D-P, Hu Y-X, Zhang Y-Q, Yin J-W. Allochthonous bone composited bone morphogenetic protein 2 for treating 31 cases of humerusnonunion. J. Clin. Rehab. Tissue Eng. Res. 2008;12(42):8377-8379. Rec # 17190 Notes: FLA
Jones AL. Recombinant human bone morphogenic protein-2 in fracture care. J Orthop Trauma. 2005;19(10 Suppl):S23-S25. [pmid: 16479219]. Rec # 7020 Notes: NRA
Jones NF, Brown EE, Mostofi A, Vogelin E, Urist MR. Healing of a scaphoid nonunion using human bone morphogenetic protein. J Hand Surg Am. 2005;30(3):528-533. [pmid: 15925163]. Rec # 8330 Notes: CR
Jones NF, Brown EE, Vogelin E, Urist MR. Bone morphogenetic protein as an adjuvant in the treatment of Kienbock's disease by vascular pedicle implantation. J Hand Surg Eur Vol. 2008;33(3):317-321. [pmid: 18562364]. Rec # 2260 Notes: CR
Jung RE, Glauser R, Scharer P, Hammerle CH, Sailer HF, Weber FE. Effect of rhBMP-2 on guided bone regeneration in humans. Clin Oral Implants Res. 2003;14(5):556-568. [pmid: 12969359]. Rec # 10450 Notes: NDE, non-commercial product
Jung RE, Thoma DS, Hammerle CH. Assessment of the potential of growth factors for localized alveolar ridge augmentation: a systematic review. J Clin Periodontol. 2008;35(8 Suppl):255-281. [pmid: 18724854]. Rec # 1730 Notes: SR
Jung RE, Windisch SI, Eggenschwiler AM, Thoma DS, Weber FE, Hammerle CH. A randomized-controlled clinical trial evaluating clinical and radiological outcomes after 3 and 5 years of dental implants placed in bone regenerated by means of GBR techniques with or without the addition of BMP-2. Clin Oral Implants Res. 2009;20(7):660-666. [pmid: 19489935]. Rec # 240 Notes: NDE non-commercial product
Kain MS, Einhorn TA. Recombinant human bone morphogenetic proteins in the treatment of fractures. Foot Ankle Clin. 2005;10(4):639-650. viii. [pmid: 16297824]. Rec # 7510 Notes: NRA
Kanakaris NK, Calori GM, Verdonk R, et al. Application of BMP-7 to tibial non-unions: a 3-year multicenter experience. Injury. Suppl 2. 2008;39:S83-S90. [pmid: 18804578]. Rec # 1610 Notes: REG
Kanakaris NK, Giannoudis PV. Clinical applications of bone morphogenetic proteins: current evidence. J Surg Orthop Adv. 2008;17(3):133-146. [pmid: 18851797]. Rec # 1380 Notes: SR
Kanakaris NK, Giannoudis PV. The health economics of the treatment of long-bone non-unions. Injury. Suppl 2. 2007;38:S77-S84. [pmid: 17920421]. Rec # 3570 Notes: CEA
Kanakaris NK, Paliobeis C, Nlanidakis N, Giannoudis PV. Biological enhancement of tibial diaphyseal aseptic non-unions: the efficacy of autologous bone grafting, BMPs and reaming by-products. Injury. Suppl 2. 2007;38:S65-S75. [pmid: 17920420]. Rec # 3580 Notes: NRA
Kim YB, Lenke LG, Kim YJ, Kim YW, Bridwell KH, Stobbs G. Surgical treatment of adult scoliosis: is anterior apical release and fusion necessary for the lumbar curve?. Spine (Phila Pa 1976). 2008;33(10):1125-1132. [pmid: 18449048]. Rec # 2440 Notes: NRQ
Lerner T, Griefingholt H, Liljenqvist U. Bone substitutes in scoliosis surgery: Knochenersatzstoffe in der Skoliosechirurgie. Orthopade. 2009;38(2):181-188. [pmid: 19093096]. Rec # 16780 Notes: FLA
Lieberman JR, Conduah A, Urist MR. Treatment of osteonecrosis of the femoral head with core decompression and human bone morphogenetic protein. Clin Orthop Relat Res. 2004;(429):139-145. [pmid: 15577478]. Rec # 9020 Notes: NDE, non-commercial BMP
Liu X, Shu D-F, Li T, Liu H. Evidence for use of bone morphogenetic protein in lumbar spinearthrodesis. Chin. J. Evid.-Based Med. 2008;8(9):786-790. Rec # 17170 Notes: FLA
Luhmann SJ, Bridwell KH, Cheng I, Imamura T, Lenke LG, Schootman M. Use of bone morphogenetic protein-2 for adult spinal deformity. Spine (Phila Pa 1976). 2005;30(17 Suppl):S110-S117. [pmid: 16138058]. Rec # 7960 Notes: NDE
Mahendra A, Maclean AD. Available biological treatments for complex non-unions. Injury. Suppl 4. 2007;38:S7-S12. [pmid: 18224732]. Rec # 2970 Notes: NRA
Maniscalco P, Gambera D, Bertone C, Rivera F, Crainz E, Urgelli S. Healing of fresh tibial fractures with OP-1. A preliminary report. Acta Biomed. 2002;73(1–2):27-33. [pmid: 12233274]. Rec # 11790 Notes: Preliminary report
McKay WF, Peckham SM, Badura JM. A comprehensive clinical review of recombinant human bone morphogenetic protein-2 (INFUSE Bone Graft). Int Orthop. 2007;31(6):729-734. [pmid: 17639384]. Rec # 4010 Notes: NRA
McKee MD. Recombinant human bone morphogenic protein-7: applications for clinical trauma. J Orthop Trauma. 2005;19(10 Suppl):S26-S28. [pmid: 16479220]. Rec # 7010 Notes: NRA
Mendenhall S. Higher costs with spinal 'fusion helpers'. OR Manager. 2006;22(2):12-13. Rec # 6580 Notes: NPD
Miyazaki M, Tsumura H, Wang JC, Alanay A. An update on bone substitutes for spinal fusion. Eur. Spine J. 2009;18(6):783-799. [pmid: 19280232]. Rec # 16400 Notes: NRA
Moghadam HG, Urist MR, Sandor GK, Clokie CM. Successful mandibular reconstruction using a BMP bioimplant. J Craniofac Surg. 2001;12(2):119-127. discussion 128. [pmid: 11314620]. Rec # 13480 Notes: CR
Mont MA, Etienne G, Ragland PS. Outcome of nonvascularized bone grafting for osteonecrosis of the femoral head. Clin Orthop Relat Res. 2003;(417):84-92. [pmid: 14646705]. Rec # 10170 Notes: NDE
Moulder E, Sharma HK. Tibial non-union: a review of current practice. Curr. Orthop. 2008;22(6):434-441. Rec # 16990 Notes: NRA
Mussano F, Ciccone G, Ceccarelli M, Baldi I, Bassi F. Bone morphogenetic proteins and bone defects: a systematic review. Spine (Phila Pa 1976). 2007;32(7):824-830. [pmid: 17414919]. Rec # 4640 Notes: SR
Nakashima M. Bone morphogenetic proteins in dentin regeneration for potential use in endodontic therapy. Cytokine Growth Factor Rev. 2005;16(3):369-376. [pmid: 15878301]. Rec # 8460 Notes: NRA
Nordsletten L. Recent developments in the use of bone morphogenetic protein in orthopaedic trauma surgery. Curr Med Res Opin. Suppl 1. 2006;22:S13-S17. S23. [pmid: 16882365]. Rec # 5930 Notes: NRA
Nordsletten L, Valentin-Opran A. Recombinant human bone morphogenetic protein-2 for the treatment of Gustilo Grade III open tibia fractures. The Journal of Bone and Joint Surgery (Proceedings). Suppl I. 2006;88-B:183-f. Rec # 16250 Notes: Abstract
Novicoff WM, Manaswi A, Hogan MV, Brubaker SM, Mihalko WM, Saleh KJ. Critical analysis of the evidence for current technologies in bone-healing and repair. J Bone Joint Surg Am. 2008;90 Suppl 1:85-91. [pmid: 18292362]. Rec # 16160 Notes: SR
Papakostidis C, Kontakis G, Bhandari M, Giannoudis PV. Efficacy of autologous iliac crest bone graft and bone morphogenetic proteins for posterolateral fusion of lumbar spine: a meta-analysis of the results. Spine (Phila Pa 1976). 2008;33(19):E680-E692. [pmid: 18758349]. Rec # 1840 Notes: MA
Patel VV, Estes S, Lindley EM, Burger E. Lumbar spinal fusion versus anterior lumbar disc replacement: the financial implications. J Spinal Disord Tech. 2008;21(7):473-476. [pmid: 18836357]. Rec # 1440 Notes: CEA
Polly DW Jr, Ackerman SJ, Shaffrey CI, et al. A cost analysis of bone morphogenetic protein versus autogenous iliac crest bone graft in single-level anterior lumbar fusion. Orthopedics. 2003;26(10):1027-1037. [pmid: 14577525]. Rec # 10330 Notes: CEA
Poynton AR, Lane JM. Safety profile for the clinical use of bone morphogenetic proteins in the spine. Spine (Phila Pa 1976). 2002;27(16 Suppl 1):S40-S48. [pmid: 12205419]. Rec # 11890 Notes: NRA
Rafiq I, Kapoor A, Burton DJC, Haines JF. A new modality of treatment for non-united fractureof the humerus in a patient with osteopetrosis: A case report. J. Med. Case Rep. 2009;3. Rec # 16830 Notes: CR
Raschke M, Csimma C, Valentin OA. Recombinant human bone morphogenetic Protein-2 (RhBMP-2; Dibotermin alpha) in the management of open tibia fractures: a prospective, randomized, controlled study in 450 patients. Hefte Zur Der Unfallchirurg. 2001;283:231-232. Rec # 16260 Notes: FLA
Recombinant human bone morphogenetic protein: Life-threatening complications. WHO Drug Inf. 2008;22(3):195. Rec # 17040 Notes: COM
Resnick DK, Choudhri TF, Dailey AT, et al. Guidelines for the performance of fusion procedures for degenerative disease of the lumbar spine. Part 16: bone graft extenders and substitutes. J Neurosurg Spine. 2005;2(6):733-736. [pmid: 16028744]. Rec # 8160 Notes: NRA
Riedel GE, Valentin-Opran A. Clinical evaluation of rhBMP-2/ACS in orthopedic trauma: a progress report. Orthopedics. 1999;22(7):663-665. [pmid: 10418860]. Rec # 14960 Notes: Abstract
Rihn JA, Gates C, Glassman SD, Phillips FM, Schwender JD, Albert TJ. The use of bone morphogenetic protein in lumbar spine surgery. Instr Course Lect. 2009;58:677-688. [pmid: 19385577]. Rec # 370 Notes: NRA
Rihn JA, Gates C, Glassman SD, Phillips FM, Schwender JD, Albert TJ. The use of bone morphogenetic protein in lumbar spine surgery. J Bone Joint Surg Am. 2008;90(9):2014-2025. [pmid: 18762664]. Rec # 1810 Notes: NRA
Ripamonti U, Heliotis M, Ferretti C. Bone morphogenetic proteins and the induction of bone formation: from laboratory to patients. Oral Maxillofac Surg Clin North Am. 2007;19(4):575-589. vii. [pmid: 18088907]. Rec # 3220 Notes: NRA
Ristiniemi J. External fixation of tibial pilon fractures and fracture healing. Acta Orthop Suppl. 5. 2007;78(326):3-34. [pmid: 17465283]. Rec # 4560 Notes: Same as REC# 4930
Robinson Y, Heyde CE, Tschoke SK, Mont MA, Seyler TM, Ulrich SD. Evidence supporting the use of bone morphogenetic proteins for spinal fusion surgery. Expert Rev Med Devices. 2008;5(1):75-84. [pmid: 18095899]. Rec # 3170 Notes: NRA
Ronga M, Baldo F, Zappala G, Cherubino P. Recombinant human bone morphogenetic protein-7 for treatment of long bone non-union: an observational, retrospective, non-randomized study of 105 patients. Injury. Suppl 3. 2006;37:S51-S56. [pmid: 16952362]. Rec # 5750 Notes: NDE
Samartzis D, Khanna N, Shen FH, An HS. Update on bone morphogenetic proteins and their application in spine surgery. J Am Coll Surg. 2005;200(2):236-248. [pmid: 15664100]. Rec # 8880 Notes: NRA
Sandhu HS, Anderson DG, Andersson GBJ, et al. Summary statement: Alternative delivery by gene therapy and cost justification of bone morphogenetic proteins for spinefusion. Spine. 2002;27(16 SUPPL.):S86. Rec # 20580 Notes: CEA
Sandhu HS, Anderson DG, Andersson GBJ, et al. Summary statement: Safety of bone morphogenetic proteins for spine fusion. Spine. 2002;27(16 SUPPL.):S39. Rec # 20570 Notes: COM
Sandhu HS. Bone morphogenetic proteins and spinal surgery. Spine (Phila Pa 1976). 2003;28(15 Suppl):S64-S73. [pmid: 12897477]. Rec # 10680 Notes: NRA
Schmidmaier G, Schwabe P, Wildemann B, Haas NP. Use of bone morphogenetic proteins for treatment of non-unions and future perspectives. Injury. Suppl 4. 2007;38:S35-S41. [pmid: 18224735]. Rec # 2960 Notes: NRA
Schwender JD, Holly LT, Rouben DP, Foley KT. Minimally invasive transforaminal lumbar interbody fusion (TLIF): technical feasibility and initial results. J Spinal Disord Tech. Suppl. 2005;18:S1-S6. [pmid: 15699793]. Rec # 8800 Notes: NDE
Seeherman H, Li R, Li XJ, Wozney J. Injectable rhBMP-2/CPM paste for closed fracture and minimally invasive orthopaedic repairs. J Musculoskelet Neuronal Interact. 2003;3(4):317-319. discussion 320-1. [pmid: 15758309]. Rec # 8680 Notes: NDE
Sen MK, Miclau T. Autologous iliac crest bone graft: should it still be the gold standard for treating nonunions?. Injury. Suppl 1. 2007;38:S75-S80. [pmid: 17383488]. Rec # 4730 Notes: NRA
Shahlaie K, Kim KD. Occipitocervical fusion using recombinant human bone morphogenetic protein-2: adverse effects due to tissue swelling and seroma. Spine (Phila Pa 1976). 2008;33(21):2361-2366. [pmid: 18827703]. Rec # 1480 Notes: CR
Smith DM, Cooper GM, Mooney MP, Marra KG, Losee JE. Bone morphogenetic protein 2 therapy for craniofacial surgery. J Craniofac Surg. 2008;19(5):1244-1259. [pmid: 18812847]. Rec # 1550 Notes: NRA
Smoljanovic T, Bojanic I, Pecina M. End plates resorptions after the applications of rhBMP-2 for interbody spinal fusions. J Spin. 2009;22(4):309. author reply 310. Rec # 220 Notes: COM
Smoljanovic T, Bojanic I, Delimar D. Adverse effects of posterior lumbar interbody fusion using rhBMP-2. Eur Spine J. 2009;18(6):920-923. author reply 924. [pmid: 19352727]. Rec # 430 Notes: COM
Smoljanovic T, Grgurevic L, Jelic M, et al. Regeneration of the skeleton by recombinant human bone morphogenetic proteins. Coll Antropol. 2007;31(3):923-932. [pmid: 18041408]. Rec # 3320 Notes: SR
Smoljanovic T, Pecina M. RE: complications attributable to the use of rhBMP-2 inside the femoral ring allograft during anterior lumbar interbody fusion. Spine J. 2008;8(2):413-414. author reply 414. [pmid: 18178134]. Rec # 3110 Notes: COM
Solofomalala GD, Guery M, Lesiourd A, Le Huec JC, Chauveaux D, Laffenetre O. Bone morphogenetic proteins: From their discoveries till their clinical applications. Eur. J. Orthop. Surg. Traumatol. 2007;17(6):609-615. Rec # 17920 Notes: NRA
Starr AJ. Fracture repair: successful advances, persistent problems, and the psychological burden of trauma. J Bone Joint Surg Am. Suppl 1. 2008;90:132-137. [pmid: 18292368]. Rec # 2690 Notes: NRA
Stiehl JB, Ulrich SD, Seyler TM, Bonutti PM, Marker DR, Mont MA. Bone morphogenetic proteins in total hip arthroplasty, osteonecrosis and trauma surgery. Expert Rev Med Devices. 2008;5(2):231-238. [pmid: 18331183]. Rec # 2710 Notes: NRA
Termaat MF, Den Boer FC, Bakker FC, Patka P, Haarman HJ. Bone morphogenetic proteins. Development and clinical efficacy in the treatment of fractures and bone defects. J Bone Joint Surg Am. 2005;87(6):1367-1378. [pmid: 15930551]. Rec # 8310 Notes: NRA
Tonetti MS, Hammerle CH. Advances in bone augmentation to enable dental implant placement: Consensus Report of the Sixth European Workshop on Periodontology. J Clin Periodontol. 2008;35(8 Suppl):168-172. [pmid: 18724849]. Rec # 1740 Notes: NRA
Tumialan LM, Rodts GE. Adverse swelling associated with use of rh-BMP-2 in anterior cervical discectomy and fusion. Spine J. 2007;7(4):509-510. [pmid: 17526433]. Rec # 4300 Notes: COM
Vaccaro AR, Anderson DG, Toth CA. Recombinant human osteogenic protein-1 (bone morphogenetic protein-7) as an osteoinductive agent in spinal fusion. Spine (Phila Pa 1976). 2002;27(16 Suppl 1):S59-S65. [pmid: 12205422]. Rec # 11870 Notes: NRA
Vaibhav B, Nilesh P, Vikram S, Anshul C. Bone morphogenic protein and its application in trauma cases: a current concept update. Injury. 2007;38(11):1227-1235. [pmid: 17307180]. Rec # 4970 Notes: NRA
Vaidya R, Weir R, Sethi A, Meisterling S, Hakeos W, Wybo CD. Interbody fusion with allograft and rhBMP-2 leads to consistent fusion but early subsidence. J Bone Joint Surg Br. 2007;89(3):342-345. [pmid: 17356146]. Rec # 4810 Notes: NDE
Vaidya R. Transforaminal interbody fusion and the "off label" use of recombinant human bone morphogenetic protein-2. Spine J. 2009;9(8):667-669. [pmid: 19622413]. Rec # 10 Notes: COM
Valdes MA, Thakur NA, Namdari S, Ciombor DM, Palumbo M. Recombinant bone morphogenic protein-2 in orthopaedic surgery: a review. Arch Orthop Trauma Surg. 2009. Rec # 610 Notes: NRA
Wang JC, Haid RW Jr, Miller JS, Robinson JC. Comparison of CD HORIZON SPIRE spinous process plate stabilization and pedicle screw fixation after anterior lumbar interbodyfusion: Invited submission from the Joint Section Meeting on Disorders of. J. Neurosurg. Spine. 2006;4(2):132-136. [pmid: 16506480]. Rec # 19150 Notes: NDE
Westerhuis RJ, van Bezooijen RL, Kloen P. Use of bone morphogenetic proteins in traumatology. Injury. 2005;36(12):1405-1412. [pmid: 16125704]. Rec # 7990 Notes: NRA
White AP, Lee RS, Grauer JN. Bone Morphogenetic Protein for Pseudarthrosis Repair in Revision Cervical Spine Surgery. Semin. Spine Surg. 2006;18(4):207-210. Rec # 18480 Notes: NRA
White AP, Vaccaro AR, Hall JA, Whang PG, Friel BC, McKee MD. Clinical applications of BMP-7/OP-1 in fractures, nonunions and spinal fusion. Int Orthop. 2007;31(6):735-741. [pmid: 17962946]. Rec # 3500 Notes: NRA
Whitesides LM, Radwan A, Sharawy M. Sinus floor augmentation using a composite graft of bone morphogenic protein-2 and allogenic cancellous bone (Puros): case report. J Oral Implantol. 2006;32(5):259-264. [pmid: 17069172]. Rec # 5380 Notes: CR
Wikesjo UM, Huang YH, Polimeni G, Qahash M. Bone morphogenetic proteins: a realistic alternative to bone grafting for alveolar reconstruction. Oral Maxillofac Surg Clin North Am. 2007;19(4):535-551. vi. vii. [pmid: 18088904]. Rec # 3230 Notes: NRA
Williams D. Doses of drugs in devices. Med Device Technol. 2009;20(1):8-9. Rec # 400 Notes: NRA
Xiao RC, Li NN, Tang ZH, et al. Bone morphogenetic protein versus iliac bone graft substitute with internal fixation in the treatment of osteoporotic intertrochanteric fracture. Journal of Clinical Rehabilitative Tissue Engineering Research. 2007;11(21):4077-4080. Rec # 16230 Notes: FLA
Xiao RC, Xiao ZM, Li Q, Tang ZH, Hu JZ, Zou GY. Bone morphogenetic protein and interbody fusion cage change the height of intervertebral space in patients with lumbar spondylolisthesis. Journal of Clinical Rehabilitative Tissue Engineering Research. 2007;11(8):1443-1446. Rec # 16220 Notes: FLA
Yu B, Tian J, Jin A-M. Clinical evaluation of bone morphogenetic protein in spinal fusion. Chin. J. Clin. Rehab. 2003;7(20):2856-2857. Rec # 20150 Notes: FLA
Zijderveld SA, Giltaij LR, Van Den Bergh JPA, Ten Bruggenkate CM, Tuinzing DB. Pre-clinical and clinical experiences with BMP-2 andBMP-7 in sinus floor elevation surgery: A comparison. J. Musculoskelet Res. 2002;6(1):43-54. Rec # 20760 Notes: NRA