# Electronic Database Search Strategies

Overall
# | Search | No. Articles
#61 | Search #56 OR #60 | 1608
#60 | Search (#55 NOT #56) NOT (animal OR dog OR dogs OR mice OR mouse OR canine OR bovine OR ovine OR rabbit* OR equine OR rat OR rats OR plant OR plants) | 79
#58 | Search #55 NOT #56 | 1280
#56 | Search #52 AND #53 Limits: Entrez Date from 1998 to 2009, Humans, English | 1529
#55 | Search #52 AND #53 Limits: Entrez Date from 1998 to 2009, English | 2809
#54 | Search #52 AND #53 | 3525
#53 | Search #50 OR #51 | 11610
#52 | Search #43 OR #47 OR #48 | 4477848
#51 | Search "bone morphogen*" OR BMP OR BMP-2 OR BMP2 OR BMP-7 OR BMP7 OR rBMP OR rBMP-2 OR rBMP2 OR rBMP-7 OR rBMP7 OR r-BMP OR r-BMP-2 OR r-BMP2 OR r-BMP-7 OR r-BMP7 OR rhBMP OR rhBMP-2 OR rhBMP2 OR rhBMP-7 OR rhBMP7 OR rh-BMP OR rh-BMP-2 OR rh-BMP2 OR rh-BMP-7 OR rh-BMP7 OR RHOP OR RHOP-1 OR op-1 OR op1 | 9501
#50 | Search "Bone Morphogenetic Proteins"[Mesh] | 8665
#48 | Search fracture* OR non-union* OR nonunion* OR fusion* OR allograft* OR autograft* OR arthrodes* OR malunion* OR dental OR alveolar | 796705
#47 | Search ("therapeutic use "[Subheading] OR "surgery "[Subheading]) OR "injuries "[Subheading] | 3916363
#43 | Search (((("Fractures, Bone"[Mesh] OR "Spinal Fusion"[Mesh]) OR "Fusion"[Mesh]) OR "Alveolar Bone Loss"[Mesh]) OR "Alveolar Ridge Augmentation"[Mesh]) OR "Dental Implants"[Mesh] | 142836

Search Strategy for Cochrane Database of Randomized Trials

"Random Allocation"[MeSH] OR "Randomized Controlled Trial"[Publication Type] OR "Controlled Clinical Trial"[Publication Type] OR "Randomized Controlled Trials"[MeSH] OR "Double-Blind Method"[MeSH] OR "Single-Blind Method"[MeSH] OR ("Clinical Trial"[Publication Type] OR "Clinical Trials"[MeSH]) OR "clinical trial" OR ((singl* OR doubl* OR trebl* OR tripl*) AND (mask* OR blind*)) OR "Placebos"[MeSH] OR "Research Design"[MeSH] OR "Comparative Study"[MeSH] OR "Evaluation Studies"[MeSH] OR "Follow-Up Studies"[MeSH] OR "Prospective Studies"[MeSH] OR placebo* OR random* OR control* OR prospectiv* OR volunteer*