# Quality of Reporting Harms

Appendix 5 Table A Reporting of BMP-Specific Harms in On-Label Comparative Studies

Investigator (yr, country, ref #) Surgical Site | Study design | Comparison(s) No. pts (BMP dose) | Explanation of how harms identified | Standard/valid instrument used | Ascertainment similar in all groups | Measure of severity reported | Were harms attributed to intervention likely causally associated | Were harms (# and type) reported separately for each study group | Comments
Boden et al., 2000 USA (71) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP2 n=11 (4.2–8.4 mg/pt) | Y | N | Y | N | N | Y | No patients had increased BMP-2 anti-bodies after treatment
Boden et al., 2000 USA (71) Lumbar Spine | Multicenter, nonblinded RCT | ICBG n=3 | Y | N | Y | N | N | Y | No patients had increased BMP-2 anti-bodies after treatment
Burkus et al., 2002 USA (72) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP2 n=143 (4.2–8.4 mg/pt) | N | N | Y | N | N | Y | Antibody testing results similar between groups
Burkus et al., 2002 USA (72) Lumbar Spine | Multicenter, nonblinded RCT | ICBG n=136 | N | N | Y | N | N | Y | Antibody testing results similar between groups
Burkus et al., 2003 USA (182) Lumbar Spine Note: may include pts in Burkus et al., 2003, (80) | Retrospective combined comparative analysis | rhBMP2 n=277 (dose NR) | N | Unclear | Y | N | Unclear | N | No harms reporting
Burkus et al., 2003 USA (182) Lumbar Spine Note: may include pts in Burkus et al., 2003, (80) | Retrospective combined comparative analysis | ICBG n=402 | N | Unclear | Y | N | Unclear | N | No harms reporting
Dawson et al., 2009 USA (73) Lumbar Spine | Multicenter nonblinded RCT | rhBMP2/CRM n=25 (12 mg/pt) | N | N | Y | N | N | Y | Text reporting
Dawson et al., 2009 USA (73) Lumbar Spine | Multicenter nonblinded RCT | ICBG n=21 | N | N | Y | N | N | Y | Text reporting
Govender et al. for the BESTT study group 2002 South Africa (74) Open Tibial Fractures | Multi-center, single blind, RCT | rhBMP2 n=151 (6 mg/patient) | Y | N | Y | N | N | Y | Mostly text reporting Antibodies present in 1, 3,9 patients in each group.
Govender et al. for the BESTT study group 2002 South Africa (74) Open Tibial Fractures | Multi-center, single blind, RCT | rhBMP2 n=149 (12 mg/patient) | Y | N | Y | N | N | Y | Mostly text reporting Antibodies present in 1, 3,9 patients in each group.
Govender et al. for the BESTT study group 2002 South Africa (74) Open Tibial Fractures | Multi-center, single blind, RCT | n=150 Standard care (IM nail fixation and soft tissue management) | Y | N | Y | N | N | Y | Mostly text reporting Antibodies present in 1, 3,9 patients in each group.
Swiontkowski et al., 2006 USA (81) Open Tibial Fractures Note: This paper reports on 131 of the same patients included in Govender et al., 2002 (74) | Subgroup analysis of combined data from two prospective randomized trials with identical designs | rhBMP2 n=169 (12 mg/patient) | N | Unknown | Unknown | N | Unknown | N | No harms reporting
Swiontkowski et al., 2006 USA (81) Open Tibial Fractures Note: This paper reports on 131 of the same patients included in Govender et al., 2002 (74) | Subgroup analysis of combined data from two prospective randomized trials with identical designs | n=169 Standard care (IM nail fixation and soft tissue management) | N | Unknown | Unknown | N | Unknown | N | No harms reporting
Boyne et al., 2005 USA (75) Maxillofacial Defects | Multicenter randomized dose-comparison, safety and efficacy study | rhBMP2/ACS n=18 (6–24 mg/pt) | Y | N | Y | N | N | Y | Facial edema related to BMP groups 4% (2 patients) had immune response to BMP-2 after treatment. Bothwere transient.
Boyne et al., 2005 USA (75) Maxillofacial Defects | Multicenter randomized dose-comparison, safety and efficacy study | rhBMP2/ACS n=17 (15–48 mg/pt) | Y | N | Y | N | N | Y | Facial edema related to BMP groups 4% (2 patients) had immune response to BMP-2 after treatment. Bothwere transient.
Boyne et al., 2005 USA (75) Maxillofacial Defects | Multicenter randomized dose-comparison, safety and efficacy study | AGB n=13 | Y | N | Y | N | N | Y | Facial edema related to BMP groups 4% (2 patients) had immune response to BMP-2 after treatment. Bothwere transient.
Fiorellini et al., 2005 USA (76) Maxillofacial Defects | Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study | rhBMP2/ACS n=22 (mn dose 0.9 mg/pt) | Y | N | Y | N | N | N | No antibodies detected.
Fiorellini et al., 2005 USA (76) Maxillofacial Defects | Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study | rhBMP2/ACS n=21 (mn dose 1.9 mg/pt) | Y | N | Y | N | N | N | No antibodies detected.
Fiorellini et al., 2005 USA (76) Maxillofacial Defects | Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study | Placebo n=17 | Y | N | Y | N | N | N | No antibodies detected.
Fiorellini et al., 2005 USA (76) Maxillofacial Defects | Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study | No Tx n=20 | Y | N | Y | N | N | N | No antibodies detected.
Triplett et al., 2009 USA (77) Maxillofacial Defects | Multicenter, nonblinded RCT | rhBMP2/ACS n=80 (12–24 mg/pt) | Y | N | Y | N | Y | Y | Facial edema 2 patients developed anti-bodies after treatment
Triplett et al., 2009 USA (77) Maxillofacial Defects | Multicenter, nonblinded RCT | AGB n=80 | Y | N | Y | N | Y | Y | Facial edema 2 patients developed anti-bodies after treatment
van den Bergh et al., 2000 Netherlands (82) Maxillofacial Defects | Retrospective cohort study | rhBMP7/ACS n=3 (2.5 mg/pt) | N | Unclear | Y | N | Unclear | Y
van den Bergh et al., 2000 Netherlands (82) Maxillofacial Defects | Retrospective cohort study | ICBG n=3 | N | Unclear | Y | N | Unclear | Y
Calori et al., 2008 Italy (78) Long Bone Nonunions | Single-center, nonblinded RCT | rhBMP7/ACS n=60 (3.5–7.0 mg/pt) | Y | Y | Y | Y | N | Y | Infections werethe only harm reported
Calori et al., 2008 Italy (78) Long Bone Nonunions | Single-center, nonblinded RCT | PRP n=60 | Y | Y | Y | Y | N | Y | Infections werethe only harm reported
Dahabreh et al., 2008 UK, Italy (83) Long Bone Nonunions | Retrospective cohort study | rhBMP7/ACS n=15 (3.5 mg/pt) | Y | N | Y | N | N | Y | Very brief in text
Dahabreh et al., 2008 UK, Italy (83) Long Bone Nonunions | Retrospective cohort study | ICBG n=12 | Y | N | Y | N | N | Y | Very brief in text
Friedlaender et al., 2001 USA (79) Long Bone Nonunions | Multicenter, partially blinded RCT | rhBMP7/ACS n=61 (3.5–7.0 mg/pt) | Y | Y | Y | Y | N | Y | 10% developedanti-bodies to OP-1 all were transient.
Friedlaender et al., 2001 USA (79) Long Bone Nonunions | Multicenter, partially blinded RCT | AGB n=61 | Y | Y | Y | Y | N | Y | 10% developedanti-bodies to OP-1 all were transient.

Appendix 5 Table B Reporting of BMP-Specific Harms in Off-Label Comparative Studies

Investigator (yr, country, ref #) | Study design | Comparison(s) No. pts (BMP dose) | Explanation of how harms identified | Standard/valid instrument used | Ascertainment similar in all groups | Measure of severity reported | Were harms attributed to intervention likely causally associated | Were harms (# and type) reported separately for each study group | Comments
Boden et al., 2002 USA (84) Lumbar Spine | Multicenter nonblinded RCT | rhBMP2/CRM plus Texas Scottish Rite Hospital (TSRH) Spinal System (TSRHSS) n=11 (40 mg/pt) | Y | N | Y | N | N | Y | Text reporting Incidence of anti-BMP-2 antibodies 4.5% in BMP-2 groups vs. 0 in auto-graft group. These were transient.
Boden et al., 2002 USA (84) Lumbar Spine | Multicenter nonblinded RCT | rhBMP2/CRM alone n=11 (40 mg/pt) | Y | N | Y | N | N | Y | Text reporting Incidence of anti-BMP-2 antibodies 4.5% in BMP-2 groups vs. 0 in auto-graft group. These were transient.
Boden et al., 2002 USA (84) Lumbar Spine | Multicenter nonblinded RCT | ICBG plus TSRHSS n=5 | Y | N | Y | N | N | Y | Text reporting Incidence of anti-BMP-2 antibodies 4.5% in BMP-2 groups vs. 0 in auto-graft group. These were transient.
Burkus et al., 2005 USA (85) Lumbar Spine Note: includes all pts from Burkus et al., 2002, rec# 11510; same pts as Burkus et al., 2006, rec# 6640 | Multicenter, nonblinded RCT | rhBMP2 n=79 (8–12 mg/pt) | N | Unknown | Y | N | N | Y | No patient had antibodies to BMP-2
Burkus et al., 2005 USA (85) Lumbar Spine Note: includes all pts from Burkus et al., 2002, rec# 11510; same pts as Burkus et al., 2006, rec# 6640 | Multicenter, nonblinded RCT | ICBG N=52 | N | Unknown | Y | N | N | Y | No patient had antibodies to BMP-2
Dimar et al., 2009 USA (86) Lumbar Spine Note: contains pts in Glassman et al., 2007, rec# 4040; Dimar et al., 2006 rec# 5480; Glassman et al., 2005, rec# 8040 | Multicenter nonblinded RCT | rhBMP2/CRM n=239 (40 mg/pt) | N | N | Y | N | N | Y
Dimar et al., 2009 USA (86) Lumbar Spine Note: contains pts in Glassman et al., 2007, rec# 4040; Dimar et al., 2006 rec# 5480; Glassman et al., 2005, rec# 8040 | Multicenter nonblinded RCT | ICBG n=224 | N | N | Y | N | N | Y
Glassman et al., 2007 USA (99) Lumbar Spine | Retrospective with historical control group | rhBMP2 n=91 (12 mg/pt) | N | Unclear | Unclear | N | Unclear | N | No harms reporting
Glassman et al., 2007 USA (99) Lumbar Spine | Retrospective with historical control group | ICBG n=35 | N | Unclear | Unclear | N | Unclear | N | No harms reporting
Glassman et al., 2008 USA (87) Lumbar Spine | Multicenter nonblinded RCT | rhBMP2 n=50 (dose not reported) | Y | N | Unclear | N | N | Y
Glassman et al., 2008 USA (87) Lumbar Spine | Multicenter nonblinded RCT | ICBG n=52 | Y | N | Unclear | N | N | Y
Haid et al., 2004 USA (88) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP2 n=34 (4.2–8.4 mg/pt) | N | Unclear | Y | N | Y | Y | No antibodies to BMP-2 Extra bone formation outside disk space
Haid et al., 2004 USA (88) Lumbar Spine | Multicenter, nonblinded RCT | ICBG N=33 | N | Unclear | Y | N | Y | Y | No antibodies to BMP-2 Extra bone formation outside disk space
Johnsson et al., 2002 Sweden (92) Lumbar Spine | Multicenter nonblinded RCT | rhBMP7 n=10 (7 mg/pt) | N | Unclear | Y | N | N | Y | In text
Johnsson et al., 2002 Sweden (92) Lumbar Spine | Multicenter nonblinded RCT | ICBG n=10 | N | Unclear | Y | N | N | Y | In text
Kanayama et al., 2006 Japan, USA (93) Lumbar Spine | Multicenter nonblinded RCT | rhBMP7 n=9 (7 mg/pt) | N | Unknown | Unknown | NA | Unknown | N | No harms reporting
Kanayama et al., 2006 Japan, USA (93) Lumbar Spine | Multicenter nonblinded RCT | AGB/CRM n=10 | N | Unknown | Unknown | NA | Unknown | N | No harms reporting
Mummaneni et al., 2004 USA (100) Lumbar Spine | Retrospective single-center cohort study | rhBMP2/AGB n=25 (8.4 mg/pt) | N | Unclear | Unclear | NA | Unclear | N | No harms reporting
Mummaneni et al., 2004 USA (100) Lumbar Spine | Retrospective single-center cohort study | ICBG N=19 | N | Unclear | Unclear | NA | Unclear | N | No harms reporting
Pradhan et al., 2006 USA (101) Lumbar Spine | Prospective consecutive patient single-center cohort study | rhBMP2 n=9 (dose NR) | N | Unknown | Unknown | N | Unknown | N | No harms reporting
Pradhan et al., 2006 USA (101) Lumbar Spine | Prospective consecutive patient single-center cohort study | ICBG n=27 | N | Unknown | Unknown | N | Unknown | N | No harms reporting
Singh et al., 2006 USA (102) Lumbar Spine | Prospective single-center case-matched cohort study | rhBMP2/ICBG n=39 (12–36 mg/pt) | N | Unknown | Y | N | N | N
Singh et al., 2006 USA (102) Lumbar Spine | Prospective single-center case-matched cohort study | ICBG N=11 | N | Unknown | Y | N | N | N
Slosar et al., 2007 USA (103) Lumbar Spine | Prospective consecutive patient single-center cohort study | rhBMP2 n=45 (3–9 mg/pt) | N | Unknown | Unknown | N | N | N | In the text it states “no complications attributable to the use of BMP-2”
Slosar et al., 2007 USA (103) Lumbar Spine | Prospective consecutive patient single-center cohort study | ALG N=30 | N | Unknown | Unknown | N | N | N | In the text it states “no complications attributable to the use of BMP-2”
Vaccaro et al., 2008 USA (94) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP7 n=207 (7 mg/pt) | Y | N | N | N | N | N | There were no harms reported. The success rate defined as absence of SAE was provided for each group. Immunologic analysis was completed. 93.7%of those receiving op-1putty were antibody positive at any time point versus 20.9% of auto-graft group. In theOP-1 group, 25.6% of participants became positive for anti-OP-1 neutralizing antibodies versus 1.2% of auto-graft patients.
Vaccaro et al., 2008 USA (94) Lumbar Spine | Multicenter, nonblinded RCT | ICBG n=86 | Y | N | N | N | N | N
Vaccaro et al., 2008 USA (95) Lumbar Spine Note: Long-term F/U study that includes all pts from Vaccaro et al., 2004, rec# 9100, and Vaccaro et al., 2005, rec# 7310 | Multicenter, nonblinded RCT | rhBMP7 n=24 (7 mg/pt) | Y | N | Y | N | N | Y
Vaccaro et al., 2008 USA (95) Lumbar Spine Note: Long-term F/U study that includes all pts from Vaccaro et al., 2004, rec# 9100, and Vaccaro et al., 2005, rec# 7310 | Multicenter, nonblinded RCT | ICBG n=12 | Y | N | Y | N | N | Y
Baskin et al., 2003 USA (89) Cervical Spine | Multicenter, nonblinded RCT | rhBMP2/ALG n=18 (0.6–1.2 mg/pt) | Y | N | Y | N | N | N | No patient had antibodies to BMP-2
Baskin et al., 2003 USA (89) Cervical Spine | Multicenter, nonblinded RCT | ICBG/ALG n=15 | Y | N | Y | N | N | N | No patient had antibodies to BMP-2
Butterman et al., 2008 USA (104) Cervical Spine | Prospective nonrandomized cohorts of consecutive patients | rhBMP2/CRA n=30 (0.9–3.7 mg/pt) | Y | N | Y | N | N | Y | Neck swelling
Butterman et al., 2008 USA (104) Cervical Spine | Prospective nonrandomized cohorts of consecutive patients | ICBG n=36 | Y | N | Y | N | N | Y | Neck swelling
Crawford et al., 2009 USA (105) Cervical Spine | Retrospective cohort of consecutive patients | rhBMP2/BGE n=41 (4.2–12 mg/pt) | Y | N | Unclear | N | N | Y
Crawford et al., 2009 USA (105) Cervical Spine | Retrospective cohort of consecutive patients | ICBG n=36 | Y | N | Unclear | N | N | Y
Smucker et al., 2006 USA (106) Cervical Spine | Retrospective case-control | rhBMP2/CRA n=69 (dose NR) | Y | Y | Y | Y | Y | Y | Cervical swelling 10.1 fold increase in risk of cervical swelling for those in BMP-2 group vs. controls.
Smucker et al., 2006 USA (106) Cervical Spine | Retrospective case-control | CRA n=165 | Y | Y | Y | Y | Y | Y | Cervical swelling 10.1 fold increase in risk of cervical swelling for those in BMP-2 group vs. controls.
Vaidya et al., 2007 USA (107) Cervical Spine | Retrospective cohorts of consecutive patients | rhBMP2 n=22 (1–3 mg/pt) | Y | Y | Y | N | Y | Y | Dysphagia 85% in BMP group and 56% in allograft group reported difficulty swallowing in the post-op period. Number of levels affected the incidence of dysphagia.
Vaidya et al., 2007 USA (107) Cervical Spine | Retrospective cohorts of consecutive patients | ALG/DBM n=24 | Y | Y | Y | N | Y | Y | Dysphagia 85% in BMP group and 56% in allograft group reported difficulty swallowing in the post-op period. Number of levels affected the incidence of dysphagia.
Boraiah et al., 2009 USA (108) Acute Tibial Fractures | Retrospective case series | rhBMP2 n=17 (12 mg/pt) | Y | N | Y | N | Y | Y | HO around the knee
Boraiah et al., 2009 USA (108) Acute Tibial Fractures | Retrospective case series | n=23 no BMP | Y | N | Y | N | Y | Y | HO around the knee
Jones et al., 2006 USA (90) Acute Tibial Fractures | Multi-center prospective RCT | rhBMP2 n=15 (12 mg/pt with allograft bone chips) | Y | N | Y | N | N | Y | In text reporting No patient developed anti-bodies to BMP-2
Jones et al., 2006 USA (90) Acute Tibial Fractures | Multi-center prospective RCT | n=15 autogenous bone graft | Y | N | Y | N | N | Y | In text reporting No patient developed anti-bodies to BMP-2
Ristiniemi et al., 2007 Finland (110) Acute Tibial Fractures (same as rec# 4560) | Retrospective cohort of matched patients | rhBMP7 n=20 Matched Zone 43 fracture (OREF) n=20 | Y | N | Y | N | Y | Y | Harms reported in text Patient developed soft tissue calcification but without symptoms
Bilic et al., 2006 Croatia, Netherlands (96) Miscellaneous Uses | Single-center, unblinded RCT | rhBMP7/AGB n=6 (3.5 mg/pt) | N | Unknown | Y | N | N | Y | In text “ No reported adverse events”
Bilic et al., 2006 Croatia, Netherlands (96) Miscellaneous Uses | Single-center, unblinded RCT | rhBMP7/ALG n=6 (3.5 mg/pt) | N | Unknown | Y | N | N | Y | In text “ No reported adverse events”
Bilic et al., 2006 Croatia, Netherlands (96) Miscellaneous Uses | Single-center, unblinded RCT | ICBG n=6 | N | Unknown | Y | N | N | Y | In text “ No reported adverse events”
Dickinson et al., 2008 USA (91) Miscellaneous Uses | Single-center RCT | rhBMP2/ACS n=9 (dose not given) | Y | N | Y | N | N | Y
Dickinson et al., 2008 USA (91) Miscellaneous Uses | Single-center RCT | ICBG n=12 | Y | N | Y | N | N | Y
Ekrol et al., 2008 UK (97) Miscellaneous Uses | Prospective randomized cohort | rhBMP2 Non bridging external fixation n=4 | Y | N | Y | N | Y | Y | This is all text reporting that is very difficult to follow. One patient developed extra-osseous bone formation
Ekrol et al., 2008 UK (97) Miscellaneous Uses | Prospective randomized cohort | Bone graft Non bridging external fixation n=6 | Y | N | Y | N | Y | Y | This is all text reporting that is very difficult to follow. One patient developed extra-osseous bone formation
Ekrol et al., 2008 UK (97) Miscellaneous Uses | Prospective randomized cohort | rhBMP-7 internal fixation w/ pi-plate n=10 | Y | N | Y | N | Y | Y | This is all text reporting that is very difficult to follow. One patient developed extra-osseous bone formation
Ekrol et al., 2008 UK (97) Miscellaneous Uses | Prospective randomized cohort | Bone graft internal fixation w/ pi-plate n=10 | Y | N | Y | N | Y | Y | This is all text reporting that is very difficult to follow. One patient developed extra-osseous bone formation
Geesink et al., 1999 Netherlands (98) Miscellaneous Uses | Prospective double-blind randomized study | Untreated n=6 | Y | N | Y | N | N | Y | No anti-body increase after treatment
Geesink et al., 1999 Netherlands (98) Miscellaneous Uses | Prospective double-blind randomized study | DMB n=6 | Y | N | Y | N | N | Y | No anti-body increase after treatment
Geesink et al., 1999 Netherlands (98) Miscellaneous Uses | Prospective double-blind randomized study | Collagen type I n=6 | Y | N | Y | N | N | Y | No anti-body increase after treatment
Geesink et al., 1999 Netherlands (98) Miscellaneous Uses | Prospective double-blind randomized study | OP-1 (2.5mg) with Collagen type I n=6 | Y | N | Y | N | N | Y | No anti-body increase after treatment
Karrholm et al., 2006 UK (111) Miscellaneous Uses | Single-center case-control | Cups: rhBMP7/ALG (1 g/pt) n=10 | N | Unknown | Unknown | N | Unknown | N | No harms reporting
Karrholm et al., 2006 UK (111) Miscellaneous Uses | Single-center case-control | Cups: ALG n=10 | N | Unknown | Unknown | N | Unknown | N | No harms reporting
Karrholm et al., 2006 UK (111) Miscellaneous Uses | Single-center case-control | Stems: rhBMP7/ALG (1 g/pt) n=11 | N | Unknown | Unknown | N | Unknown | N | No harms reporting
Karrholm et al., 2006 UK (111) Miscellaneous Uses | Single-center case-control | Stems: ALG n=30 | N | Unknown | Unknown | N | Unknown | N | No harms reporting
Maeda et al., 2009 USA, Japan (109) Miscellaneous Uses | Cohort study with nonconcurrent control group | rhBMP2/BGE n=23 (64–320 mg/pt) | N | Unknown | Y | N | Unknown | N | No harms reporting
Maeda et al., 2009 USA, Japan (109) Miscellaneous Uses | Cohort study with nonconcurrent control group | ICBG n=32 | N | Unknown | Y | N | Unknown | N | No harms reporting