# Specific Harms Tables

Appendix 4 Table A Specific Harms Associated with BMP in Noncomparative Studies

Investigators (ref #) | Surgical Intervention | No. pts | BMP Type | Dose (mg/pt) | FDA Status | Specific Harms | Incidence (%)
Dickerman et al., 2009 (150) | Posterolateral lumbar fusion | 1 | rhBMP2 | NA | Off | Heterotopic bone formation in the psoas and iliacus | 100
Brower et al., 2008 (148) | Posterior lumbar interbody fusion | 1 | rhBMP2 | NA | Off | Psoas ossification | 100
Moshel et al., 2008 (147) | L5-S1 TLIF (3 operations) | 1 | rhBMP2 | NA | Off | Serum BMP2 antibodies detected | 100
Shah et al., 2008 (181) | Cranial reconstruction for craniosynotosis | 1 | rhBMP2 | NA | Off | Unusual swelling and edema that resolved after the removal of the rhBMP2 strips | 100
D'Agostino et al., 2007 (158) | Allograft w/ rhBMP7 femoral fusion | 1 | rhBMP7 | NA | Off | Heterotopic ossification | 100
Wysocki et al., 2007 (155) | Revision of distal humeral non-union | 1 | rhBMP7 | 3.5 | Off | Profound heterotopic ossification | 100
Perri et al., 2007 (125) | Anterior cervical disectomy and fusion | 1 | rhBMP2 | NA | Off | Soft tissue swelling in neck and dysphagia | 100
Aryan et al., 2007 (116) | Corpectomy of osteomylitic patients in 1–3 levels | 15 | rhBMP2 | 4.2 | Off | Dysphonia or dysphagia | 66
Meisel et al, 2008 (138) | Posterior lumbar interbody fusion | 17 | rhBMP2 | 12 | Off | Hererotopic ossification of humeral shaft | 50
Meisel et al, 2008 (138) | Posterior lumbar interbody fusion | 17 | rhBMP2 | 12 | Off | Hererotopic ossification of distal humerus | 25
Joseph et al., 2007 (134) | Instrumented lumbar interbody PLIF and TLIF fusions | 23 | rhBMP2 | 4.2 per lever | Off | Heterotopic epidural bone formation in 5 levels | 21
Boakye et al., 2005 (114) | Anterior cervical discectomy and fusion | 24 | rhBMP2 | 4.2 per level | Off | Heterotopic bone formation | 13
Boakye et al., 2005 (114) | Anterior cervical discectomy 1–3 levels | 24 | rhBMP2 | 4.2 per level | Off | Transient dysphagia | 9
Tumialan et al. 2008 (119) | ACDF 1–4 levels | 200 | rhBMP2 | 2.1-0.7 per level | Off | Significant dysphagia | 7
Aryan et al., 2007 (116) | Corpectomy of osteomylitic patients in 1–3 levels | 15 | rhBMP2 | 4.2 | Off | Persistent dysphagia | 7
Lanman et al. 2004 (113) | Anterior cervical interbody fusion 1–3 levels | 20 | rhBMP2 | NA | Off | Dysphagia | 5
Tumialan et al. 2008 (119) | ACDF 1–4 levels | 200 | rhBMP2 | 2.1-0.7 per level | Off | Mild dysphagia | 3
Tumialan et al. 2008 (119) | ACDF 1–4 levels | 200 | rhBMP2 | 2.1-0.7 per level | Off | Severe dysphagia | 3
Rihn et al., 2009 (139) | Single level TLIF | 86 | rhBMP2 | 8.4 | Off | Ectopic bone formation | 2
Rihn et al. 2009 (186) | Single level TLIF | 48 | rhBMP2 | NA | Off | Ectopic bone formation | 2
Tumialan et al. 2008 (119) | ACDF 1–4 levels | 200 | rhBMP2 | 2.1-0.7 per level | Off | Readmission for difficulty breathing or swallowing in 1 week post-op | 2
Tumialan et al. 2008 (119) | ACDF 1–4 levels | 200 | rhBMP2 | 2.1-0.7 per level | Off | Moderate dysphagia | 2
Tumialan et al. 2008 (119) | ACDF 1–4 levels | 200 | rhBMP2 | 2.1-0.7 per level | Off | PEG tube | 2

Appendix 4 Table B Graft Donor Site Harms in On-Label BMP Comparative Studies

Investigator (yr, country, ref #) Surgical site | Study design | Comparison(s) No. pts (BMP dose) | Did the study assess harms at the graft donor site? | Were there any infections at the graft donor site (#) | What harms were reported at the graft donor site? | Comments
Boden et al., 2000 USA (71) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP2 n=11 (4.2–8.4 mg/pt) | N | NA | NA
Boden et al., 2000 USA (71) Lumbar Spine | Multicenter, nonblinded RCT | ICBG n=3 | N | NA | NA
Burkus et al., 2002 USA (72) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP2 n=143 (4.2–8.4 mg/pt) | Y | Y(1) | 8 adverse events related to harvesting were identified. Injury to lateral femoral nerve (3)
Burkus et al., 2002 USA (72) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP2 n=143 (4.2–8.4 mg/pt) | Y | Y(1) | Avulsion fractures (2)
Burkus et al., 2002 USA (72) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP2 n=143 (4.2–8.4 mg/pt) | Y | Y(1) | Infection (1)
Burkus et al., 2002 USA (72) Lumbar Spine | Multicenter, nonblinded RCT | ICBG n=136 | Y | Y(1) | Hematoma (1)
Burkus et al., 2002 USA (72) Lumbar Spine | Multicenter, nonblinded RCT | ICBG n=136 | Y | Y(1) | Pain at harvest site 12.7 on 20 point scale immediately after surgery. At 24 months 32% still experienced pain of 1.8 on 20 point scale and 16% were bothered by graft site appearance.
Burkus et al., 2003 USA (182) Lumbar Spine Note: may include pts in Burkus et al., 2003, (80) | Retrospective combined comparative analysis | rhBMP2 n=277 (dose NR) | Y | Y (5) | 32% reported pain at harvest site 2 years post surgery.
Burkus et al., 2003 USA (182) Lumbar Spine Note: may include pts in Burkus et al., 2003, (80) | Retrospective combined comparative analysis | ICBG n=402 | Y | Y (5) | 5 other adverse events at harvest site.
Dawson et al., 2009 USA (73) Lumbar Spine | Multicenter nonblinded RCT | rhBMP2/CRM n=25 (12 mg/pt) | Y | Y (1) | Infection
Dawson et al., 2009 USA (73) Lumbar Spine | Multicenter nonblinded RCT | | Y | Y (1) | Infection
Dawson et al., 2009 USA (73) Lumbar Spine | Multicenter nonblinded RCT | ICBG n=21 | Y | Y (1) | Infection
Govender et al. for the BESTT study group 2002 South Africa (74) Lumbar Spine | Multi-center, single blind, RCT | rhBMP2 (1) n=151 (6 mg/patient) | N | NA | NA
Govender et al. for the BESTT study group 2002 South Africa (74) Lumbar Spine | Multi-center, single blind, RCT | (2) n=149 (12 mg/patient) | N | NA | NA
Govender et al. for the BESTT study group 2002 South Africa (74) Lumbar Spine | Multi-center, single blind, RCT | (3) n=150 Standard care (IM nail fixation and soft tissue management) | N | NA | NA
Swiontkowski et al., 2006 USA (81) Lumbar Spine Note: This paper reports on 131 of the same patients included in Govender et al., 2002 (74) | Subgroup analysis of combined data from two prospective randomized trials with identical designs | rhBMP2 (1) n=169 (12 mg/patient) | N | NA | NA | No reporting
Swiontkowski et al., 2006 USA (81) Lumbar Spine Note: This paper reports on 131 of the same patients included in Govender et al., 2002 (74) | Subgroup analysis of combined data from two prospective randomized trials with identical designs | (2) n=169 Standard care (IM nail fixation and soft tissue management) | N | NA | NA | No reporting
Boyne et al., 2005 USA (75) Maxillofacial Defects | Multicenter randomized dose-comparison, safety and efficacy study | rhBMP2/ACS (6–24 mg/pt) n=18 | Y | N | Edema, rash and pain at the harvest site.
Boyne et al., 2005 USA (75) Maxillofacial Defects | Multicenter randomized dose-comparison, safety and efficacy study | rhBMPS2/ACS (15–48 mg/pt) n=17 | Y | N | Edema, rash and pain at the harvest site.
Boyne et al., 2005 USA (75) Maxillofacial Defects | Multicenter randomized dose-comparison, safety and efficacy study | AGB n=13 | Y | N | Edema, rash and pain at the harvest site.
Fiorellini et al., 2005 USA (76) Maxillofacial Defects | Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study | rhBMP2/ACS (mn dose 0.9 mg/pt) n=22 | N | NA | NA | No reporting
Fiorellini et al., 2005 USA (76) Maxillofacial Defects | Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study | rhBMP2/ACS (mn dose 1.9 mg/pt) n=21 | N | NA | NA | No reporting
Fiorellini et al., 2005 USA (76) Maxillofacial Defects | Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study | Placebo n=17 | N | NA | NA | No reporting
Fiorellini et al., 2005 USA (76) Maxillofacial Defects | Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study | No Tx n=20 | N | NA | NA | No reporting
Triplett et al., 2009 USA (77) Maxillofacial Defects | Multicenter, nonblinded RCT | rhBMP2/ACS n=80 (12–24 mg/pt) | Y | N | Pain at harvest site
Triplett et al., 2009 USA (77) Maxillofacial Defects | Multicenter, nonblinded RCT | AGB n=80 | Y | N | Pain at harvest site
van den Bergh et al., 2000 Netherlands (82) Maxillofacial Defects | Retrospective cohort study | rhBMP7/ACS n=3 (2.5 mg/pt) | N | NA | NA
van den Bergh et al., 2000 Netherlands (82) Maxillofacial Defects | Retrospective cohort study | ICBG n=3 | N | NA | NA
Calori et al., 2008 Italy (78) Long Bone Nonunions | Single-center, nonblinded RCT | rhBMP7/ACS n=60 (3.5–7.0 mg/pt) | N | NA | NA
Calori et al., 2008 Italy (78) Long Bone Nonunions | Single-center, nonblinded RCT | PRP n=60 | N | NA | NA
Dahabreh et al., 2008 UK, Italy (83) Long Bone Nonunions | Retrospective cohort study | rhBMP7/ACS n=15 (3.5 mg/pt) | Y | Y (1) | Wound infection and abscessat the donor site in one patient.
Dahabreh et al., 2008 UK, Italy (83) Long Bone Nonunions | Retrospective cohort study | ICBG n=12 | Y | Y (1) | Wound infection and abscessat the donor site in one patient.
Friedlaender et al., 2001 USA (79) Long Bone Nonunions | Multicenter, partially blinded RCT | rhBMP7/ACS n=61 (3.5–7.0 mg/pt) | N | NA | NA
Friedlaender et al., 2001 USA (79) Long Bone Nonunions | Multicenter, partially blinded RCT | AGB n=61 | N | NA | NA

Appendix 4 Table C Graft Donor Site Harms in Off-Label BMP Comparative Studies

Investigator (yr, country, ref #) Surgical site | Study design | Comparison(s) No. pts (BMP dose) | Did the study assess harms at the graft donor site? | Were there any infections at the graft donor site (#) | What harms were reported at the graft donor site? | Comments
Boden et al., 2002 USA (84) Lumbar Spine | Multicenter nonblinded RCT | rhBMP2/CRM plus Texas Scottish Rite Hospital (TSRH) Spinal System (TSRHSS) n=11 (40 mg/pt) | N | NA | NA | No harms reporting
Boden et al., 2002 USA (84) Lumbar Spine | Multicenter nonblinded RCT | rhBMP2/CRM alone n=11 (40 mg/pt) | N | NA | NA | No harms reporting
Boden et al., 2002 USA (84) Lumbar Spine | Multicenter nonblinded RCT | ICBG plus TSRHSS n=5 | N | NA | NA | No harms reporting
Burkus et al., 2005 USA (85) Lumbar Spine Note: includes all pts from Burkus et al., 2002, rec# 11510; same pts as Burkus et al., 2006, rec# 6640 | Multicenter, nonblinded RCT | rhBMP2 n=79 (8–12 mg/pt) | N | N | N
Burkus et al., 2005 USA (85) Lumbar Spine Note: includes all pts from Burkus et al., 2002, rec# 11510; same pts as Burkus et al., 2006, rec# 6640 | Multicenter, nonblinded RCT | ICBG N=52 | N | N | N
Dimar et al., 2009 USA (86) Lumbar Spine Note: contains pts in Glassman et al., 2007, rec# 4040; Dimar et al., 2006 rec# 5480; Glassman et al., 2005, rec# 8040 | Multicenter nonblinded RCT | rhBMP2/CRM n=239 (40 mg/pt) | Y | 45 infections in the bone-graft group. Unclear how many of those were at infection site. | Pain at graft site mean pain score at discharge (11.3), 7.9 at 6 weeks, 6.3 at three months with minimal improvement after that. 60% of patients had persistent donor-site pain, with a mean score of 5.1 at 24 months.
Dimar et al., 2009 USA (86) Lumbar Spine Note: contains pts in Glassman et al., 2007, rec# 4040; Dimar et al., 2006 rec# 5480; Glassman et al., 2005, rec# 8040 | Multicenter nonblinded RCT | ICBG n=224 | Y | 45 infections in the bone-graft group. Unclear how many of those were at infection site.
Dimar et al., 2009 USA (86) Lumbar Spine Note: contains pts in Glassman et al., 2007, rec# 4040; Dimar et al., 2006 rec# 5480; Glassman et al., 2005, rec# 8040 | Multicenter nonblinded RCT | ICBG n=224 | Y | 45 infections in the bone-graft group. Unclear how many of those were at infection site. | Total of 17 graft site related events.
Glassman et al., 2007 USA (99) Lumbar Spine | Retrospective with historical control group | rhBMP2 n=91 (12 mg/pt) | N | NA | No harms reporting
Glassman et al., 2007 USA (99) Lumbar Spine | Retrospective with historical control group | ICBG n=35 | N | NA | No harms reporting
Glassman et al., 2008 USA (87) Lumbar Spine | Multicenter nonblinded RCT | rhBMP2 n=50 (dose not reported) | N | Unclear 4 wound infections reported as perioperative complications. Unclear if this is at the donor site or not.
Glassman et al., 2008 USA (87) Lumbar Spine | Multicenter nonblinded RCT | ICBG n=52 | N | Unclear 4 wound infections reported as perioperative complications. Unclear if this is at the donor site or not.
Haid et al., 2004 USA (88) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP2 n=34 (4.2–8.4) | Y | N | Pain (1) | At 24 months 60% of patients still were experiencing pain. Pain scores at 2 years were 5.5 on 20 point scale and 13.3% still felt the appearance of the graft site was bothersome.
Haid et al., 2004 USA (88) Lumbar Spine | Multicenter, nonblinded RCT | ICBG N=33 | Y | N | Hematoma (1) | At 24 months 60% of patients still were experiencing pain. Pain scores at 2 years were 5.5 on 20 point scale and 13.3% still felt the appearance of the graft site was bothersome.
Johnsson et al., 2002 Sweden (92) Lumbar Spine | Multicenter nonblinded RCT | rhBMP7 n=10 (7 mg/pt) | Y | N | Persistent minor pain at harvest site (1)
Johnsson et al., 2002 Sweden (92) Lumbar Spine | Multicenter nonblinded RCT | ICBG n=10 | Y | N | Persistent minor pain at harvest site (1)
Kanayama et al., 2006 Japan, USA (93) Lumbar Spine | Multicenter nonblinded RCT | rhBMP7 n=9 (7 mg/pt) | N | NA | NA | No reporting
Kanayama et al., 2006 Japan, USA (93) Lumbar Spine | Multicenter nonblinded RCT | AGB/CRM n=10 | N | NA | NA | No reporting
Mummaneni et al., 2004 USA (100) Lumbar Spine | Retrospective single-center cohort study | rhBMP2/AGB n=25 (8.4 mg/pt) | Y | N | 58% of patients at 6 months reported donor site pain with a mean score of 5 on 10 point VAS.
Mummaneni et al., 2004 USA (100) Lumbar Spine | Retrospective single-center cohort study | ICBG N=19 | Y | N | 58% of patients at 6 months reported donor site pain with a mean score of 5 on 10 point VAS.
Pradhan et al., 2006 USA (101) Lumbar Spine | Prospective consecutive patient single-center cohort study | rhBMP2 n=9 (dose NR) | N | NA | NA
Pradhan et al., 2006 USA (101) Lumbar Spine | Prospective consecutive patient single-center cohort study | ICBG n=27 | N | NA | NA
Singh et al., 2006 USA (102) Lumbar Spine | Prospective single-center case-matched cohort study | rhBMP2/ICBG n=39 (12–36 mg/pt) | N | NA | NA | No reporting
Singh et al., 2006 USA (102) Lumbar Spine | Prospective single-center case-matched cohort study | ICBG N=11 | N | NA | NA | No reporting
Slosar et al., 2007 USA (103) Lumbar Spine | Prospective consecutive patient single-center cohort study | rhBMP2 n=45 (3–9 mg/pt) | N | NA | NA
Slosar et al., 2007 USA (103) Lumbar Spine | Prospective consecutive patient single-center cohort study | ALG N=30 | N | NA | NA
Vaccaro et al., 2008 USA (94) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP7 n=207 (7 mg/pt) | Y | N | VAS assessment of donor site pain at 12, 24 and 36 months showed 44% , 45%, and 35% of participants reporting pain at donor site. VAS rating was 2.1 at 12 months, 1.2 at 24 and 1.1 at 36 months.
Vaccaro et al., 2008 USA (94) Lumbar Spine | Multicenter, nonblinded RCT | ICBG n=86 | Y | N | VAS assessment of donor site pain at 12, 24 and 36 months showed 44% , 45%, and 35% of participants reporting pain at donor site. VAS rating was 2.1 at 12 months, 1.2 at 24 and 1.1 at 36 months.
Vaccaro et al., 2008 USA (95) Lumbar Spine Note: Long-term F/U study that includes all pts from Vaccaro et al., 2004 (184), and Vaccaro et al., 2005, (185) | Multicenter, nonblinded RCT | rhBMP7 n=24 (7 mg/pt) | Y | N | None
Vaccaro et al., 2008 USA (95) Lumbar Spine Note: Long-term F/U study that includes all pts from Vaccaro et al., 2004 (184), and Vaccaro et al., 2005, (185) | Multicenter, nonblinded RCT | ICBG n=12 | Y | N | None
Baskin et al., 2003 USA (89) Cervical Spine | Multicenter, nonblinded RCT | rhBMP2/ALG n=18 (0.6–1.2 mg/pt) | Y | N | Pain at the graft site Appearance of the graft site. | No differences between groups at 6 months. At 12 months some patients still had pain and only rated the appearance of the graft site as fair.
Baskin et al., 2003 USA (89) Cervical Spine | Multicenter, nonblinded RCT | ICBG/ALG n=15 | Y | N | Pain at the graft site Appearance of the graft site. | No differences between groups at 6 months. At 12 months some patients still had pain and only rated the appearance of the graft site as fair.
Butterman et al., 2008 USA (104) Cervical Spine | Prospective nonrandomized cohorts of consecutive patients | rhBMP2/CRA n=30 (0.9–3.7 mg/pt) | Y | Y (1) | Infection (1)
Butterman et al., 2008 USA (104) Cervical Spine | Prospective nonrandomized cohorts of consecutive patients | ICBG n=36 | Y | Y (1) | ASIS fracture (1)
Butterman et al., 2008 USA (104) Cervical Spine | Prospective nonrandomized cohorts of consecutive patients | ICBG n=36 | Y | Y (1) | At 1 year follow-up those in the IBG group graft site, the VAS pain at donor site was only 0.2
Crawford et al., 2009 USA (105) Cervical Spine | Retrospective cohort of consecutive patients | rhBMP2/BGE n=41 (4.2–12 mg/pt) | Y | Y (1) | Iliac site deep infection (1)
Crawford et al., 2009 USA (105) Cervical Spine | Retrospective cohort of consecutive patients | ICBG n=36 | Y | Y (1) | Iliac site deep infection (1)
Smucker et al., 2006 USA (106) Cervical Spine | Retrospective case-control | rhBMP2/CRA n=69 (dose NR) | N | NA | NA | No reporting
Smucker et al., 2006 USA (106) Cervical Spine | Retrospective case-control | CRA n=165 | N | NA | NA | No reporting
Vaidya et al., 2007 USA (107) Cervical Spine | Retrospective cohorts of consecutive patients | rhBMP2 n=22 (1–3 mg/pt) | N | NA | None reported
Vaidya et al., 2007 USA (107) Cervical Spine | Retrospective cohorts of consecutive patients | ALG/DBM n=24 | N | NA | None reported
Boraiah et al., 2009 USA (108) Acute Tibial Fractures | Retrospective case series | rhBMP2 n=17 (12 mg/pt) | N | NA | NA | No harms reporting
Boraiah et al., 2009 USA (108) Acute Tibial Fractures | Retrospective case series | n=23 no BMP | N | NA | NA | No harms reporting
Jones et al., 2006 USA (90) Acute Tibial Fractures | Multi-center prospective RCT | rhBMP2 n=15 (12 mg/pt with allograft bone chips n=15 autogenous bone graft | Y | N | 14/15 in autograft group reported acute onset of pain at the donor site, lasted about 5 days to 4.5 months. Residual tenderness present in one patient through 12 months. 3 patients reported pustules or drainage at the donor site that lasted as long as 2 weeks
Ristiniemi et al., 2007 Finland (110) Acute Tibial Fractures | Retrospective cohort of matched patients | rhBMP7 n =20 | N | NA | NA
Ristiniemi et al., 2007 Finland (110) Acute Tibial Fractures | Retrospective cohort of matched patients | Matched Zone 43 fracture (OREF) n=20 | N | NA | NA
Bilic et al., 2006 Croatia, Netherlands (96) Miscellaneous Uses | Single-center, unblinded RCT | rhBMP7/AGB n=6 (3.5 mg/pt) | Y | N | Pain at the donor site
Bilic et al., 2006 Croatia, Netherlands (96) Miscellaneous Uses | Single-center, unblinded RCT | rhBMP7/ALG n=6 (3.5 mg/pt) | Y | N | Pain at the donor site
Bilic et al., 2006 Croatia, Netherlands (96) Miscellaneous Uses | Single-center, unblinded RCT | ICBG n=6 | Y | N | Pain at the donor site
Dickinson et al., 2008 USA (91) Miscellaneous Uses | Single-center RCT | rhBMP2/ACS n=9 (dose not given) | Y | N | Pain at the harvest site 100% reported pain post op
Dickinson et al., 2008 USA (91) Miscellaneous Uses | Single-center RCT | ICBG n=12 | Y | N | 3/12 reported pain 6 months after surgery
Ekrol et al., 2008 UK (97) Miscellaneous Uses | Prospective randomized cohort | rhBMP2 Non bridging external fixation n=4 | Y | N | Minor hematomas at the donor site (8)
Ekrol et al., 2008 UK (97) Miscellaneous Uses | Prospective randomized cohort | Bone graft Non bridging external fixation =6 | Y | N | Minor hematomas at the donor site (8)
Ekrol et al., 2008 UK (97) Miscellaneous Uses | Prospective randomized cohort | rhBMP7 internal fixation w/ pi-plate n=10 | Y | N | Minor hematomas at the donor site (8)
Ekrol et al., 2008 UK (97) Miscellaneous Uses | Prospective randomized cohort | Bone graft internal fixation w/pi-plate n=10 | Y | N | Minor hematomas at the donor site (8)
Geesink et al., 1999 Netherlands (98) Miscellaneous Uses | Prospective double-blind randomized study | Untreated n=6 | N | NA | NA
Geesink et al., 1999 Netherlands (98) Miscellaneous Uses | Prospective double-blind randomized study | DMB n=6 | N | NA | NA
Geesink et al., 1999 Netherlands (98) Miscellaneous Uses | Prospective double-blind randomized study | Collagen type I n=6 | N | NA | NA
Geesink et al., 1999 Netherlands (98) Miscellaneous Uses | Prospective double-blind randomized study | OP-1 (2.5mg) with Collagen type I n=6 | N | NA | NA
Karrholm et al., 2006 UK (111) Miscellaneous Uses | Single-center case-control | Cups rhBMP7/ALG (1 g/pt) n=10 | N | NA | NA | No harms reporting
Karrholm et al., 2006 UK (111) Miscellaneous Uses | Single-center case-control | Cups ALG n=10 | N | NA | NA | No harms reporting
Karrholm et al., 2006 UK (111) Miscellaneous Uses | Single-center case-control | Stems rhBMP7/ALG (1 g/pt) n=11 | N | NA | NA | No harms reporting
Karrholm et al., 2006 UK (111) Miscellaneous Uses | Single-center case-control | Stems ALG n=30 | N | NA | NA | No harms reporting
Maeda et al., 2009 USA, Japan (109) Miscellaneous Uses | Cohort study with nonconcurrent control group | rhBMP2/BGE n=23 (64–320 mg/pt) | N | NA | NA
Maeda et al., 2009 USA, Japan (109) Miscellaneous Uses | Cohort study with nonconcurrent control group | ICBG n=32 | N | NA | NA