# Reporting of Power and Sample Size Calculations

Appendix 3 Table A Assessment of Power and Sample Size in On-Label BMP Comparative Studies

Investigator (yr, country, ref #) Surgical site | Study design | Comparison(s) No. pts (BMP dose) | Were power and sample size calculated by the authors | Did the study enroll sufficient sample size to meet the sample size requirements | Comments
Boden et al., 2000 USA (71) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP2 n=11 (4.2–8.4 mg/pt) | N | NA
Boden et al., 2000 USA (71) Lumbar Spine | Multicenter, nonblinded RCT | ICBG n=3 | N | NA
Burkus et al., 2002 USA (72) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP2 n=143 (4.2–8.4 mg/pt) | N | NA
Burkus et al., 2002 USA (72) Lumbar Spine | Multicenter, nonblinded RCT | ICBG n=136 | N | NA
Burkus et al., 2003 USA (182) Lumbar Spine Note: may include pts in Burkus et al., 2003 (80) | Retrospective combined comparative analysis | rhBMP2 n=277 (dose NR) | N | NA
Burkus et al., 2003 USA (182) Lumbar Spine Note: may include pts in Burkus et al., 2003 (80) | Retrospective combined comparative analysis | ICBG n=402 | N | NA
Dawson et al., 2009 USA (73) Lumbar Spine | Multicenter nonblinded RCT | rhBMP2/CRM n=25 (12 mg/pt) | N | NA
Dawson et al., 2009 USA (73) Lumbar Spine | Multicenter nonblinded RCT | ICBG n=21 | N | NA
Govender et al. for the BESTT study group 2002 South Africa (74) Open Tibial Fracture | Multi-center, single blind, RCT | rhBMP2 n=151 (6 mg/patient) management) rhBMP2 n=149 (12 mg/patient) | Y | Needed 150 per group. Enrolled 150, 151, 149 Numbers completing the final study visit 138, 142, 141
Govender et al. for the BESTT study group 2002 South Africa (74) Open Tibial Fracture | Multi-center, single blind, RCT | n=150 Standard care (IM nail fixation and soft tissue | Y | Needed 150 per group. Enrolled 150, 151, 149 Numbers completing the final study visit 138, 142, 141
Swiontkowski et al., 2006 USA (81) Open Tibial Fracture Note: This paper reports on 131 of the same patients included in Govender et al., 2002 (74) | Subgroup analysis of combined data from two prospective randomized trials with identical designs | rhBMP2 n=169 (12 mg/patient) | N | NA
Swiontkowski et al., 2006 USA (81) Open Tibial Fracture Note: This paper reports on 131 of the same patients included in Govender et al., 2002 (74) | Subgroup analysis of combined data from two prospective randomized trials with identical designs | n=169 Standard care (IM nail fixation and soft tissue management) | N | NA
Boyne et al., 2005 USA (75) Maxillofacial Defects | Multicenter randomized dose-comparison, safety and efficacy study | rhBMP2/ACS (6–24 mg/pt) n=18 | N | NA
Boyne et al., 2005 USA (75) Maxillofacial Defects | Multicenter randomized dose-comparison, safety and efficacy study | rhBMP2/ACS (15–48 mg/pt) n=17 | N | NA
Boyne et al., 2005 USA (75) Maxillofacial Defects | Multicenter randomized dose-comparison, safety and efficacy study | AGB n=13 | N | NA
Fiorellini et al., 2005 USA (76) Maxillofacial Defects | Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study | rhBMP2/ACS (mn dose 0.9 mg/pt) n=22 | Y | Y | Looks like this was retrospectively determined.
Fiorellini et al., 2005 USA (76) Maxillofacial Defects | Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study | rhBMP2/ACS (mn dose 1.9 mg/pt) n=21 | Y | Y | Looks like this was retrospectively determined.
Fiorellini et al., 2005 USA (76) Maxillofacial Defects | Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study | Placebo n=17 | Y | Y | Looks like this was retrospectively determined.
Fiorellini et al., 2005 USA (76) Maxillofacial Defects | Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study | No Tx n=20 | Y | Y | Looks like this was retrospectively determined.
Triplett et al., 2009 USA (77) Maxillofacial Defects | Multicenter, nonblinded RCT | rhBMP2/ACS n=80 (12–24 mg/pt) | Y | Y
Triplett et al., 2009 USA (77) Maxillofacial Defects | Multicenter, nonblinded RCT | AGB n=80 | Y | Y
van den Bergh et al., 2000 Netherlands (82) Maxillofacial Defects | Retrospective cohort study | rhBMP7/ACS n=3 (2.5 mg/pt) | N | NA
van den Bergh et al., 2000 Netherlands (82) Maxillofacial Defects | Retrospective cohort study | ICBG n=3 | N | NA
Calori et al., 2008 Italy (78) Long Bone Nonunions | Single-center, nonblinded RCT | rhBMP7/ACS n=60 (3.5–7.0 mg/pt) | No | Power analysis showed that they had 78.5% power with the number of participants they enrolled. This was in the results section as a one liner. No methods included.
Calori et al., 2008 Italy (78) Long Bone Nonunions | Single-center, nonblinded RCT | PRP n=60 | No | Power analysis showed that they had 78.5% power with the number of participants they enrolled. This was in the results section as a one liner. No methods included.
Dahabreh et al., 2008 UK, Italy (83) Long Bone Nonunions | Retrospective cohort study | rhBMP7/ACS n=15 (3.5 mg/pt) | N | NA
Dahabreh et al., 2008 UK, Italy (83) Long Bone Nonunions | Retrospective cohort study | ICBG n=12 | N | NA
Friedlaender et al., 2001 USA (79) Long Bone Nonunions | Multicenter, partially blinded RCT | rhBMP7/ACS n=61 (3.5–7.0 mg/pt) | N | NA
Friedlaender et al., 2001 USA (79) Long Bone Nonunions | Multicenter, partially blinded RCT | AGB n=61 | N | NA

Appendix 3 Table B Assessment of Power and Sample Size in Off-Label BMP Comparative Studies

Investigator (yr, country, ref #) Surgical Site | Study design | Comparison(s) No. pts (BMP dose) | Were power and sample size calculated by the authors | Did the study enroll sufficient sample size to meet the sample size requirements | Comments
Boden et al., 2002 USA (84) Lumbar Spine | Multicenter nonblinded RCT | rhBMP2/CRM plus Texas Scottish Rite Hospital (TSRH) Spinal System (TSRHSS) n=11 (40 mg/pt) | N | NA
Boden et al., 2002 USA (84) Lumbar Spine | Multicenter nonblinded RCT | rhBMP2/CRM alone n=11 (40 mg/pt) | N | NA
Boden et al., 2002 USA (84) Lumbar Spine | Multicenter nonblinded RCT | ICBG plus TSRHSS n=5 | N | NA
Burkus et al., 2005 USA (85) Lumbar Spine Note: includes all pts from Burkus et al., 2002, rec# 11510; same pts as Burkus et al., 2006, rec# 6640 | Multicenter, nonblinded RCT | rhBMP2 n=79 (8–12 mg/pt) | N | NA
Burkus et al., 2005 USA (85) Lumbar Spine Note: includes all pts from Burkus et al., 2002, rec# 11510; same pts as Burkus et al., 2006, rec# 6640 | Multicenter, nonblinded RCT | ICBG N=52 | N | NA
Dimar et al., 2009 USA (86) Lumbar Spine Note: contains pts in Glassman et al., 2007, rec# 4040; Dimar et al., 2006 rec# 5480; Glassman et al., 2005, rec# 8040 | Multicenter nonblinded RCT | rhBMP2/CRM n=239 (40 mg/pt) | N | NA
Dimar et al., 2009 USA (86) Lumbar Spine Note: contains pts in Glassman et al., 2007, rec# 4040; Dimar et al., 2006 rec# 5480; Glassman et al., 2005, rec# 8040 | Multicenter nonblinded RCT | ICBG n=224 | N | NA
Glassman et al., 2007 USA (99) Lumbar Spine | Retrospective with historical control group | rhBMP2 n=91 (12 mg/pt) | N | NA
Glassman et al., 2007 USA (99) Lumbar Spine | Retrospective with historical control group | ICBG n=35 | N | NA
Glassman et al., 2008 USA (87) Lumbar Spine | Multicenter nonblinded RCT | rhBMP2 n=50 (dose not reported) | N | NA
Glassman et al., 2008 USA (87) Lumbar Spine | Multicenter nonblinded RCT | ICBG n=52 | N | NA
Haid et al., 2004 USA (88) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP2 34 (4.2–8.4) | N | NA
Haid et al., 2004 USA (88) Lumbar Spine | Multicenter, nonblinded RCT | ICBG N=33 | N | NA
Johnsson et al., 2002 Sweden (92) Lumbar Spine | Multicenter nonblinded RCT | rhBMP7 n=10 (7 mg/pt) | N | NA
Johnsson et al., 2002 Sweden (92) Lumbar Spine | Multicenter nonblinded RCT | ICBG n=10 | N | NA
Kanayama et al., 2006 Japan, USA (93) Lumbar Spine | Multicenter nonblinded RCT | rhBMP7 n=9 (7 mg/pt) | N | NA
Kanayama et al., 2006 Japan, USA (93) Lumbar Spine | Multicenter nonblinded RCT | AGB/CRM n=10 | N | NA
Mummaneni et al., 2004 USA (100) Lumbar Spine | Retrospective single-center cohort study | rhBMP2/AGB n=25 (8.4 mg/pt) | N | NA
Mummaneni et al., 2004 USA (100) Lumbar Spine | Retrospective single-center cohort study | ICBG N=19 | N | NA
Pradhan et al., 2006 USA (101) Lumbar Spine | Prospective consecutive patient single-center cohort study | rhBMP2 n=9 (dose NR) | N | NA
Pradhan et al., 2006 USA (101) Lumbar Spine | Prospective consecutive patient single-center cohort study | ICBG n=27 | N | NA
Singh et al., 2006 USA (102) Lumbar Spine | Prospective single-center case-matched cohort study | rhBMP2/ICBG n=39 (12–36 mg/pt) | N | NA
Singh et al., 2006 USA (102) Lumbar Spine | Prospective single-center case-matched cohort study | ICBG N=11 | N | NA
Slosar et al., 2007 USA (103) Lumbar Spine | Prospective consecutive patient single-center cohort study | rhBMP2 n=45 (3–9 mg/pt) | N | NA
Slosar et al., 2007 USA (103) Lumbar Spine | Prospective consecutive patient single-center cohort study | ALG N=30 | N | NA
Vaccaro et al., 2008 USA (94) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP7 n=207 (7 mg/pt) | Y | No they needed 180 in op-1 groups and 90 in the autograft group but only recruited 87 autograft. At 24 months they had 183 op-1 and 74 autograft at 36 months they had 144 OP-1 and 58 autograft.
Vaccaro et al., 2008 USA (94) Lumbar Spine | Multicenter, nonblinded RCT | ICBG n=86 | Y | No they needed 180 in op-1 groups and 90 in the autograft group but only recruited 87 autograft. At 24 months they had 183 op-1 and 74 autograft at 36 months they had 144 OP-1 and 58 autograft.
Vaccaro et al., 2008 USA (95) Lumbar Spine Note: Long-term F/U study that includes all pts from Vaccaro et al., 2004, (184), and Vaccaro et al., 2005, (185) | Multicenter, nonblinded RCT | rhBMP7 n=24 (7 mg/pt) | N | NA | Pilot study
Vaccaro et al., 2008 USA (95) Lumbar Spine Note: Long-term F/U study that includes all pts from Vaccaro et al., 2004, (184), and Vaccaro et al., 2005, (185) | Multicenter, nonblinded RCT | ICBG n=12 | N | NA | Pilot study
Baskin et al., 2003 USA (89) Lumbar Spine | Multicenter, nonblinded RCT | rhBMP2/ALG n=18 (0.6–1.2 mg/pt) | N | NA
Baskin et al., 2003 USA (89) Lumbar Spine | Multicenter, nonblinded RCT | ICBG/ALG n=15 | N | NA
Butterman et al., 2008 USA (104) Lumbar Spine | Prospective nonrandomized cohorts of consecutive patients | rhBMP2/CRA n=30 (0.9–3.7 mg/pt) | N | NA
Butterman et al., 2008 USA (104) Lumbar Spine | Prospective nonrandomized cohorts of consecutive patients | ICBG n=36 | N | NA
Crawford et al., 2009 USA (105) Lumbar Spine | Retrospective cohort of consecutive patients | rhBMP2/BGE n=41 (4.2–12 mg/pt) | N | NA
Crawford et al., 2009 USA (105) Lumbar Spine | Retrospective cohort of consecutive patients | ICBG n=36 | N | NA
Smucker et al., 2006 USA (106) Lumbar Spine | Retrospective case-control | rhBMP2/CRA n=69 (dose NR) | N | NA
Smucker et al., 2006 USA (106) Lumbar Spine | Retrospective case-control | CRA n=165 | N | NA
Vaidya et al., 2007 USA (107) Lumbar Spine | Retrospective cohorts of consecutive patients | rhBMP2 n=22 (1–3 mg/pt) | N | NA
Vaidya et al., 2007 USA (107) Lumbar Spine | Retrospective cohorts of consecutive patients | ALG/DBM n=24 | N | NA
Boraiah et al., 2009 USA (108) Acute Tibial Fractures | Retrospective case series | rhBMP2 n=17 (12 mg/pt) | N | NA
Boraiah et al., 2009 USA (108) Acute Tibial Fractures | Retrospective case series | n=23 no BMP | N | NA
Jones et al., 2006 USA (90) Acute Tibial Fractures | Multi-center prospective RCT | rhBMP2 n=15 (12 mg/pt with allograft bone chips | Y | Y | Retrospectively established
Jones et al., 2006 USA (90) Acute Tibial Fractures | Multi-center prospective RCT | n=15 autogenous bone graft | Y | Y | Retrospectively established
Ristiniemi et al., 2007 Finland (110) Acute Tibial Fractures (same as rec# 4560) | Retrospective cohort of matched patients | rhBMP7 n=20 | N | NA
Ristiniemi et al., 2007 Finland (110) Acute Tibial Fractures (same as rec# 4560) | Retrospective cohort of matched patients | Matched Zone 43 fracture (OREF) n=20 | N | NA
Bilic et al., 2006 Croatia, Netherlands (96) Miscellaneous Uses | Single-center, unblinded RCT | rhBMP7/AGB n=6 (3.5 mg/pt) | N | NA
Bilic et al., 2006 Croatia, Netherlands (96) Miscellaneous Uses | Single-center, unblinded RCT | rhBMP7/ALG n=6 (3.5 mg/pt) | N | NA
Bilic et al., 2006 Croatia, Netherlands (96) Miscellaneous Uses | Single-center, unblinded RCT | ICBG n=6 | N | NA
Dickinson et al., 2008 USA (91) Miscellaneous Uses | Single-center RCT | rhBMP2/ACS n=9 (dose not given) | N | NA
Dickinson et al., 2008 USA (91) Miscellaneous Uses | Single-center RCT | ICBG n=12 | N | NA
Ekrol et al., 2008 UK (97) Miscellaneous Uses | Prospective randomized cohort | rhBMP2 Non bridging external fixation n=4 | N | NA
Ekrol et al., 2008 UK (97) Miscellaneous Uses | Prospective randomized cohort | Bone graft non bridging external fixation n=6 | N | NA
Ekrol et al., 2008 UK (97) Miscellaneous Uses | Prospective randomized cohort | rhBMP7 internal fixation w/ pi-plate n=10 | N | NA
Ekrol et al., 2008 UK (97) Miscellaneous Uses | Prospective randomized cohort | Bone graft internal fixation w/ pi-plate n=10 | N | NA
Geesink et al., 1999 Netherlands (98) Miscellaneous Uses | Prospective double-blind randomized study | Untreated n=6 | N | NA
Geesink et al., 1999 Netherlands (98) Miscellaneous Uses | Prospective double-blind randomized study | DMB n=6 | N | NA
Geesink et al., 1999 Netherlands (98) Miscellaneous Uses | Prospective double-blind randomized study | Collagen type I n=6 | N | NA
Geesink et al., 1999 Netherlands (98) Miscellaneous Uses | Prospective double-blind randomized study | rhBMP7 (2.5mg) with collagen type I n=6 | N | NA
Karrholm et al., 2006 UK (111) Miscellaneous Uses | Single-center case-control | Cups rhBMP7/ALG (1 g/pt) n=10 | N | NA
Karrholm et al., 2006 UK (111) Miscellaneous Uses | Single-center case-control | Cups ALG n=10 | N | NA
Karrholm et al., 2006 UK (111) Miscellaneous Uses | Single-center case-control | Stems rhBMP7/ALG (1 g/pt) n=11 | N | NA
Karrholm et al., 2006 UK (111) Miscellaneous Uses | Single-center case-control | Stems ALG n=30 | N | NA
Maeda et al., 2009 USA, Japan (109) Miscellaneous Uses | Cohort study with nonconcurrent control group | rhBMP2/BGE n=23 (64–320 mg/pt) | N | NA
Maeda et al., 2009 USA, Japan (109) Miscellaneous Uses | Cohort study with nonconcurrent control group | ICBG n=32 | N | NA