# USPSTF Comparative Study Quality Rating

Appendix 2 Table A USPSTF Comparative Study Quality

Study (ref #) | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal | Interventions Comparable, Clearly Defined | Appropriate Analysis of Results | Funding or Sponsorship Source Acknowledged | Overall Rating
Baskin et al., 2003 (89) | U Randomization method not described Combined patients with one- and two-level DDD | U Low loss to F/U but unclear if groups were comparable at inception | Y | Y | U Cannot blind patients or surgeons to treatment, but used independent analyses of fusion Did not describe statistical analyses used | Y Medtronic Sofamor Danek | FAIR
Bilic et al., 2006 (96) | Y | Y | Y | Y | Y Surgeons were unaware of treatment group each patient was assigned after randomization Used independent analyses of fusion | N | GOOD
Boden et al., 2000 (71) | U Randomization method not described | Y | Y | Y | U No explicit ITT analysis Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y Medtronic Sofamor Danek | FAIR
Boden et al., 2002 (84) | U Randomization method not described | Y | Y | Y | U No explicit ITT analysis Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y Sponsor not specified | FAIR
Boraiah et al., 2009 (108) | U Retrospective study of consecutive patients | U | N There was no blinding of outcome assessment | U Does not provide the BMP-2 dose used | Y | N | POOR
Boyne et al., 2005 (75) | Y Multicenter randomized, dose-comparison, safety and efficacy study | Y | Y | U Mixed autograft and allograft bone in some patients, did not define numbers | Y Used ITT analysis and three independent masked CT scan reviewers | Y Wyeth/Genetics Institute | GOOD
Burkus et al., 2005 (85) Note: includes all pts from Burkus et al., 2002, rec# 11510; same pts as Burkus et al., 2006, rec# 6640 | Y | Y | Y | Y | U No explicit ITT analysis Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y Medtronic Sofamor Danek | FAIR
Burkus et al., 2003 (182) | N Retrospective combined analysis of data from 3 studies showing significant between group differences in prognostic factors | N Patients not accounted for amount to 16%–30% at end of 24 mos F/U | Y | Y | Y Used analysis of covariance to adjust for influence of prognostic factors Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y Medtronic Sofamor Danek | POOR
Burkus et al., 2003 (80) Note: may be subset of Burkus et al., 2002, (72) | U Patient demographic data very limited (only mean age, gender, tobacco use provided, no statistical comparisons) | Y | Y | Y | U ITT analysis not explicit Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y Not specified | FAIR
Burkus et al., 2002 (72) Note: may include pts in Burkus et al., 2003, (80) | U Randomization method not described | U Asserts > 90% F/U but based on ”expected” calculation | Y | Y | U ITT analysis not explicit Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | N | FAIR
Butterman et al., 2008 (104) | U Prospective non-randomized study of patients encountered in author’s clinical practice | U Patients made treatment decisions | Y | N Treatment differed based on patient’s decision Mixed local bone with BMP but did not discriminate | N Reported compiled results for groups with more than one level DDD Cannot blind patients or surgeons to treatment, did not report independent analyses of fusion | Y None | POOR
Calori et al., 2008 (78) | Y | Y | Y | N Adjuvant bone grafts used according to surgeon’s choice Revision of fixation according to surgeon’s choice | U Unclear if analysis of fusion was independent and blinded | Y None | POOR
Crawford et al., 2009 (105) | U Not a randomized study Consecutive patients | U | U Only reported complications | N Bone graft extenders used at surgeon’s discretion but not reported | Y Analysis of complications based on independent chart review by individual uninvolved with patient treatment | Y None | POOR
Dahabreh et al., 2008 (83) | U Retrospective study of consecutive patients Primarily a cost study | U | U No clinical health outcomes reported | U Do not report dose of rhBMP7 that was used per pt | U No clinical health outcomes reported | N | POOR
Dawson et al., 2009 (90) | Y Randomization stratified by site with fixed block size of 4 | Y | Y | Y | Y Used modified ITT analysis that accounted for second surgery failures Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y Medtronic Sofamor Danek | GOOD
Dickinson et al., 2008 (91) | U Randomization method not described | U | U Validity of outcome scoring systems is unclear | U Did not provide dose information for rhBMP2 | Y Cannot blind patients of surgeons, but used independent analyses of CT scans | Y Academic award | POOR
Dimar et al., 2009 (86) Note: contains all pts in Glassman et al., 2007, rec# 4040; Dimar et al., 2006 rec# 5480; Glassman et al., 2005, rec# 8040 | Y | Y | Y | Y | N Primary analysis predefined to be as-treated for assessing a noninferiority hypothesis Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y Medtronic Sofamor Danek | FAIR
Ekrol et al., 2008 (97) | N Randomization not specified After 10 of 30 pts, treatment changed from external fixation to ORIF w/ pi-plate | Y 0 pts. lost to FU | Y | Y | U No explicit ITT analysis, authors Independent radiographic analysis blinded to treatment | Y Authors state no conflict of interest | POOR
Fiorellini et al., 2005 (76) | U Double-blind, multicenter randomized, placebo-control dose-comparison, safety and efficacy study Scant demographic data | U Cannot ascertain comparability of patient groups because data not provided | Y | Y | Y Used ITT analysis and three independent masked CT scan reviewers | Y Wyeth/Genetics Institute | FAIR
Friedlaender et al., 2001 (79) | N Statistically higher number of atrophic nonunions and trend to more smokers in rhBMP7 group Surgeons were aware of assigned treatment group after randomization | Y | Y | Y | Y Surgeons not blinded to treatment, but used independent analyses of fusion | Y Stryker Biotech | FAIR
Geesnik et al., 1999 (98) | Patient randomization method not mentioned. Comparison of OP-1 on type I collagen sponge vs. collagen sponge alone was randomized, double-blinded | Y No pts. lost to FU 2 pts missed 1 FU appointment | Y | Y | N Missing values for 2 missed FU appointments not imputed Radiographic analysis conducted by 2 surgeons blinded to treatment | Y Stryker Biotech | FAIR
Glassman et al., 2008 (87) | U Randomization method not described | Y | Y | N Reported preparation of BMP according to label, but do not provide dose Reported use of bone graft extender in 100% of BMP cases and 67% of ICBG cases, plus local bone in 100% cases in both groups, | N No explicit ITT analysis Reported compiled data for multilevel fusions | Y Norton Healthcare | POOR
Glassman et al., 2007 (99) | N Retrospective study using historical controls | Y | N Did not report clinical health outcomes | N Reported use of bone graft extender in 100% of BMP cases, compared to ICBG controls | Y Reported fusion data from disparate groups separately Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y Norton Healthcare Medtronic Sofamor Danek | POOR
Govender et al, 2002 (74) | N Statistically significant difference in age rhBMP2 (12mg group) was younger 37 (for standard of care and the other treatment group) vs. 33 years Few demographics provided, and significance testing is not shown. Surgeons were not blinded to treatment assignment after randomization | Y | Y | Y | Y Surgeons not blinded but they used their conclusions in conjunction with an independent board who analyzed fusion | Y Wyeth/Genetics Institute | FAIR
Haid et al., 2004 (88) | U Randomization method not described Reports subset of pts from a larger terminated trial | U Do not know how reported patients compare to larger sample that would have been enrolled | Y | Y | U No explicit ITT analysis Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y Medtronic Sofamor Danek | POOR
Johnsson et al., 2002 (92) | U Minimal demographic data | Y | U Short F/U Did not use CT analysis to supplement plain radiographs | Y | N Cannot blind patients or surgeons to treatment, but used independent analyses of fusion Used patient subjective evaluation of back pain as only health outcome measure | Y Stryker Biotech provided rhBMP7 | POOR
Jones et al., 2006 (90) | U Randomization method not described | Y On the border with 20% loss to follow-up | N There was no blinding of outcome assessment however an independent review by a blinded assessor agreed with the clinical assessment | Y | Y There was no blinding of outcome assessment however an independent review by a blinded assessor agreed with the clinical assessment | Y Wyeth/Genetics Institute | FAIR
Kanayama et al., 2006 (93) | N Randomization method not described Minimal demographic data Significantly older pts in rhBMP7 group than ICBG group (p < 0.05) | N Groups different from beginning of study | Y | Y | N Cannot blind patients or surgeons to treatment, did not report independent analysis of fusion | Y None | POOR
Karrholm et al., 2006 (111) | Y Case-control study | Y | Y | U Reported use of one OP-1 kit per patient according to manufacturer instructions | N Did not report statistical analyses Study stopped early | Y Smith&Nephew Stryker Biotech | POOR
Maeda et al., 2009 (109) | N Demographics appear similar, but used a nonconcurrent control group | U | Y | Y | N Reported compiled fusion data for rhBMP2 group but interventions differed | Y None | POOR
Mummameni et al., 2004 (100) | U Not a randomized study Unknown if consecutive pts | U | N | N Used rhBMP2 plus local autograft bone or iliac crest bone Do not describe how pts were allocated to interventions | N No statistical analysis done Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | N | POOR
Pradhan et al., 2006 (101) | U Non-randomized prospective cohort study | Y | Y | Y | Y Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y None | FAIR
Ristiniemi et al., 2007 (110) (same as Ristiniemi et al., 2007, rec# 4560) | U Prospective study of consecutive patients who were matched to a control | U | Y | U Does not provide the BMP-7 dose used | Y | N | POOR
Singh et al., 2006 (102) | N Not a randomized study Consecutive sex-matched patients | Y | Y | U | N Did not seem to account for apparent large age differential Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | N | POOR
Slosar et al., 2007 (103) | U Prospective, sequential enrollment, not randomized Patients with multilevel fusion mixed with single-level fusion, scoliosis | U | Y | Y | U Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y Medtronic Sofamor Danek | POOR
Smucker et al., 2006 (106) | N Retrospective case-control study with consecutive patients | U Low loss to F/U but groups were clearly not comparable at inception | U Only reported complications | N Aspects of treatment with BMP varied according to surgeon’s discretion | Y Used multiple logistic regression to assess association between BMP use, complications and other variables | Y None | POOR
Swiontkowski et al., 2006 (81) Note: This paper reports on 131 of the same patients included in Govender (74) | N Few demographics provided, and significance testing is not shown. Surgeon’s were not blinded to treatment assignment after randomization Better description of the parent study randomization was needed | Y | Y | Y | Y | Y Wyeth/Genetics Institute Medtronic Sofamor Danek | FAIR
Triplett et al., 2009 (77) | Y Multicenter RCT | Y | Y | U Mixed autograft and allograft bone in some patients, did not define numbers | Y Used ITT analysis and three independent masked CT scan reviewers | N | GOOD
Vaccaro et al., 2008 (94) | Y | Y | Y | Y | Y Used modified ITT analysis Noninferiority design Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y None | GOOD
Vaccaro et al., 2008 (95) Note: Long-term F/U study that includes all pts from Vaccaro et al., 2004, (184), and Vaccaro et al., 2005, (185) | Y | N Only had full radiographic data for 61% of pts, and full clinical data for 72% of pts | Y | Y | U Analyzed and presented data as-treated and also with last-observation-carried forward method from 24 mos F/U Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | Y Stryker Biotech | POOR
Vaidya et al., 2007 (107) | U Retrospective study with consecutive patients | U Low loss to F/U but unclear if groups were comparable | Y | Y | Y Cannot blind patients or surgeons to treatment, but used independent analyses of fusion | N | POOR
van den Bergh et al., 2000 (82) | N Retrospective consecutive cohort | U All patients accounted for, but comparability is unclear | Y | Y | U Open label pilot study, not clear if radiographic results were indepdently assessed | N | POOR