# Data Abstraction Tables

Appendix 1 Table A On-Label BMP Comparative Studies

Appendix 1 Table B Off-Label BMP Comparative Studies

Appendix 1 Table C On-Label Comparative Studies Patient Characteristics

Appendix 1 Table D Off-Label Comparative Studies Patient Characteristics

Appendix 1 Table E On-Label Comparative Study Surgery and Perioperative Outcomes

Appendix 1 Table F Off-Label Comparative Study Surgery and Perioperative Outcomes

Appendix 1 Table G On-Label Comparative Study BMP-Related Adverse Events

Appendix 1 Table H Off-Label Comparative Study BMP-Related Adverse Events

Appendix 1 Table I On-Label Comparative Study Radiographic Outcomes

Appendix 1 Table J Off-Label Comparative Study Radiographic Outcomes

Appendix 1 Table K On-Label Comparative Study Pain Outcomes

Appendix 1 Table L Off-Label Comparative Study Pain Outcomes

Appendix 1 Table M On-Label Comparative Study Functional Outcomes

Appendix 1 Table N Off-Label Comparative Study Functional Outcomes

Appendix 1 Table O On-Label Comparative Study Quality of Life and Satisfaction Outcomes

Appendix 1 Table P Off-Label Comparative Study Quality of Life and Satisfaction Outcomes