# PEER REVIEWERS

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Richard A. Deyo, M.D., M.P.H.
  Kaiser Permanente Professor of Evidence-Based Family Medicine
  Departments of Family Medicine and Internal Medicine
  Oregon Health and Science University
  Portland, OR
- Sohail K. Mirza, M.D., M.P.H.
  Vice Chair
  Department of Orthopaedics
  Dartmouth-Hitchcock Medical Center
  Lebanon, NH