# REFERENCES

1 Senta H, Park H, Bergeron E, et al. Cell responses to bone morphogenetic proteins and peptides derived from them: biomedical applications and limitations. Cytokine Growth Factor Rev. 2009;20(3):213-222. [pmid: 19493693].
2 Hadjidakis DJ, Androulakis II. Bone remodeling. Ann N Y Acad Sci. 2006;1092:385-396. [pmid: 17308163].
3 Lanyon LE. Osteocytes, strain detection, bone modeling and remodeling. Calcif Tissue Int. Suppl 1. 1993;53:S102-S106. discussion S106-7. [pmid: 8275362].
4 Burchardt H, Enneking WF. Transplantation of bone. Surg Clin North Am. 1978;58(2):403-427. [pmid: 349741].
5 DePalma AF, Rothman RH, Lewinnek GE, et al. Anterior interbody fusion for severe cervical disc degeneration. Surg Gynecol Obstet. 1972;134(5):755-758. [pmid: 5031486].
6 Kim CH, Takai E, Zhou H, et al. Trabecular bone response to mechanical and parathyroid hormone stimulation: the role of mechanical microenvironment. J Bone Miner Res. 2003;18(12):2116-2125. [pmid: 14672346].
7 Karsdal MA, Martin TJ, Bollerslev J, et al. Are nonresorbing osteoclasts sources of bone anabolic activity?. J Bone Miner Res. 2007;22(4):487-494. [pmid: 17227224].
8 Karsdal MA, Henriksen K, Sorensen MG, et al. Acidification of the osteoclastic resorption compartment provides insight into the coupling of bone formation to bone resorption. Am J Pathol. 2005;166(2):467-476. [pmid: 15681830].
9 Martin TJ, Sims NA. Osteoclast-derived activity in the coupling of bone formation to resorption. Trends Mol Med. 2005;11:76-81. [pmid: 15694870].
10 Henriksen K, Neutzsky-Wulff AV, Bonewald LF, et al. Local communication on and within bone controls bone remodeling. Bone. 2009;44:1026-1033. [pmid: 19345750].
11 Hulth A. Current concepts in fracture healing. Clin Orthop. 1989;249:265-284. [pmid: 2684464].
12 Malloy KM, Hilibrand AS. Autograft versus allograft in degenerative cervical disease. Clin Orthop Rel Res. 2002;394:27-38. [pmid: 11795743].
13 Galler RM, Sonntag VK. Bone graft harvest. Barrow Quarterly. Last accessed February 2010. 2003;19(4):13-19. Available online at www.thebarrow.org/Education/Barrow_Quarterly/Vol_19_No_4_2003/158516.
14 Yue WM, Brodner W, Highland TR. Long-term results after anterior cervical discectomy and fusion with allograft and plating. Spine. 2005;30(19):2138-2144. [pmid: 16205338].
15 Daftari TK, Whitesides TE Jr, Heller JG, et al. Nicotine on the revascularization of bone graft. An experimental study in rabbits. Spine. 1994;19:904-911. [pmid: 7516583].
16 Riebel GD, Boden SD, Whitesides TE, et al. The effect of nicotine on incorporation of cancellous bone graft in an animal model. Spine. 1995;20:2198-2202. [pmid: 8545712].
17 Rubenstein I, Yong T, Rennard SI, et al. Cigarette smoke extract attenuates endothelium-dependent arteriolar dilation in vivo. Am J Physiol. 1991;261:H1913-H1918. [pmid: 1750544].
18 Silcox DH 3rd, Daftari T, Boden SD, et al. The effects of nicotine on spinal fusion. Spine. 1995;20:1549-1553. [pmid: 7570168].
19 Macey LR, Kana SM, Jingushi S, et al. Defect of early fracture-healing in experimental diabetes. J Bone Joint Surg Am. 1989;75(5):722-733. [pmid: 2659600].
20 Gruber R, Koch H, Doll BA, et al. Fracture healing in the elderly patient. Exp Gerontol. 2006;41(11):1080-1093. [pmid: 17092679].
21 Manolagas SC. Birth and death of bone cells: basic regulatory mechanisms and implications for the pathogenesis and treatment of osteoporosis. Endocr Rev. 2000;21:115-137. [pmid: 10782361].
22 Riggs BL, Parfitt AM. Drugs used to treat osteoporosis: the critical need for a uniform nomenclature based on their action on bone remodeling. J Bone Miner Res. 2005;20:117-184. [pmid: 15619677].
23 Cummings SR, Melton LJ. Epidemiology and outcomes of osteoporotic fractures. Lancet. 2002;359:1761-1767. [pmid: 12049882].
24 Riggs BL, Melton LJ 3rd. The worldwide problem of osteoporosis: insights afforded by epidemiology. Bone. 1995;17:505S-511S. [pmid: 8573428].
25 Raisz LG. Clinical practice. Screening for osteoporosis. N Engl J Med. 2005;353:164-171. [pmid: 16014886].
26 Garrison KR, Donell S, Ryder J, et al. Clinical effectiveness and cost-effectiveness of bone morphogenetic proteins in the non-healing of fractures and spinal fusion: a systematic review. Health Technol Assess. 2007;11(30):1-150. [pmid: 17669279].
27 Arrington ED, Smith WJ, Chambers HG, et al. Complications of iliac crest bone graft harvesting. Clin Orthop. 1996;329:300-309. [pmid: 8769465].
28 Bauer TW. An overview of the histology of skeletal substitute materials. Arch Pathol Lab Med. 2007;131(2):217-224. [pmid: 17284105].
29 Fraser JF, Hartl R. Anterior approaches to fusion of the cervical spine: a metaanalysis of fusion rates. J Neurosurg Spine. 2007;6(4):298-303. [pmid: 17436916].
30 Samartzis D, Shen FH, Goldberg EJ, et al. Is autograft the gold standard in achieving radiographic fusion on one-level anterior cervical discectomy and fusion with rigid anterior plate fixation?. Spine. 2005;30(15):1756-1761. [pmid: 16094278].
31 Suchomel P, Barsa P, Buchvald P, et al. Autologous versus allogeneic bone grafts in instrumented anterior cervical discectomy and fusion: a prospective study with respect to bone union pattern. Eur Spine J. 2004;13(6):510-515. [pmid: 15042453].
32 Jones AL, Bucholz RW, Bosse MJ, et al. Recombinant human BMP-2 and allograft compared with autogenous bone graft for reconstruction of diaphyseal tibial fractures with cortical defects. A randomized, controlled trial. J Bone Joint Surg Am. 2006;88:1431-1441. [pmid: 16818967].
33 Heary RF, Schlenk RP, Sacchieri TA, et al. Persistent iliac crest donor site pain: independent outcome assessment. Neurosurgery. 2002;50:510-516. [pmid: 11841718].
34 Ahlmann E, Patzakis M, Roidis N, et al. Comparison of anterior and posterior iliac crest bone grafts in terms of harvest-site morbidity and functional outcomes. J Bone Joint Surg Am. 2002;84-A:716-720. [pmid: 12004011].
35 Banwart JC, Asher MA, Hassanein RS. Iliac crest bone graft harvest donor site morbidity. A statistical evaluation. Spine. 1995;20:1055-1060. [pmid: 7631235].
36 Canady J, Zeitler DP, Thompson SA, et al. Suitability of the iliac crest as a site for harvest of autogenous bone grafts. Cleft Palate Craniofac J. 1993;30:579-581. [pmid: 8280737].
37 Cockin J. Autologous bone grafting: complications at the donor site. J Bone Joint Surg. 1971;53:153.
38 Keller EE, Triplett WW. Iliac bone grafting: review of 160 consecutive cases. J Oral Maxillofac Surg. 1987;45:11-14. [pmid: 3540237].
39 Sawin PD, Traynelis VC, Menezes AH. A comparative analysis of fusion rates and donor-site morbidity for autogeneic rib and iliac crest bone grafts in posterior cervical fusions. J Neurosurg. 1998;88:255-265. [pmid: 9452233].
40 Summers B, Eisenstein SM. Donor site pain from the ilium. A complication of lumbar spine fusion. J Bone Joint Surg Br. 1989;71:677-680. [pmid: 2768321].
41 Younger EM, Chapman MW. Morbidity at bone graft donor sites. J Orthop Trauma. 1989;3:192-195. [pmid: 2809818].
42 Silber JS, Anderson DG, Daffner SD, et al. Donor site morbidity after anterior iliac crest bone harvest for single-level anterior cervical discectomy and fusion. Spine (Phila Pa 1976). 2003;28(2):134-139. [pmid: 12544929].
43 Boyce T, Edwards J, Scarborough N. Allograft bone. The influence of processing on safety and performance. Orthop Clin North Am. 1999;30:571-581. [pmid: 10471762].
44 Urist MR. Bone formation by autoinduction. Science. 1965;150:893-899. [pmid: 5319761].
45 Adachi T, Takanaga H, Kunimoto M, et al. Influence of LIF and BMP-2 on differentiation and development of glial cells in primary cultures of embryonic rat cerebral hemisphere. J Neurosci Res. 2005;79:608-615. [pmid: 15678513].
46 Hogan BL. Bone morphogenetic proteins: multifunctional regulators of vertebrate development. Genes Dev. 1996;10:1580-1594. [pmid: 8682290].
47 Zou H, Choe KM, Lu Y, et al. BMP signaling and vertebrate limb development. Cold Spring Harb Symp Quant Biol. 1997;62:269-272. [pmid: 9598360].
48 Massague J, Weis-Garcia F. Serine/threonine kinase receptors: mediators of transforming growth factor beta family signals. Cancer Surv. 1996;27:41-64. [pmid: 8909794].
49 Yamashita H, Ten Dijke P, Heldin CH, et al. Bone morphogenetic protein receptors. Bone. 1996;19:569-574. [pmid: 8968021].
50 Medtronic Sofamor Danek USA, Inc. INFUSE Bone Graft product information: Tibial. Memphis, TN. 2004. Last accessed February 2010. Available online at www.accessdata.fda.gov/cdrh_docs/pdf/P000054c.pdf.
51 Medtronic Sofamor Danek USA, Inc. INFUSE Bone Graft product information: Oral/Facial. Memphis, TN. 2006. Last accessed February 2010. Available online at www.accessdata.fda.gov/cdrh_docs/pdf5/P050053c.pdf.
52 Medtronic Sofamor Danek USA, Inc. INFUSE Bone Graft product information: Lumbar. Memphis, TN. 2002. Last accessed February 2010. Available online at www.accessdata.fda.gov/cdrh_docs/pdf/P000058c.pdf.
53 Medtronic Sofamor Danek USA Inc. INFUSE/MASTERGRAFT Posterolateral Revision Device product information. Memphis, TN. 2008. Last accessed February 2010. Available online at www.accessdata.fda.gov/cdrh_docs/pdf4/H040004c.pdf.
54 Stryker Biotech. OP-1 Implant® product information. Hopkinton, MA. 2009. Last accessed February 2010. Available online at www.stryker.com/stellent/groups/public/documents/web_prod/126737.pdf.
55 Stryker Biotech. OP-1 Putty® product information. Hopkinton, MA. 2009. Last accessed February 2010. Available online at www.stryker.com/stellent/groups/public/documents/web_prod/127024.pdf.
56 U.S. Food and Drug Administration. Orthopaedic and Rehabilitation Devices Panel Meeting - March 31, 2009. Last accessed February 2010. Available online at www.fda.gov/AdvisoryCommittees/CommitteesMeetingMaterials/MedicalDevices/MedicalDevicesAdvisoryCommittee/OrthopaedicandRehabilitationDevicesPanel/ucm129187.htm.
57 U.S. Food and Drug Administration. FDA Public Health Notification: Life-threatening Complications Associated with Recombinant Human Bone Morphogenetic Protein in Cervical Spine Fusion. 2008. Issued: July 1, http://www.fda.gov/MedicalDevices/Safety/AlertsandNotices/PublicHealthNotifications/UCM062000.
58 Alderson P, Green S, Higgins JPT, editors. Cochrane Reviewers’ Handbook 4.2.2 [updated March 2004]. Last accessed February 2010. Available online at www.cochrane.org/resources/handbook/hbook.htm.
59 Morshed S, Corrales L, Genant H, et al. Outcome assessment in clinical trials of fracture-healing. J Bone Joint Surg Am. suppl 1. 2008;90:62-67. [pmid: 18292359].
60 Institute for Work and Health. Disabilities of the Arm, Shoulder and Hand (DASH) outcome measure. Last accessed February 2010. Available online at www.dash.iwh.on.ca/index.htm.
61 Roland M, Fairbank J. The Roland-Morris Disability Questionnaire and the Oswestry Disability Questionnaire. Spine. 2000;25:3115-3124. [pmid: 11124727].
62 Meade T, Brown W, Mellows S, et al. Comparison of chiropractic and outpatient management of low back pain: a feasibility study. Report of a working group. J Epidemiol Community Health. 1986;40:12-17. [pmid: 2872260].
63 Vernon H, Mior S. The Neck Disability Index: a study of reliability and validity. J Manipulative Physiol Ther. 1991;14:409-415. [pmid: 1834753].
64 Santaguida PL, Raina P. McMaster Quality Assessment Scale of Harms (McHarm) for primary studies. 2005. Last accessed February 2010. Available online at: http://hiru.mcmaster.ca/epc/mcharm.pdf.
65 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0 [Draft posted Oct. 2007]. Last accessed February 2010. Rockville, MD. Available online at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf.
66 Drummond MF, O’Brien B, Stoddart GL, et al. Methods for the economic evaluation of health care programmes. 2nd ed. Oxford. Oxford University Press. 1997.
67 Harris RP, Helfand M, Woolf SH, et al. for the Third US Preventive Services Task Force. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
68 Brown P, Brunnhuber K, Chalkidou K, et al. How to formulate research recommendations. BMJ. 2006;333(7572):804-806. [pmid: 17038740].
69 Lohr KN, Helfand M, Owens DK, et al. Grading the strength of a body of evidence. J Clin Epidemiol. 2009. Jul. 10. [Epub ahead of print]. [pmid: 19595577].
70 Guyatt GH, Oxman AD, Vist GE, et al. for the GRADE Working Group. GRADE: an emerging consensus on rating quality of evidence and strength of recommendations. BMJ. 2008;336(7650):924-926. [pmid: 18436948].
71 Boden SD, Zdeblick TA, Sandhu HS, et al. The use of rhBMP-2 in interbody fusion cages. Definitive evidence of osteoinduction in humans: a preliminary report. Spine (Phila Pa 1976). 2000;25(3):376-381. [pmid: 10703113].
72 Burkus JK, Gornet MF, Dickman CA, et al. Anterior lumbar interbody fusion using rhBMP-2 with tapered interbody cages. J Spinal Disord Tech. 2002;15(5):337-349. [pmid: 12394656].
73 Dawson E, Bae HW, Burkus JK, et al. Recombinant human bone morphogenetic protein-2 on an absorbable collagen sponge with an osteoconductive bulking agent in posterolateral arthrodesis with instrumentation. A prospective randomized trial. J Bone Joint Surg Am. 2009;91(7):1604-1613. [pmid: 19571082].
74 Govender S, Csimma C, Genant HK, et al. Recombinant human bone morphogenetic protein-2 for treatment of open tibial fractures: a prospective, controlled, randomized study of four hundred and fifty patients. J Bone Joint Surg Am. 2002;84-A(12):2123-2134. [pmid: 12473698].
75 Boyne PJ, Lilly LC, Marx RE, et al. De novo bone induction by recombinant human bone morphogenetic protein-2 (rhBMP-2) in maxillary sinus floor augmentation. J Oral Maxillofac Surg. 2005;63(12):1693-1707. [pmid: 16297689].
76 Fiorellini JP, Howell TH, Cochran D, et al. Randomized study evaluating recombinant human bone morphogenetic protein-2 for extraction socket augmentation. J Periodontol. 2005;76(4):605-613. [pmid: 15857102].
77 Triplett RG, Nevins M, Marx RE, et al. Pivotal, randomized, parallel evaluation of recombinant human bone morphogenetic protein-2/absorbable collagen sponge and autogenous bone graft for maxillary sinus floor augmentation. J Oral Maxillofac Surg. 2009;67(9):1947-1960. [pmid: 19686934].
78 Calori GM, Tagliabue L, Gala L, et al. Application of rhBMP-7 and platelet-rich plasma in the treatment of long bone non-unions: a prospective randomised clinical study on 120 patients. Injury. 2008;39(12):1391-1402. [pmid: 19027898].
79 Friedlaender GE, Perry CR, Cole JD, et al. Osteogenic protein-1 (bone morphogenetic protein-7) in the treatment of tibial nonunions. J Bone Joint Surg Am. 2001;83-A(Suppl 1(Pt 2)):S151-S158. [pmid: 11314793].
80 Burkus JK, Dorchak JD, Sanders DL. Radiographic assessment of interbody fusion using recombinant human bone morphogenetic protein type 2. Spine (Phila Pa 1976). 2003;28(4):372-377. [pmid: 12590213].
81 Swiontkowski MF, Aro HT, Donell S, et al. Recombinant human bone morphogenetic protein-2 in open tibial fractures. A subgroup analysis of data combined from two prospective randomized studies. J Bone Joint Surg Am. 2006;88(6):1258-1265. [pmid: 16757759].
82 van den Bergh JP, ten Bruggenkate CM, Groeneveld HH, et al. Recombinant human bone morphogenetic protein-7 in maxillary sinus floor elevation surgery in 3 patients compared to autogenous bone grafts. A clinical pilot study. J Clin Periodontol. 2000;27(9):627-636. [pmid: 10983596].
83 Dahabreh Z, Calori GM, Kanakaris NK, et al. A cost analysis of treatment of tibial fracture nonunion by bone grafting or bone morphogenetic protein-7. Int Orthop. 2009;33(5):1407-1414. [pmid: 19052743].
84 Boden SD, Kang J, Sandhu H, et al. Use of recombinant human bone morphogenetic protein-2 to achieve posterolateral lumbar spine fusion in humans: a prospective, randomized clinical pilot trial: 2002 Volvo Award in clinical studies. Spine (Phila Pa 1976). 2002;27(23):2662-2673. [pmid: 12461392].
85 Burkus JK, Sandhu HS, Gornet MF, et al. Use of rhBMP-2 in combination with structural cortical allografts: clinical and radiographic outcomes in anterior lumbar spinal surgery. J Bone Joint Surg Am. 2005;87(6):1205-1212. [pmid: 15930528].
86 Dimar JR 2nd, Glassman SD, Burkus JK, et al. Clinical and radiographic analysis of an optimized rhBMP-2 formulation as an autograft replacement in posterolateral lumbar spine arthrodesis. J Bone Joint Surg Am. 2009;91(6):1377-1386. [pmid: 19487515].
87 Glassman SD, Carreon LY, Djurasovic M, et al. RhBMP-2 versus iliac crest bone graft for lumbar spine fusion: a randomized, controlled trial in patients over sixty years of age. Spine (Phila Pa 1976). 2008;33(26):2843-2849. [pmid: 19092613].
88 Haid RW Jr, Branch CL Jr, Alexander JT, et al. Posterior lumbar interbody fusion using recombinant human bone morphogenetic protein type 2 with cylindrical interbody cages. Spine J. 2004;4(5):527-538. [pmid: 15363423].
89 Baskin DS, Ryan P, Sonntag V, et al. A prospective, randomized, controlled cervical fusion study using recombinant human bone morphogenetic protein-2 with the CORNERSTONE-SR allograft ring and the ATLANTIS anterior cervical plate. Spine (Phila Pa 1976). 2003;28(12):1219-1224. [pmid: 12811263].
90 Jones AL, Bucholz RW, Bosse MJ, et al. Recombinant human BMP-2 and allograft compared with autogenous bone graft for reconstruction of diaphyseal tibial fractures with cortical defects. A randomized, controlled trial. J Bone Joint Surg Am. 2006;88(7):1431-1441. [pmid: 16818967].
91 Dickinson BP, Ashley RK, Wasson KL, et al. Reduced morbidity and improved healing with bone morphogenic protein-2 in older patients with alveolar cleft defects. Plast Reconstr Surg. 2008;121(1):209-217. [pmid: 18176223].
92 Johnsson R, Stromqvist B, Aspenberg P. Randomized radiostereometric study comparing osteogenic protein-1 (BMP-7) and autograft bone in human noninstrumented posterolateral lumbar fusion: 2002 Volvo Award in clinical studies. Spine (Phila Pa 1976). 2002;27(23):2654-2661. [pmid: 12461391].
93 Kanayama M, Hashimoto T, Shigenobu K, et al. A prospective randomized study of posterolateral lumbar fusion using osteogenic protein-1 (OP-1) versus local autograft with ceramic bone substitute: emphasis of surgical exploration and histologic assessment. Spine (Phila Pa 1976). 2006;31(10):1067-1074. [pmid: 16648739].
94 Vaccaro AR, Lawrence JP, Patel T, et al. The safety and efficacy of OP-1 (rhBMP-7) as a replacement for iliac crest autograft in posterolateral lumbar arthrodesis: a long-term (>4 years) pivotal study. Spine (Phila Pa 1976). 2008;33(26):2850-2862. [pmid: 19092614].
95 Vaccaro AR, Whang PG, Patel T, et al. The safety and efficacy of OP-1 (rhBMP-7) as a replacement for iliac crest autograft for posterolateral lumbar arthrodesis: minimum 4-year follow-up of a pilot study. Spine J. 2008;8(3):457-465. [pmid: 17588821].
96 Bilic R, Simic P, Jelic M, et al. Osteogenic protein-1 (BMP-7) accelerates healing of scaphoid non-union with proximal pole sclerosis. Int Orthop. 2006;30(2):128-134. [pmid: 16506027].
97 Ekrol I, Hajducka C, Court-Brown C, et al. A comparison of RhBMP-7 (OP-1) and autogenous graft for metaphyseal defects after osteotomy of the distal radius. Injury. Suppl 2. 2008;39:S73-S82. [pmid: 18804577].
98 Geesink RG, Hoefnagels NH, Bulstra SK. Osteogenic activity of OP-1 bone morphogenetic protein (BMP-7) in a human fibular defect. J Bone Joint Surg Br. 1999;81(4):710-718. [pmid: 10463751].
99 Glassman SD, Carreon L, Djurasovic M, et al. Posterolateral lumbar spine fusion with INFUSE bone graft. Spine J. 2007;7(1):44-49. [pmid: 17197332].
100 Mummaneni PV, Pan J, Haid RW, et al. Contribution of recombinant human bone morphogenetic protein-2 to the rapid creation of interbody fusion when used in transforaminal lumbar interbody fusion: a preliminary report. Invited submission from the Joint Section Meeting on Disorders of the Spine and Peripheral Nerves, March 2004. J Neurosurg Spine. 2004;1(1):19-23. [pmid: 15291015].
101 Pradhan BB, Bae HW, Dawson EG, et al. Graft resorption with the use of bone morphogenetic protein: lessons from anterior lumbar interbody fusion using femoral ring allografts and recombinant human bone morphogenetic protein-2. Spine (Phila Pa 1976). 2006;31(10):E277-E284. [pmid: 16648733].
102 Singh K, Smucker JD, Gill S, et al. Use of recombinant human bone morphogenetic protein-2 as an adjunct in posterolateral lumbar spine fusion: a prospective CT-scan analysis at one and two years. J Spinal Disord Tech. 2006;19(6):416-423. [pmid: 16891977].
103 Slosar PJ, Josey R, Reynolds J. Accelerating lumbar fusions by combining rhBMP-2 with allograft bone: a prospective analysis of interbody fusion rates and clinical outcomes. Spine J. 2007;7(3):301-307. [pmid: 17482113].
104 Buttermann GR. Prospective nonrandomized comparison of an allograft with bone morphogenic protein versus an iliac-crest autograft in anterior cervical discectomy and fusion. Spine J. 2008;8(3):426-435. [pmid: 17977799].
105 Crawford CH 3rd, Carreon LY, et al. Perioperative complications of recombinant human bone morphogenetic protein-2 on an absorbable collagen sponge versus iliac crest bone graft for posterior cervical arthrodesis. Spine (Phila Pa 1976). 2009;34(13):1390-1394. [pmid: 19440166].
106 Smucker JD, Rhee JM, Singh K, et al. Increased swelling complications associated with off-label usage of rhBMP-2 in the anterior cervical spine. Spine (Phila Pa 1976). 2006;31(24):2813-2819. [pmid: 17108835].
107 Vaidya R, Carp J, Sethi A, et al. Complications of anterior cervical discectomy and fusion using recombinant human bone morphogenetic protein-2. Eur Spine J. 2007;16(8):1257-1265. [pmid: 17387522].
108 Boraiah S, Paul O, Hawkes D, et al. Complications of recombinant human BMP-2 for treating complex tibial plateau fractures: A preliminary report. Clin Orthop Relat Res. 2009;467(12):3257-3262. [pmid: 19693635].
109 Maeda T, Buchowski JM, Kim YJ, et al. Long adult spinal deformity fusion to the sacrum using rhBMP-2 versus autogenous iliac crest bone graft. Spine (Phila Pa 1976). 2009;34(20):2205-2212. [pmid: 19752707].
110 Ristiniemi J, Flinkkila T, Hyvonen P, et al. RhBMP-7 accelerates the healing in distal tibial fractures treated by external fixation. J Bone Joint Surg Br. 2007;89(2):265-272. [pmid: 17322450].
111 Karrholm J, Hourigan P, Timperley J, et al. Mixing bone graft with OP-1 does not improve cup or stem fixation in revision surgery of the hip: 5-year follow-up of 10 acetabular and 11 femoral study cases and 40 control cases. Acta Orthop. 2006;77(1):39-48. [pmid: 16534701].
112 Madrazo I, Zamorano C, Magallon E, et al. Recombinant human bone morphogenetic protein-2 (rhBMP-2) for cervical fusion: Is there a role in cervical trauma?. Top. Spinal Cord Inj. Rehabil. 2006;12(2):30-39.
113 Lanman TH, Hopkins TJ. Early findings in a pilot study of anterior cervical interbody fusion in which recombinant human bone morphogenetic protein-2 was used with poly(L-lactide-co-D,L-lactide) bioabsorbable implants. Neurosurg Focus. 2004;16(3):E6. [pmid: 15198494].
114 Boakye M, Mummaneni PV, Garrett M, et al. Anterior cervical discectomy and fusion involving a polyetheretherketone spacer and bone morphogenetic protein. J Neurosurg Spine. 2005;2(5):521-525. [pmid: 15945426].
115 Shields LB, Raque GH, Glassman SD, et al. Adverse effects associated with high-dose recombinant human bone morphogenetic protein-2 use in anterior cervical spine fusion. Spine (Phila Pa 1976). 2006;31(5):542-547. [pmid: 16508549].
116 Aryan HE, Lu DC, Acosta FL Jr, et al. Corpectomy followed by the placement of instrumentation with titanium cages and recombinant human bone morphogenetic protein-2 for vertebral osteomyelitis. J Neurosurg Spine. 2007;6(1):23-30. [pmid: 17233287].
117 Lu DC, Sun PP. Bone morphogenetic protein for salvage fusion in an infant with Down syndrome and craniovertebral instability. Case report. J Neurosurg. 2007;106(6 Suppl):480-483. [pmid: 17566406].
118 Allen RT, Lee YP, Stimson E, et al. Bone morphogenetic protein-2 (BMP-2) in the treatment of pyogenic vertebral osteomyelitis. Spine (Phila Pa 1976). 2007;32(26):2996-3006. [pmid: 18091493].
119 Tumialan LM, Pan J, Rodts GE, et al. The safety and efficacy of anterior cervical discectomy and fusion with polyetheretherketone spacer and recombinant human bone morphogenetic protein-2: a review of 200 patients. J Neurosurg Spine. 2008;8(6):529-535. [pmid: 18518673].
120 Vaidya R, Sethi A, Bartol S, et al. Complications in the use of rhBMP-2 in PEEK cages for interbody spinal fusions. J Spinal Disord Tech. 2008;21(8):557-562. [pmid: 19057248].
121 Hiremath GK, Steinmetz MP, Krishnaney AA. Is it safe to use recombinant human bone morphogenetic protein in posterior cervical fusion?. Spine (Phila Pa 1976). 2009;34(9):885-889. [pmid: 19531997].
122 Klimo P Jr, Peelle MW. Use of polyetheretherketone spacer and recombinant human bone morphogenetic protein-2 in the cervical spine: a radiographic analysis. Spine J. 2009;9(12):959-966. [pmid: 19574105].
123 Govender PV, Rampersaud YR, Rickards L, et al. Use of osteogenic protein-1 in spinal fusion: literature review and preliminary results in a prospective series of high-risk cases. Neurosurg Focus. 2002;13(6):e4. [pmid: 15766230].
124 Furlan JC, Perrin RG, Govender PV, et al. Use of osteogenic protein-1 in patients at high risk for spinal pseudarthrosis: a prospective cohort study assessing safety, health-related quality of life, and radiographic fusion. Invited submission from the Joint Section on Disorders of the Spine and Peripheral Nerves, March 2007. J Neurosurg Spine. 2007;7(5):486-495. [pmid: 17977189].
125 Perri B, Cooper M, Lauryssen C, et al. Adverse swelling associated with use of rh-BMP-2 in anterior cervical discectomy and fusion: a case study. Spine J. 2007;7(2):235-239. [pmid: 17321975].
126 Oluigbo CO, Solanki GA. Use of recombinant human bone morphogenetic protein-2 to enhance posterior cervical spine fusion at 2 years of age: technical note. Pediatr Neurosurg. 2008;44(5):393-396. [pmid: 18703886].
127 Lanman TH, Hopkins TJ. Lumbar interbody fusion after treatment with recombinant human bone morphogenetic protein-2 added to poly(L-lactide-co-D,L-lactide) bioresorbable implants. Neurosurg Focus. 2004;16(3):E9. [pmid: 15198497].
128 Kuklo TR, Rosner MK, Polly DW Jr. Computerized tomography evaluation of a resorbable implant after transforaminal lumbar interbody fusion. Neurosurg Focus. 2004;16(3):E10. [pmid: 15198498].
129 Villavicencio AT, Burneikiene S, Nelson EL, et al. Safety of transforaminal lumbar interbody fusion and intervertebral recombinant human bone morphogenetic protein-2. J Neurosurg Spine. 2005;3(6):436-443. [pmid: 16381205].
130 McClellan JW, Mulconrey DS, Forbes RJ, et al. Vertebral bone resorption after transforaminal lumbar interbody fusion with bone morphogenetic protein (rhBMP-2). J Spinal Disord Tech. 2006;19(7):483-486. [pmid: 17021411].
131 Lewandrowski KU, Nanson C, Calderon R. Vertebral osteolysis after posterior interbody lumbar fusion with recombinant human bone morphogenetic protein 2: a report of five cases. Spine J. 2007;7(5):609-614. [pmid: 17526434].
132 Wong DA, Kumar A, Jatana S, et al. Neurologic impairment from ectopic bone in the lumbar canal: a potential complication of off-label PLIF/TLIF use of bone morphogenetic protein-2 (BMP-2). Spine J. 2008;8(6):1011-1018. [pmid: 18037352].
133 Hamilton DK, Jones-Quaidoo SM, Sansur C, et al. Outcomes of bone morphogenetic protein-2 in mature adults: posterolateral non-instrument-assisted lumbar decompression and fusion. Surg Neurol. 2008;69(5):457-461. [pmid: 18207557].
134 Joseph V, Rampersaud YR. Heterotopic bone formation with the use of rhBMP2 in posterior minimal access interbody fusion: a CT analysis. Spine (Phila Pa 1976). 2007;32(25):2885-2890. [pmid: 18246013].
135 Katayama Y, Matsuyama Y, Yoshihara H, et al. Clinical and radiographic outcomes of posterolateral lumbar spine fusion in humans using recombinant human bone morphogenetic protein-2: an average five-year follow-up study. Int Orthop. 2009;33(4):1061-1067. [pmid: 18581064].
136 Aryan HE, Newman CB, Gold JJ, et al. Percutaneous axial lumbar interbody fusion (AxiaLIF) of the L5-S1 segment: initial clinical and radiographic experience. Minim Invasive Neurosurg. 2008;51(4):225-230. [pmid: 18683115].
137 Anand N, Baron EM, Thaiyananthan G, et al. Minimally invasive multilevel percutaneous correction and fusion for adult lumbar degenerative scoliosis: a technique and feasibility study. J Spinal Disord Tech. 2008;21(7):459-467. [pmid: 18836355].
138 Meisel HJ, Schnoring M, Hohaus C, et al. Posterior lumbar interbody fusion using rhBMP-2. Eur Spine J. 2008;17(12):1735-1744. [pmid: 18839225].
139 Rihn JA, Patel R, Makda J, et al. Complications associated with single-level transforaminal lumbar interbody fusion. Spine J. 2009;9(8):623-629. [pmid: 19482519].
140 Acosta FL, Cloyd JM, Aryan HE, et al. Patient satisfaction and radiographic outcomes after lumbar spinal fusion without iliac crest bone graft or transverse process fusion. J Clin Neurosci. 2009;16(9):1184-1187. [pmid: 19500992].
141 Geibel PT, Boyd DL, Slabisak V. The use of recombinant human bone morphogenic protein in posterior interbody fusions of the lumbar spine: a clinical series. J Spinal Disord Tech. 2009;22(5):315-320. [pmid: 19525785].
142 Mindea SA, Shih P, Song JK. Recombinant human bone morphogenetic protein-2-induced radiculitis in elective minimally invasive transforaminal lumbar interbody fusions: a series review. Spine (Phila Pa 1976). 2009;34(14):1480-1484. [pmid: 19525840].
143 Vaccaro AR, Patel T, Fischgrund J, et al. A pilot safety and efficacy study of OP-1 putty (rhBMP-7) as an adjunct to iliac crest autograft in posterolateral lumbar fusions. Eur Spine J. 2003;12(5):495-500. [pmid: 12908103].
144 Vaccaro AR, Patel T, Fischgrund J, et al. A 2-year follow-up pilot study evaluating the safety and efficacy of op-1 putty (rhbmp-7) as an adjunct to iliac crest autograft in posterolateral lumbar fusions. Eur Spine J. 2005;14(7):623-629. [pmid: 15672240].
145 Hansen SM, Sasso RC. Resorptive response of rhBMP2 simulating infection in an anterior lumbar interbody fusion with a femoral ring. J Spinal Disord Tech. 2006;19(2):130-134. [pmid: 16760788].
146 Anand N, Hamilton JF, Perri B, et al. Cantilever TLIF with structural allograft and RhBMP2 for correction and maintenance of segmental sagittal lordosis: long-term clinical, radiographic, and functional outcome. Spine (Phila Pa 1976). 2006;31(20):E748-E753. [pmid: 16985443].
147 Moshel YA, Hernandez EI, Kong L, et al. Acute renal insufficiency, supraventricular tachycardia, and confusion after recombinant human bone morphogenetic protein-2 implantation for lumbosacral spine fusion. J Neurosurg Spine. 2008;8(6):589-593. [pmid: 18518683].
148 Brower RS, Vickroy NM. A case of psoas ossification from the use of BMP-2 for posterolateral fusion at L4-L5. Spine (Phila Pa 1976). 2008;33(18):E653-E655. [pmid: 18708918].
149 Whang PG, O'Hara BJ, Ratliff J, et al. Pseudarthrosis following lumbar interbody fusion using bone morphogenetic protein-2: intraoperative and histopathologic findings. Orthopedics. 2008;31(10):1031. [pmid: 19226004].
150 Dickerman RD, Reynolds AS, Bennett M, Brower RS, Vickrov NM. A case of psoas ossification from the use of BMP-2 for posterolateral fusion at L4-L5. Spine. 2008;33:E653-E655. Spine (Phila Pa 1976) 2009; 34(7):749. [pmid: 18708918].
151 Bennett M, Reynolds AS, Dickerman RD. Recent article by Shields et al titled "adverse effects associated with high-dose recombinant human bone morphogenetic protein-2 use in anterior cervical spine fusion". Spine (Phila Pa 1976). 2006;31(17):2029-2030. [pmid: 16924224].
152 Bong MR, Capla EL, Egol KA, et al. Osteogenic protein-1 (bone morphogenic protein-7) combined with various adjuncts in the treatment of humeral diaphyseal nonunions. Bull Hosp Jt Dis. 2005;63(1–2):20-23. [pmid: 16536213].
153 Axelrad TW, Steen B, Lowenberg DW, et al. Heterotopic ossification after the use of commercially available recombinant human bone morphogenetic proteins in four patients. J Bone Joint Surg Br. 2008;90(12):1617-1622. [pmid: 19043134].
154 Schwartz ND, Hicks BM. Eight-centimeter segmental ulnar defect treated with recombinant human bone morphogenetic protein-2. Am J Orthop. 2008;37(11):569-571. [pmid: 19104684].
155 Wysocki RW, Cohen MS. Ectopic ossification of the triceps muscle after application of bone morphogenetic protein-7 to the distal humerus for recalcitrant nonunion: a case report. J Hand Surg Am. 2007;32(5):647-650. [pmid: 17482003].
156 Delloye C, Suratwala SJ, Cornu O, et al. Treatment of allograft nonunions with recombinant human bone morphogenetic proteins (rhBMP). Acta Orthop Belg. 2004;70(6):591-597. [pmid: 15669462].
157 Alt V, Meyer C, Litzlbauer HD, et al. Treatment of a double nonunion of the femur by rhBMP-2. J Orthop Trauma. 2007;21(10):734-737. [pmid: 17986892].
158 D'Agostino P, Stassen P, Delloye C. Post-traumatic bone loss of the femur treated with segmental bone allograft and bone morphogenetic protein: a case report. Acta Orthop Belg. 2007;73(3):396-399. [pmid: 17715734].
159 Lee FY, Sinicropi SM, Lee FS, et al. Treatment of congenital pseudarthrosis of the tibia with recombinant human bone morphogenetic protein-7 (rhBMP-7). A report of five cases. J Bone Joint Surg Am. 2006;88(3):627-633. [pmid: 16510831].
160 Lee FY, Sinicropi SM, Lee FS, et al. Treatment of congenital pseudarthrosis of the tibia with recombinant human bone morphogenetic protein-7 (rhBMP-7). A report of five cases. J Bone Joint Surg Am. 2006;88(3):627-633. [pmid: 16510831].
161 Anticevic D, Jelic M, Vukicevic S. Treatment of a congenital pseudarthrosis of the tibia by osteogenic protein-1 (bone morphogenetic protein-7): a case report. J Pediatr Orthop B. 2006;15(3):220-221. [pmid: 16601593].
162 Bibbo C, Haskell MD. Recombinant bone morphogenetic protein-2 (rhBMP-2) in high-risk foot and ankle surgery: Surgical techniques and preliminary results of a prospective, intention-to-treat study. Tech. Foot Ankle Surg. 2007;6(2):71-79.
163 Bibbo C, Patel DV, Haskell MD. Recombinant bone morphogenetic protein-2 (rhBMP-2) in high-risk ankle and hindfoot fusions. Foot Ankle Int. 2009;30(7):597-603. [pmid: 19589304].
164 Schuberth JM, DiDomenico LA, Mendicino RW. The utility and effectiveness of bone morphogenetic protein in foot and ankle surgery. J Foot Ankle Surg. 2009;48(3):309-314. [pmid: 19423030].
165 White G, Blundell CM. Case study: Use of osteogenic protein-1 (BMP-7) in non-union of a calcaneus fracture following ORIF. Foot Ankle Surg. 2007;13(4):203-206.
166 Chin M, Ng T, Tom WK, et al. Repair of alveolar clefts with recombinant human bone morphogenetic protein (rhBMP-2) in patients with clefts. J Craniofac Surg. 2005;16(5):778-789. [pmid: 16192856].
167 Carstens MH, Chin M, Ng T, et al. Reconstruction of #7 facial cleft with distraction-assisted in situ osteogenesis (DISO): role of recombinant human bone morphogenetic protein-2 with Helistat-activated collagen implant. J Craniofac Surg. 2005;16(6):1023-1032. [pmid: 16327550].
168 Herford AS, Boyne PJ, Williams RP. Clinical applications of rhBMP-2 in maxillofacial surgery. J Calif Dent Assoc. 2007;35(5):335-341. [pmid: 17822159].
169 Herford AS, Boyne PJ, Rawson R, et al. Bone morphogenetic protein-induced repair of the premaxillary cleft. J Oral Maxillofac Surg. 2007;65(11):2136-2141. [pmid: 17954305].
170 Clokie CM, Sandor GK. Reconstruction of 10 major mandibular defects using bioimplants containing BMP-7. J Can Dent Assoc. 2008;74(1):67-72. [pmid: 18298888].
171 Herford AS, Boyne PJ. Reconstruction of mandibular continuity defects with bone morphogenetic protein-2 (rhBMP-2). J Oral Maxillofac Surg. 2008;66(4):616-624. [pmid: 18355584].
172 Carter TG, Brar PS, Tolas A, et al. Off-label use of recombinant human bone morphogenetic protein-2 (rhBMP-2) for reconstruction of mandibular bone defects in humans. J Oral Maxillofac Surg. 2008;66(7):1417-1425. [pmid: 18571026].
173 Tom WK, Chin M, Ng T, et al. Distraction of rhBMP-2-generated mandible: how stable is the engineered bone in response to subsequent surgeries?. J Oral Maxillofac Surg. 2008;66(7):1499-1505. [pmid: 18571039].
174 Schuckert KH, Jopp S, Teoh SH. Mandibular defect reconstruction using three-dimensional polycaprolactone scaffold in combination with platelet-rich plasma and recombinant human bone morphogenetic protein-2: de novo synthesis of bone in a single case. Tissue Eng Part A. 2009;15(3):493-499. [pmid: 18767969].
175 Carreon LY, Glassman SD, Brock DC, et al. Adverse events in patients re-exposed to bone morphogenetic protein for spine surgery. Spine (Phila Pa 1976). 2008;33(4):391-393. [pmid: 18277870].
176 O'Shaughnessy BA, Kuklo TR, Ondra SL. Surgical treatment of vertebral osteomyelitis with recombinant human bone morphogenetic protein-2. Spine (Phila Pa 1976). 2008;33(5):E132-E139. [pmid: 18317180].
177 Mulconrey DS, Bridwell KH, Flynn J, et al. Bone morphogenetic protein (RhBMP-2) as a substitute for iliac crest bone graft in multilevel adult spinal deformity surgery: minimum two-year evaluation of fusion. Spine (Phila Pa 1976). 2008;33(20):2153-2159. [pmid: 18725869].
178 Giannoudis PV, Psarakis S, Kanakaris NK, et al. Biological enhancement of bone healing with bone morphogenetic protein-7 at the clinical setting of pelvic girdle non-unions. Injury. Suppl 4. 2007;38:S43-S48. [pmid: 18224736].
179 Seyler TM, Marker DR, Ulrich SD, et al. Nonvascularized bone grafting defers joint arthroplasty in hip osteonecrosis. Clin Orthop Relat Res. 2008;466(5):1125-1132. [pmid: 18351424].
180 Morgan A. Treatment of chronic nonunion of a sternal fracture with bone morphogenetic protein. Ann Thorac Surg. 2008;85(2):e12-e13. [pmid: 18222222].
181 Shah MM, Smyth MD, Woo AS. Adverse facial edema associated with off-label use of recombinant human bone morphogenetic protein-2 in cranial reconstruction for craniosynostosis. Case report. J Neurosurg Pediatr. 2008;1(3):255-257. [pmid: 18352773].
182 Burkus JK, Heim SE, Gornet MF, et al. Is INFUSE bone graft superior to autograft bone? An integrated analysis of clinical trials using the LT-CAGE lumbar tapered fusion device. J Spinal Disord Tech. 2003;16(2):113-122. [pmid: 12679664].
183 Kleeman TJ, Ahn UM, Talbot-Kleeman A. Laparoscopic anterior lumbar interbody fusion with rhBMP-2: a prospective study of clinical and radiographic outcomes. Spine (Phila Pa 1976). 2001;26(24):2751-2756. [pmid: 11740368].
184 Vaccaro AR, Patel T, Fischgrund J, et al. A pilot study evaluating the safety and efficacy of OP-1 Putty (rhBMP-7) as a replacement for iliac crest autograft in posterolateral lumbar arthrodesis for degenerative spondylolisthesis. Spine (Phila Pa 1976). 2004;29(17):1885-1892. [pmid: 15534410].
185 Vaccaro AR, Anderson DG, Patel T, et al. Comparison of OP-1 Putty (rhBMP-7) to iliac crest autograft for posterolateral lumbar arthrodesis: a minimum 2-year follow-up pilot study. Spine (Phila Pa 1976). 2005;30(24):2709-2716. [pmid: 16371892].
186 Rihn JA, Makda J, Hong J, et al. The use of RhBMP-2 in single-level transforaminal lumbar interbody fusion: a clinical and radiographic analysis. Eur Spine J. 2009.
187 Carreon LY, Glassman SD, Djurasovic M, et al. RhBMP2 versus iliac crest bone graft for lumbar spine fusion in patients over 60 years of age: a cost-utility study. Spine (Phila Pa 1976). 2009;34(3):238-243. [pmid: 19179918].
188 Sprague S, Bhandari M. An economic evaluation of early versus delayed operative treatment in patients with closed tibial shaft fractures. Arch Orthop Trauma Surg. 2002;122:315-323. [pmid: 12136294].
189 Brazier J, Usherwood T, Harper R, et al. Deriving a preference based single index from the UK SF-36 health survey. J Clin Epidemiol. 1998;51:1115-1128. [pmid: 9817129].
190 Polly DW Jr, Ackerman SJ, Shaffrey CI, et al. A cost analysis of bone morphogenetic protein versus autogenous iliac crest bone graft in single-level anterior lumbar fusion. Orthopedics. 2003;26(10):1027-1037. [pmid: 14577525].
191 Glassman SD, Carreon LY, Campbell MJ, et al. The perioperative cost of Infuse bone graft in posterolateral lumbar spine fusion. Spine J. 2008;8(3):443-448. [pmid: 17526436].