# Methods

The objective of this technology assessment report is to conduct a systematic review of the clinical effectiveness of unilateral and bilateral cochlear implants in adult patients with sensorineural hearing loss. The methods for this technology assessment largely follow those outlined in the AHRQ Methods Guide for Comparative Effectiveness Reviews, available at: http://effectivehealthcare.ahrq.gov/healthInfo.cfm?infotype=rr&ProcessID=60.

## Technical Experts

The Tufts-EPC collaborated with a physician with expertise in adult cochlear implantation from the Department of Otology and Laryngology, Harvard Medical School, who provided input to the Tufts EPC project team regarding the population, clinical conditions, and the interventions of interest with respect to the key questions of interest, and participated in the review and revisions of the report. An audiologist from the audiology program at the Children’s Hospital, Boston conducted an educational seminar on cochlear implantation and speech perception outcomes, but did not participate in conducting the review or in preparation or approval of the report.

## Search Strategy

A comprehensive search of the scientific literature was conducted to identify relevant studies addressing the key questions. For Key Question 1, we searched the FDA database, Devices@FDA, the database of cleared and approved devices, for the term cochlear. We also searched for the term MCM (the specific product code for “implant, cochlear”) in the Premarket Approvals database of the FDA. In ClinicalTrials.gov, we searched the term cochlear. For Key Questions 2 and 3, we searched MEDLINE®, the Cochrane Central Register of Controlled Trials, and Scopus (which includes articles indexed in Embase since 1997) from January 2004 through February 2011 for published studies of adult human subjects to identify articles relevant to each key question. We also reviewed reference lists of related systematic reviews and selected narrative reviews, and primary articles. In electronic searches, we combined terms for unilateral and bilateral cochlear implantation and sensorineural hearing loss, and limited search terms to adult humans (see Appendix A for complete search strategy). We invited technical consultants and peer and public reviewers to provide additional citations. We did not use any language restriction.

## Study Selection

We assessed titles and/or abstracts of citations identified from literature searches for inclusion, using the criteria described below. Full-text articles of potentially relevant abstracts were retrieved, and a second review for inclusion was conducted by reapplying the inclusion criteria.

### Population and Condition of Interest

We focused on studies of patients with sensorineural hearing loss, and exclusively on studies of adults (≥ 18 years) with cochlear implantation for sensorineural hearing loss. Studies that included subjects with a cochlear implant ≥ 60 years were considered generalizable to the subset of Medicare population. We thus excluded studies of conductive deafness, studies evaluating children-only populations or studies with data not separately available for children and adults, and reviews without primary data.

### Interventions of Interest

The primary interventions of interest were both unilateral and bilateral cochlear implantation. Eligible cochlear implantation included one or two multichannel cochlear implants using whole-speech processing coding strategies. We included both sequential and simultaneous bilateral cochlear implantation. Also included were studies with patients who used both cochlear implants and hearing aids. We limited data to recent cochlear implant devices that use whole-speech processing strategies by restricting our searches to studies published since 2004. We excluded studies of brain stem implants, middle ear implants, and bone-anchored hearing aids used for conductive and mixed hearing loss.

### Comparators of Interest

We considered the following comparisons of interest: unilateral cochlear implantation compared with hearing aids in one ear or both ears, and bilateral cochlear implantation. We also included studies that compared preoperative and postoperative cochlear implantation for clinical outcomes of interest. Bilateral cochlear implantation was compared with unilateral cochlear implantation with or without hearing aids from an external cohort, and with either ear implant unilaterally (i.e., cross-over design within subjects).

### Outcomes of Interest

Outcomes of interest involved speech perception outcomes (open-set sentences, two syllable or multi-syllable words) and health-related quality-of-life. A speech perception test is considered to be “open-set” if the listener is required to recognize words or sentences without the presence of response alternatives (a free recall response). Listeners must identify what they heard by repeating or writing down the words or sentences. Two-syllable or multi-syllable words are words that may or may not have equal emphasis on all syllables (see Appendix A1 for term definitions). Health-related quality-of-life outcomes included generic or hearing-specific quality-of-life measures (see Appendix A2 for term definitions). For bilateral cochlear implantation, sound localization and derived measures of binaural processing capabilities such as, head shadow, squelch, and summation were also assessed (see Appendix A3 for term definitions). We included data on device non-use and hearing loss after cochlear implantation. We excluded studies with music tests as the only outcomes and studies of surgical or implant techniques without data on outcomes of interest. Studies with available evidence were evaluated separately for those individuals with sensorineural hearing loss as demonstrated by preimplantation test scores between 40 and 50 percent, as well as those with test scores between 50 and 60 percent (best aided listening on tape or otherwise recorded tests of open-set sentence recognition).

### Study designs and sample size

We included studies of any design to address Key Questions 2 and 3. For Key Question 2, we included studies with at least 30 subjects with cochlear implants. Sample size thresholds were chosen based primarily on practical consideration of available resources and time balanced with the likely amount of available literature. For Key Question 3, we included studies with at least 10 subjects with cochlear implants per study. This cut-off was based on a small number of studies evaluating bilateral cochlear implantation.

### Predictors of Interest

The predictors of interest were defined a priori during key question development, and included: speech recognition/word understanding, auditory sensitivity/audibility, duration of impaired hearing, associated ear or bone disease, pre versus postlinguistic deafness, presence of other disabilities (e.g. visual impairment, impending or current), age (i.e., age at implantation, or older vs. younger age at baseline), degree of preimplant residual hearing, choice of implanted ear, site or center (expertise) of cochlear implant team, and implanted device.

## Data Extraction

For study characteristics, we extracted the following items: the first author’s name, year, PubMed ID, study design, country/setting, recruitment dates, funding source, inclusion and exclusion criteria, interventions, comparators, concurrent treatment, outcome assessor, and duration of followup. For population characteristics, the items extracted were: the number of patients enrolled and completed, age, percentage of male patients, degree and duration of deafness, device coding strategy, and time between deafness and cochlear implantation.

We also extracted the following preoperative patient characteristics that might be associated with communication-related health outcomes as well as health-related quality-of-life: speech recognition/word understanding, duration of impaired hearing, associated ear or bone disease, pre versus postlinguistic deafness, other disabilities (e.g., visual impairment, impending or current), age, degree of preimplant residual hearing, choice of implanted ear, site or center (expertise) of cochlear implant team, and implanted device (see Appendix B for the data extraction forms).

For outcomes, we categorized them into speech test, two syllable/multi-syllable test, health-related quality-of-life measures, and communication-related adverse events. We briefly described each outcome measure and summarized the relevant data from the primary studies. We conducted a systematic review without performing any meta-analysis due to heterogeneity in methodologies including duration of deafness, implanted devices, speech coding strategies, and outcome tests. In summary tables, we indicated the direction of outcomes using dark up arrows (benefit with statistical significance), white up arrows (benefit but no statistical significance), dark down arrows (worse and statistical significance), white down arrows (worse but no statistical significance), and white side arrows (no difference between comparison groups).

## Quality Assessment

We employed a three-grade classification (A, B, or C) using the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews (available at: http://effectivehealthcare.ahrq.gov/healthInfo.cfm?infotype=rr&ProcessID=60). We used a quality assessment method that produces a generic grading scale that is applicable to various study designs including randomized controlled trials and cohort studies. We specifically noted study characteristics, such as study design (i.e., prospective, case control, retrospective, and cross-sectional), selection bias, recall bias, the appropriate selection of a representative population sample, attrition bias, and identification for the potential confounders.

“A” quality studies. Quality-A studies are considered good quality studies, which have the least bias and their conclusions are considered valid. Good quality studies generally meet the following criteria: clear description of eligibility criteria, unbiased selection of subjects, drop-rates less than 20 percent, assessment of blinding, adjustments for confounding factors and the use of random sampling.

“B” quality studies. Quality-B studies are considered fair or moderate quality studies that are susceptible to some bias, but it is not sufficient to invalidate the results. Quality-B studies do not meet all the criteria listed for Quality-A studies nor provide complete information. However, none of them introduce a significant bias.

“C” quality studies. Quality-C studies are considered poor quality studies that have significant flaws that imply biases of various types that may invalidate the study results. These studies introduce major errors in methods, analysis or discrepancies in reporting results.

## Grading a Body of Evidence

We graded the strength of the body of evidence for each analysis within each key question as per the AHRQ methods guide, with modifications as described below. Risk of bias was defined as low, medium, or high based on the study design and methodological quality. We assessed the consistency of the data as either “no inconsistency” or “inconsistency present” (or “not applicable” if only one study). The direction, magnitude, and statistical significance of all studies were evaluated in assessing consistency, and logical explanations were provided in the presence of equivocal results. We also assessed the relevance of evidence and the precision of the evidence based on the degree of certainty surrounding an effect estimate. A precise estimate was considered an estimate that would allow a clinically useful conclusion. An imprecise estimate was one for which the confidence interval was wide enough to preclude a conclusion.

Based on individual studies rated quality-A or -B, we rated the strength of evidence with one of the following four strengths (as per the AHRQ methods guide): High, Moderate, Low, and Insufficient. Ratings were assigned based on our level of confidence that the evidence reflected the true effect for the major comparisons of interest. Ratings were defined as follows:

High. There is a high level of assurance that the findings of the literature are valid with respect to the relevant comparison. No important scientific disagreement exists across studies. At least two quality-A studies are required for this rating. In addition, there must be evidence regarding important clinical outcomes. Further research is very unlikely to change our confidence in the estimate of effect.

Moderate. There is a moderate level of assurance that the findings of the literature are valid with respect to the relevant comparison. Little disagreement exists across studies. Moderately-rated bodies of evidence contain fewer than two quality-A or-B studies or such studies lack long-term outcomes of relevant populations. Further research may change our confidence in the estimates of effect and may change the estimate.

Low. There is a low level of assurance that the findings of the literature are valid with respect to the relevant comparison. Underlying studies may report conflicting results. Further research is likely to change our confidence in the estimate of effect and may change the estimate for this outcome.

Insufficient. Evidence is either unavailable or does not permit estimation of an effect due to a lack of or sparse data. In general, when only one study has been published, the evidence was considered insufficient, unless the study was particularly large, robust, and of good quality.