# Future research needs

- Good quality studies in terms of clear reporting selection criteria, center characteristics, recruitment dates, and reasons for loss to followup are needed on the effectiveness of unilateral cochlear implants for speech perception and health-related quality-of-life outcomes.
- Studies that explore potential modifiers of cochlear implant outcomes need to carefully consider confounders, perform appropriate adjustments, and include sufficient numbers of subjects.
- Large databases or registries of patients who received cochlear implants with long-term followup data on patient outcomes are needed to properly explore potential modifiers of cochlear implant outcomes using multivariate analyses.
- Future research should focus on the association between expanding the candidacy profile of cochlear implants (e.g., degree of hearing loss, speech perception ability) and assessing consequent outcomes.
- Long-term studies are needed to assess health-related quality-of-life outcomes (both generic and disease-specific) in subjects with bilateral cochlear implantation.
- Long-term studies are needed to assess the complications and risks of bilateral cochlear implantation.
- Further research is needed to develop speech perception tests that mimic real-world listening conditions in order to assess the practical benefits associated with unilateral and bilateral cochlear implantation.
- Future research should focus on developing quality-of-life instruments specifically designed for people with severe-to-profound hearing impairment, so that patient-reported outcomes associated with unilateral and bilateral cochlear implantation can be assessed quantitatively.
- Future research is needed to identify a time period needed for the sound localization, improved speech perception, and improved health-related quality-of-life after bilateral implantation.
- Improved measures are needed to more accurately report outcomes in noise and 3D binaural fusion of perception of sound. There is a need to develop better measures of performance and disease-specific quality-of-life instruments that may reflect the significance of these important, but currently subjective benefits.
- There will be increasing demand for hybrid devices in the future with the improvements in technology and increasing elderly population. Studies should be designed to carefully assess baseline (including potentially outcome predictive) characteristics and performance measures to be compared with same subject performances postimplantation.