# Executive Summary

## Background

Sensorineural hearing loss is the third leading cause of disability during the adult years, according to the World Health Organization. This type of hearing loss is usually permanent, most commonly occurs gradually, and becomes worse with increasing age with clinical manifestations typically appearing during the fifth and sixth decades. In recent years, cochlear implants have been used in adults with sensorineural hearing loss. Cochlear implants replace the function of hair cells that are no longer able to generate electrical impulses in response to sound. Therefore, these devices may provide a viable alternative to hearing aids among older adults with sensorineural hearing loss as they bypass damaged hair cells by directly transmitting the electrical impulses to the acoustic nerve. Currently, most patients are fitted unilaterally, with some receiving contralateral assistance with a hearing aid when residual low-frequency hearing exists. In recent years, the number of people implanted bilaterally has continued to increase. Therefore, the Centers for Medicare and Medicaid Services (CMS) is interested in an evaluation of recent published literature on the effectiveness of cochlear implantation. After consultation with the Agency for Healthcare Research and Quality (AHRQ) and CMS, this technology assessment has been commissioned specifically to evaluate the clinical effectiveness of unilateral cochlear implants and bilateral cochlear implants in adult patients (≥ 18 years of age) with sensorineural hearing loss. The key questions were formulated in consultation with CMS and AHRQ.

## Methods

This report addresses the following key questions:

1. What current cochlear implantation devices are approved by the FDA for individuals ≥ 18 years of age? What are the indications for their use?
2. What are the communication-related health outcomes as well as the quality-of-life outcomes that are achieved in the population of adults (≥ 18 years old) who undergo unilateral cochlear implantation? How is a “successful” implantation defined?

2a For those individuals ≥ 18 years of age with sensorineural hearing loss, what are the preoperative patient characteristics associated with the successful attainment of the aforementioned improved communication-related health outcomes as well as quality-of-life outcomes in those who undergo unilateral cochlear implantation?
  At a minimum, the evidence surrounding the following will be discussed:
  1. Speech recognition/word understanding
  2. Auditory sensitivity/audibility
  3. Duration of impaired hearing
  4. Associated ear or bone disease
  5. Pre vs. postlinguistic deafness
  6. Presence of other disabilities (e.g. visual impairment, impending or current)
  7. Age at implantation
  8. Degree of preimplant residual hearing
  9. Choice of implanted ear
  10. Site or center (expertise) of cochlear implant team
  11. Implanted device
2b For studies included in key question 2 and 2a, report the available evidence separately for those individuals with sensorineural hearing loss as demonstrated by preimplantation test scores of > 40 percent and ≤ 50 percent, as well as those with test scores > 50 percent and ≤ 60 percent (best aided listening on tape or otherwise recorded tests of open-set sentence recognition).
3 For those individuals ≥ 18 years of age, what are the additional communication-related health outcomes as well as quality-of-life outcomes (as compared with those achieved in question 2) that are gained from the use of bilateral cochlear implants over a unilateral cochlear implant? How is a “successful” bilateral cochlear implant defined?
3a What are the preoperative patient characteristics associated with the successful attainment of the communication-related health outcomes as well as quality-of-life outcomes in questions 2 or 3 in individuals ≥ 18 years of age who undergo simultaneous bilateral cochlear implantation?
3b What are the preoperative patient characteristics associated with the successful attainment of the communication-related health outcomes as well as quality-of-life outcomes in questions 2 or 3 in individuals ≥ 18 years of age who undergo sequential bilateral cochlear implantation?
  At a minimum, the evidence surrounding the following will be discussed:
  1. Speech recognition/word understanding
  2. Auditory sensitivity/audibility
  3. Duration of impaired hearing
  4. Associated ear or bone disease
  5. Pre vs. postlinguistic deafness
  6. Presence of other disabilities (e.g. visual impairment, impending or current)
  7. Age at implantation
  8. Degree of preimplant residual hearing
  9. Choice of implanted ear
  10. Site or center (expertise) of cochlear implant team
  11. Implanted device
3c For studies included in key question 3, 3a and 3b, report the available evidence separately for those individuals with sensorineural hearing loss as demonstrated by preimplantation test scores of ≤ 40 percent, > 40 percent and ≤ 50 percent, as well as those with test scores between > 50 percent and ≤ 60 percent (best aided listening on tape or otherwise recorded tests of open-set sentence recognition).

For Key Question 1, we searched the Food and Drug Administration (FDA) database, Devices@FDA, the database of cleared and approved devices, for the term cochlear. We also searched for the term MCM (the specific product code for “implant, cochlear”) in the Premarket Approval database of the FDA. In ClinicalTrials.gov, we searched the term cochlear. For key questions 2 and 3, we searched MEDLINE®, the Cochrane Central Register of Controlled Trials, and Scopus (which includes articles indexed in Embase since 1997) from January, 2004 through February, 2011 for published studies of adult human subjects to identify articles relevant to each key question. Primary interventions of interest were both unilateral and bilateral cochlear implantation; also included were both sequential and simultaneous bilateral cochlear implantation as well as studies of patients who used both cochlear implants and hearing aids. Eligible devices included one or two multichannel cochlear implants using whole-speech processing coding strategies. We also included studies that compared preoperative and postoperative cochlear implantation, evaluating outcomes of interest. Comparisons of bilateral cochlear implantation with unilateral cochlear implantation with or without hearing aids, and with cochlear implantation left ear or right ear unilaterally were included. Outcomes of interest involved sound localization, speech perception outcomes (open-set sentences, two syllable or multi-syllable words), derived measures of binaural processing outcomes (head shadow, squelch, and summation) and health-related quality-of-life.

Items extracted included relevant study characteristics and population characteristics. Preoperative patient characteristics associated with communication-related health outcomes and health-related quality-of-life included speech recognition/word understanding, duration of impaired hearing, associated ear or bone disease, pre versus postlinguistic deafness, other disabilities (e.g., visual impairment, impending or current), age, degree of preimplant residual hearing, choice of implanted ear, site or center (expertise) of cochlear implant team, and implanted device. Outcomes were categorized according to open-set speech test, two syllable or multi-syllable test, health-related quality-of-life measures, and communication-related adverse events. We used a 3-grade (A, B, C) rating system to rate the quality of each individual study. We also used a 3-category rating system (high, moderate, insufficient) to assess the overall strength of evidence for the outcomes reported in each of the comparisons.

## Results and Strength of Evidence

We searched for articles on cochlear implants in adults published between January 2004 and February 2011 in the MEDLINE®, Scopus, and Cochrane Central databases and found 56 out of 1,908 articles that met our inclusion criteria.

### Key Question 1 FDA-approved cochlear implant devices

Our search of the FDA Web site found three cochlear implant devices currently approved for use in the U.S.: the Nucleus^®^ 5 (Cochlear™), the Harmony™ HiRes 90K^®^ (Advanced Bionics^®^), and the MAESTRO™ Cochlear Implant System [either SONATA_TI_^100^ or PULSAR_CI_^100^ implants] (MED-EL). Criteria for cochlear implant candidacy are variable across devices and individual to each. Based on the safety and efficacy information provided to the FDA by each device manufacturer, likely candidates could have percent correct scores on the Hearing in Noise Test (HINT) or open–set sentence recognition tests ranging from ≤ 40 to ≤ 60 percent (depending on the device as described in Table 1).

### Key Question 2 Effectiveness of unilateral cochlear implants

Evidence was rated as moderate based on nine quality-B studies (total of 22 studies), where postimplantation speech perception among adult subjects was greater compared with preimplantation speech perception as assessed with multi-syllable tests and open-set sentences tests, with or without hearing aids. Benefits were similarly shown in speech perception with unilateral cochlear implantation compared with hearing aids in one study. When health-related quality-of-life was evaluated with generic measures, unilateral cochlear implantation showed significant benefit on overall health-related quality-of-life and social domains compared with preimplantation measures. In addition, using disease-specific instruments of health-related quality-of-life measures, unilateral cochlear implantation showed benefits compared with preimplantation measures in these studies.

### Key Question 2a Preoperative patient characteristics associated with post implant improvement in communication and health outcomes

Evidence was rated low for eight quality-B studies (total of 21 studies), due to methodological deficiencies, that assessed preoperative patient characteristics as potential modifying factors of speech and/or quality-of-life outcomes including: duration of impaired hearing, age of implantation, older (≥ 65 years old) versus younger age (< 65 years old), type of implanted device, preoperative speech recognition or word understanding, degree of preimplant residual hearing, associated ear or bone disease, pre versus postlinguistic deafness, age of onset of hearing loss, and choice of implanted ear. No studies evaluated implant center/expertise of cochlear implant teams or other patient-related disabilities as potential modifying factors of outcomes. Overall, there was a low level of evidence regarding the association between preoperative patient characteristics (such as shorter duration of impaired hearing and better preoperative HINT score) and better postoperative speech outcomes. In addition, the studies provided insufficient evidence to draw a conclusion about the relationships between preoperative patient characteristics and postoperative health-related quality-of-life outcomes.

### Key Question 2b Effectiveness of unilateral cochlear implants by their preimplantation open-set sentence test scores of > 40 percent and ≤ 50 percent, and > 50 percent and ≤ 60 percent

Evidence was rated insufficient based on lack of data to address this question. Of the 22 studies that evaluated Key Question 2, there were no studies that used the results of open-set sentence tests for cochlear implantation indication. Of the 21 qualifying studies that evaluated Key Question 2a, only two (one quality-B; one quality-C) provided relevant data for this question. The quality-B study was a retrospective cohort of elderly (≥ 70 years old). Elderly with preimplantation HINT-Q scores below 20 percent, 20 to 40 percent, and > 40 percent were analyzed with respect to 1 year postimplant HINT-Q scores. The results indicated that better preimplant HINT-Q scores showed significant association with higher postimplant HINT-Q (r=0.44, P=0.02), and HINT-N (r=0.43, P=0.04) scores regardless of age. Only adults implanted with either the Clarion device or Nucleus device between 1991 and 2002 were included in the analyses. The criteria for cochlear implantation included severe-to-profound hearing loss in both ears (mean 70 dB) and a score of less than 50 percent on an open-set sentence test using conventional hearing aid(s). The proportion of patients between the scores of > 40 percent and ≤ 50 percent was unclear. Sixty-five elderly adults (≥ 70 years old) were compared with 101 younger adults (< 70 years old) for speech outcomes. The study found that both elderly and younger adults had significant improvements in HINT and CID scores after implantation. However, there were no significant differences between groups (P=0.07). This analysis was not adjusted for potential confounding factors.

### Key Question 3 Effectiveness of bilateral cochlear implants, sequential and simultaneous

Evidence was rated moderate to low based on data from nine quality-B studies assessing subjects with simultaneous or sequential bilateral cochlear implantation. Overall, 16 studies published since 2004 evaluated subjects with bilateral cochlear implants that met our eligibility criteria. Studies evaluating speech perception in noise conditions found significant gains with bilateral simultaneous cochlear implants compared with a unilateral cochlear implant. One cross-sectional study showed no benefit and another study did not evaluate speech outcomes. The results of speech perception in quiet and health-related quality-of-life were mixed across studies. Only three of 16 studies assessed health-related quality-of-life in subjects with bilateral implants. While subjects with bilateral cochlear implants showed significant gains in some disease-specific instruments of health-related quality-of-life subscales, others found no difference between the two groups. In a randomized controlled trial evaluating sequential bilateral cochlear implants, the second ear implant resulted in negative or non-significant results for quality-of-life after the first ear implant.

### Key Question 3a, 3b Preoperative patient characteristics associated with post implant improvement in communication and health outcomes among bilateral implants

Evidence was rated low based on two quality-B rated studies reporting data on age at implantation as a predictor of postoperative outcomes. The first study reported that preoperative characteristic such as age at implantation (≤ 59 years of age) was predictive of different postoperative outcomes evaluated in this study among simultaneous bilateral implants. The second study did not find an association between age at second implant and postoperative outcomes among sequential bilateral implants. Duration of hearing loss before implant (two quality-B studies) and implant device characteristics (one quality-B study) did not predict postoperative outcomes in bilateral implants.

### Key Question 3c Effectiveness of bilateral cochlear implants by their preimplantation test scores test scores of ≤ 40 percent, > 40 percent and ≤ 50 percent, and > 50 percent and ≤ 60 percent

Overall, evidence was rated low for the effectiveness of simultaneous bilateral implantation by their preimplantation open-set sentence test scores of ≤ 40 percent, which was evaluated in three quality-B studies that showed improved speech perception, and sound localization, but inconsistent gains in terms of hearing-specific quality-of-life in one study. Evidence was rated moderate for the effectiveness of simultaneous bilateral implantation by their preimplantation open-set sentence test scores of ≤ 40 percent, which was evaluated in three quality-B studies that showed improved speech perception, sound localization, and binaural processing. Evidence was rated insufficient for the outcome of hearing-specific quality-of-life in one study that evaluated this outcome. Although two studies of simultaneous bilateral implants conducted in the U.S. reported the requirement of an open-set sentence score of ≤ 50 percent in the best-aided condition as an indication for bilateral cochlear implantation, the evidence was rated insufficient because of lack of information on the percentage of subjects with preimplantation scores of > 40 percent and ≤ 50 percent. No studies reported data on the preimplantation scores of > 50 percent and ≤ 60 percent among bilateral implants.

Evidence was rated insufficient for the effectiveness of sequential bilateral implantation by the preimplantation test scores of ≤ 40 percent, which was evaluated in one quality-B study that showed improved speech perception in noise, and sound localization. This study included subjects who had a preoperative open-set sentence score of minimum 30 percent (after first ear implant) in the best-aided condition as an indication for bilateral cochlear implantation. This study reported that no significant advantage after the second ear implant over the first (unilateral) ear with the CUNY test in quiet at 3 and 9 months of followup. The second ear implant also resulted in negative results or non-significant changes in health-related quality-of-life after the first ear implant.

### Discontinuation of use

Of the 56 articles included in this report, four studies reported adverse events of total hearing loss or permanent discontinuation of use as a result of hearing-related complications. Twenty out of 495 distinct subjects within these studies permanently discontinued use of their cochlear implant(s) after experiencing an adverse event.

ES Table 1 Strength of Evidence for Effectiveness of Cochlear Implants in Adults with Sensorineural Hearing Loss

| High | Moderate | Low | Insufficient
KQ1. Current cochlear implantation devices that are approved by the FDA in adults | -- | -- | -- | --
KQ2. Effectiveness of unilateral cochlear implants
Speech perception using open-set sentences tests; multi-syllable tests | | X
Generic or disease-specific HRQoL outcomes | | X
2a. Association between preoperative patient characteristics and postoperative outcomes after unilateral cochlear implants
Speech perception using open-set sentences tests
Duration of impaired hearing | | X
Age at implantation | | | X
Type of implanted device | | | X
Older age (≥65 yr) versus younger age, preoperative speech perception scores, degree of preimplant residual hearing, associated ear or bone disease, post versus prelinguistic deafness, age of hearing loss onset, or choice of implanted ear | | | | X
Implant center or expertise of cochlear implant team or other patient-related disabilities | | | | X a
Generic or disease-specific HRQoL outcomes
Duration of impaired hearing, age at implantation, older age (≥65 yr) versus younger age, preoperative speech perception scores, or degree of preimplant residual hearing | | | | X
Type of implanted device, associated ear or bone disease, post versus prelinguistic deafness, age of hearing loss onset, choice of implanted ear, implant center or expertise of cochlear implant team or other patient-related disabilities | | | | X a
2b. Data for individuals with specific indications for unilateral cochlear implants^b^ | | | | X
KQ3. Effectiveness of bilateral versus unilateral cochlear implants
3. Bilateral simultaneous cochlear implants
Speech perception using open-set sentences tests; multi-syllable tests | | X
Sound localization | | X
Generic or disease-specific HRQoL outcomes | | | X
3. Bilateral sequential cochlear implants
Speech perception using open-set sentences tests; multi-syllable tests | | X
Sound localization | | X
Generic or disease-specific HRQoL outcomes | | | X
3a, b. Association between preoperative patient characteristics and postoperative outcomes after bilateral cochlear implants
Age at implantation | | | X
Duration of impaired hearing | | | X
Type of implanted device | | | | X
Degree of preimplant residual hearing, associated ear or bone disease, post versus prelinguistic deafness, age of hearing loss onset, or choice of implanted ear, implant center or expertise of cochlear implant team or other patient-related disabilities | | | | X a
3c. Data for individuals with specific indications for bilateral cochlear implants b | | | | X
Bilateral simultaneous cochlear implants | | | X
preimplantation open-set sentence test scores of ≤ 40 percent and outcome speech perception | | X
preimplantation open-set sentence test scores of ≤ 40 percent and outcome quality-of-life | | | | X
Bilateral sequential cochlear implants
preimplantation open-set sentence test scores of ≤ 40 percent | | | | X

HRQoL = health-related quality-of-life

a No study available

b Individuals with sensorineural hearing loss as demonstrated by test scores of > 40 percent and ≤ 50 percent, as well as those with test scores > 50 percent and ≤ 60 percent

## Discussion

Our review indicates that unilateral cochlear implantation is an effective method of hearing assistance that provides significant gains in speech perception and health-related quality-of-life in adults with sensorineural hearing loss. Adults showed significant benefit in postimplantation speech perception scores (both multi-syllable tests and open-set sentences tests) over preimplantation scores, which were consistent across studies whether they did or did not utilize bimodal hearing (unilateral cochlear implantation with additional use of hearing aids). In general, unilateral cochlear implantation showed benefits in both generic and disease-specific health-related quality-of-life measures compared with preimplantation results. Studies of unilateral implants provided low to insufficient level evidence regarding relationships between preoperative patient characteristics and postoperative health-related quality-of-life outcomes, making it difficult to render any conclusions. There was insufficient evidence to address the effectiveness of unilateral cochlear implants by their preimplantation open-set sentence test scores of > 40 percent and ≤ 50 percent, and > 50 percent and ≤ 60 percent. Reviewed studies from current literature were rated moderate or poor quality due to incomplete reporting of information including study selection criteria, recruitment of study subjects and year of recruitment, center characteristics, and reasons for loss to followup.

Results from recently published studies of bilateral cochlear implantation imply greater benefit in speech perception test scores among adults compared with unilateral cochlear implantation with or without hearing aids, particularly in noise conditions. There is a demonstrated advantage in speech perception discrimination in noise with bilateral hearing, apparently with intact ears or with cochlear implants. However, benefit under quiet conditions was unclear suggesting that in such quiet conditions, the first ear implant may likely to be “ceiling out” the effects of the second ear’s implant under such listening conditions. Results from a series of studies indicated significant binaural head-shadow benefit, in bilateral listening conditions over unilateral listening conditions, suggesting that subjects with bilateral cochlear implants could perform better in real world conditions. In the reviewed literature, one study found a small binaural squelch effect after 1 year of bilateral implantation, while four studies found small or non-significant squelch effects. The results of this review document an increase in benefit following long-term experience with bilateral implants, thus emphasizing a need for long-term followup studies. Estimates of binaural summation were slightly better in bilateral listening condition but were statistically non-significant compared with the unilateral listening conditions in two studies. These study results were in contrast and summation values were smaller than the effects reported in one study. Given the small number of subjects with bilateral cochlear implants included in these studies, cautious interpretation of these results is needed to draw definitive conclusions. Although evidence was rated moderate for the effectiveness of simultaneous bilateral implantation by their preimplantation open-set sentence test scores of ≤ 40 percent, there was insufficient data for the outcome of hearing-specific quality-of-life as only one study evaluated this outcome. The evidence was rated insufficient because of lack of information on the percentage of subjects with bilateral implants who had preimplantation scores of > 40 percent and ≤ 50 percent. No studies reported data on the preimplantation scores of > 50 percent and ≤ 60 percent among bilateral implants. Lack of information on candidacy criteria in evaluated studies emphasizes the need for additional research to address health policy needs.

Although published studies revealed significant gains in terms of speech perception outcomes, this did not translate to consistent gains in the perceived performance as assessed through a variety of health-related quality-of-life measures in three studies of bilateral cochlear implantation. Sparse data and inconsistent benefits in terms of health-related quality-of-life outcomes preclude any definitive conclusions with regard to benefits in quality-of-life outcomes in subjects with bilateral cochlear implantation. In general, cochlear implantation is safe and provides benefit to patients. Similar to any surgical procedure, complications can occur. A second ear implant brings additional risk in terms of additional surgery and an increase in operating time. Further studies with longer followup duration are needed to assess the benefits and potential risks of bilateral cochlear implantation.

## Conclusion

In summary, unilateral cochlear implantation with or without additional use of hearing aids has been an effective method of hearing assistance. Published studies show improved speech perception and health-related quality-of-life in adults with sensorineural hearing loss. Bilateral cochlear implantation provides added improvements in speech perception outcomes in noisy environments over unilateral cochlear implantation. With future improvements in implant device technology and implant programming, the number of patients implanted bilaterally will continue to increase. Further studies with longer followup duration are needed to assess the additional benefits in terms of improved health-related quality-of-life and potential risks of bilateral cochlear implantation compared with unilateral implantation. Additionally, none of the studies have been able to quantify the sensation described by patients of fusion of bilateral sound into a stereo perception within one’s head. There is a need to develop better measures of performance and disease-specific quality-of-life instruments that may reflect the significance of these subjective benefits.