# Abbreviations

APHAB: Abbreviated Profile of Hearing Aid Benefit
ADIDS: Adapted Deaf Identity Developmental Scale
AQoL: Assessment quality-of-life
AzBio: AzBio sentence test
BKB: Bamford-Kowal-Bench speech perception test
BKB-SIN: Bamford-Kowal-Bench Speech-in-Noise Test
CID: Central Institute for the Deaf sentences
CNC: Consonant-Nucleus-Consonant words
CPA: Centro de Pesquisas Audiológicas sentence recognition test
CUNY: City University of New York tests
CVC: Consonant-Vocal-Consonant
dB HL: Decibel Hearing Level
EQ-5D: EuroQoL 5 dimensions
FDA: Food and Drug Administration
GBI: Glasgow Benefit Inventory
GHSI: Glasgow Health Status Inventory
HHIA: Hearing Handicap Inventory for Adults
HHIE: Hearing Handicap Inventory for the Elderly
HHQ: Hearing Handicap Questionnaire
HINT: Hearing in Noise Test
HINT-Q: HINT sentences/speech in quiet
HPS: Hearing Participation Scale
HRQoL: Health-related quality-of-life
HSM: Hochmair, Schultz and Moser sentence test
HUI-2: Health Utilities Index Mark II
HUI-3: Health Utilities Index Mark III
Hz: Hertz
KQ: Key Question
MCM: FDA product code for “implant, cochlear”
NCIQ: Nijmegen Cochlear Implant Questionnaire
NICE: National Institute for Clinical Excellence (UK)
OLSA: Oldenburg sentence test
SF-36: The Short Form (36) Health Survey
SNR: Signal to noise ratio
SPL: Sound pressure level
SRT: Speech recognition threshold
TAP: Technology Assessment Program
UKCISG: UK Cochlear Implant Study Group
VAS: Visual Analogue Scale

Detailed descriptions of abbreviations and relevant terms are listed in Appendix A.