# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- John K. Niparko, MD
  George T. Nager Professor of Otolaryngology-Head & Neck Surgery
  The Johns Hopkins University School of Medicine
  Baltimore, MD
- Sarah F. Poissant PhD
  Associate Professor
  University of Massachusetts Amherst
  Amherst, MA
- Susan Waltzman, PhD, CCC-A
  Marica F. Vilcek Professor of Otolaryngology and Co-Director
  NYU Cochlear Implant Center Affiliation
  New York, NY