# Discussion

Our review found that in adults with sensorineural hearing loss, unilateral cochlear implantation is an effective method of hearing assistance that provides significant gains in speech perception and health-related quality-of-life. Adults showed significant benefit in postimplantation speech perception scores (both multi-syllable tests and open-set sentences tests) over preimplantation scores, which were consistent across 11 studies whether they did or did not utilize bimodal hearing (unilateral cochlear implantation with additional use of hearing aids). In general, unilateral cochlear implantation showed benefits in both generic and disease-specific health-related quality-of-life measures compared with preimplantation results. However, in certain subscales, such as social domains of overall health-related quality-of-life, subjects with unilateral implants failed to show significant benefits in physical, cognitive, and emotional measures. Additionally, studies of unilateral implants provided insufficient evidence to draw a conclusion about the relationships between preoperative patient characteristics and postoperative health-related quality-of-life outcomes. There was insufficient evidence to address the effectiveness of unilateral cochlear implants by their preimplantation open-set sentence test scores of > 40 percent and ≤ 50 percent, and > 50 percent and ≤ 60 percent. Overall, there was low level of evidence regarding the association between preoperative patient characteristics (such as shorter duration of impaired hearing, better preoperative HINT score, and postlinguistic deafness) and better postoperative speech outcomes. In addition, the studies provided insufficient evidence to draw a conclusion about the relationships between preoperative patient characteristics and postoperative health-related quality-of-life outcomes. Largely due to small sample sizes, the studies mostly had imprecise estimates of the comparative effects. Small studies reported an association between preoperative patient characteristics, such as shorter duration of impaired hearing, better preoperative HINT score, and postlinguistic deafness and better postoperative speech outcomes. We found no studies that examined side of implantation or expertise of cochlear implant teams or other patient-related disabilities as potential modifying factors of speech perception and/or health-related quality-of-life outcomes. The device non-use rate secondary to hearing-related complications was 4.0 percent among subjects with cochlear implants.

Recently published studies of bilateral simultaneous cochlear implantation show greater benefit in speech perception and localization among adults compared with unilateral cochlear implantation with or without hearing aids, particularly in noise conditions. However, benefit under quiet conditions was unclear among those who had bilateral sequential cochlear implantation. This result is to be expected as it is generally not a test that is usually administered. In such quiet conditions, the first ear implant is likely to be “ceiling out” the effects of the second ear‘s implant under such listening conditions. Studies showed significant gains in the binaural processing measure of head-shadow benefit with an average 38 to 55 percent improvement over unilateral listening conditions, suggesting that subjects with bilateral cochlear implants may perform better in real world conditions. One study found a small binaural squelch effect after 1 year of bilateral implantation,46 while others found small or non-significant squelch effects.44, 48, 53, 54 In addition, a small sample size study of nine subjects followed over a period of 4 years has shown consistent benefit in binaural squelch over longer duration of followup.63 This results of this study documents an increase in benefit following long-term experience with bilateral implants, thus emphasizing a need for long-term followup studies. Estimates of binaural summation were slightly better in bilateral listening condition but were statistically non-significant compared with the unilateral listening conditions in two studies.46, 54 These study results were in contrast and summation values were smaller than the effects reported in one study.53 Given the small number of subjects with short duration of followup in bilateral cochlear implants included in these studies, cautious interpretation of these results is needed to draw definitive conclusions regarding speech perception outcomes. Small benefits in summation and squelch effects suggest that subjects with bilateral implants may be able to neurally integrate inputs over time. Further continued assessments are needed to know which of these perceptual abilities translate into clinically measurable benefit in real-world performance thereby improving health-related quality-of-life outcomes.

Although there were significant gains in terms of speech perception outcomes, in published studies this did not translate to consistent gains in the perceived performance as assessed through a variety of health-related quality-of-life measures in three studies that reported these outcomes. Sparse data and inconsistent benefits in terms of health-related quality-of-life outcomes preclude any definitive conclusions regarding improved quality-of-life in subjects with bilateral cochlear implantation. Inconsistent benefits may also indicate a lack of better measures of performance and a need to develop quality-of-life instruments specifically designed for people with severe-to-profound hearing loss, which can be used to assess health-related quality-of-life outcomes in subjects with bilateral cochlear implantation. Results from a small number of subjects in a randomized controlled trial reported that the positive binaural benefit may have been offset by the worsening of tinnitus after the second implant.51 However, observational studies have also shown improvement in tinnitus with bilateral cochlear implantation. In general, cochlear implantation is safe and provides benefit to patients. Similar to any surgical procedure, complications can occur. A second ear implant brings additional risk in terms of additional surgery and an increase in operating time. Of note, only one bilateral cochlear implantation reported adverse events in a small sample with 6 months of followup.52 It is important to assess long-term outcomes from bilateral implantation because of its irreversible changes to the cochlea, without preserving one ear for future medical intervention. Further studies with longer followup duration are needed to assess health-related quality-of-life outcomes in bilateral cochlear implantation.

Overall, evidence was rated low for the effectiveness of simultaneous bilateral implantation by their preimplantation open-set sentence test scores of ≤ 40 percent, which was evaluated in three quality-B studies that showed improved speech perception, and sound localization, but inconsistent gains in terms of hearing-specific quality-of-life in one study. Although evidence was rated moderate for the effectiveness of simultaneous bilateral implantation by their preimplantation open-set sentence test scores of ≤ 40 percent, there was insufficient data for the outcome of hearing-specific quality-of-life as only one study evaluated this outcome. The evidence was rated insufficient because of lack of information on the percentage of subjects with bilateral implants who had preimplantation scores of > 40 percent and ≤ 50 percent. No studies reported data on the preimplantation scores of > 50 percent and ≤ 60 percent among bilateral implants. Lack of information on candidacy criteria in evaluated studies emphasizes that additional research should be conducted to address health policy needs.

Potential limitations of our review directly reflect the limitations of recently published studies of unilateral and bilateral cochlear implantation. Although unilateral cochlear implantation is a well-established intervention, good-quality studies are still needed to yield stronger evidence of their effectiveness for speech-perception and health-related quality-of-life outcomes. Reviewed studies from current literature were rated moderate or poor quality due to incomplete reporting of information including study selection criteria, recruitment of study subjects and year of recruitment, center characteristics, adjustment for potential confounders, and reasons for loss to followup. Additionally, more studies with longer duration are suggested to examine change in effectiveness of bilateral cochlear implants especially for health-related quality-of-life using disease specific instruments. Studies that analyzed preoperative patient characteristics as potential predictors of postoperative speech perception outcomes (open-set sentences, two syllable words) and/or health-related quality-of-life outcomes did not account for potential confounding factors in their analyses. Number of subjects needed in a multivariate analysis is typically larger than a univariate analysis (which does not account for potential confounding). There are some guidelines regarding the number of candidate predictors that can reliably be studied in relation to the size of the data set. A well-known rule of thumb is the 1 in 10 rule.64 That is, for linear regression models, one candidate predictor can be studied for every 10 patients. Thus, most of the included studies did not have sufficient number of subjects for multivariate analysis of more than two candidate predictors. Existing studies do not allow accurate conclusions to be drawn. All except for one study tested sound localization in quiet, with no background noise among bilateral cochlear implant users, thus failing to evaluate in realistic listening environments. Furthermore, use of cross-over study design to evaluate performance of bilateral implants for outcomes of localization and speech perception outcomes may have precluded evaluation of health-related quality-of-life outcomes, which may require use of alternative study designs.