# Conclusion

In summary, unilateral cochlear implantation with or without additional use of hearing aids has been an effective method for improving speech perception and health-related quality-of-life in adults with severe to profound sensorineural hearing loss. Bilateral cochlear implantation provides added improvements in speech perception outcomes in noisy environments over unilateral cochlear implantation. Bilateral cochlear implants show significant binaural head-shadow benefit, small benefits in binaural summation, binaural squelch effects, and better sound localization. Although the magnitude of the benefits in noise appears modest, they translate to significant and important differences as reported anecdotally by patients. Additionally, none of the studies have been able to quantify the sensation described by patients of fusion of bilateral sound into a stereo perception within one’s head. There is a need to develop better measures of performance and disease-specific quality-of-life instruments that may reflect the significance of these subjective benefits. Further studies with longer followup duration are needed to assess the additional benefits in terms of improved health-related quality-of-life and potential risks of bilateral cochlear implantation compared with unilateral implantation.