# References of Included Studies

1 Sprinzl GM, Riechelmann H. Current trends in treating hearing loss in elderly people: a review of the technology and treatment options - a mini-review. Gerontology. 2010;56(3):351-8.
2 Gates GA, Rees TS. Hear ye? Hear ye! Successful auditory aging. West J Med. October. 1997;167(4):247-52. [pmid: 9348755].
3 Bond M, Mealing S, Anderson R, et al. The effectiveness and cost-effectiveness of cochlear implants for severe to profound deafness in children and adults: a systematic review and economic model. Health Technol Assess. September. 2009;13(44):1-330. [pmid: 19799825].
4 Isaacson B, Lee KH, Kutz JW, Roland PS, Sargent EW. Cochlear Implants, Indications. emedicine medscape com. 2010. June. 25. Available at: URL: http://emedicine.medscape.com/article/857164-print.
5 Huart SA. Unidentified and Underserved: Cochlear Implant Candidates in the Hearing Aid Dispensing Practice. www audiology online. 2009. August. 17. Available at: URL: www.audiologyonline.com/articles/pf_article_detail.asp?article_id=2272. September 20, 2010.
6 Disability Programs. www socialsecurity gov. 2010. August. Available at: URL: http://www.ssa.gov/disability/professionals/bluebook/2.00-SpecialSensesandSpeech-Adult.htm#2_10.
7 NICE. Cochlear implants for children and adults with severe to profound deafness. National Institute for Health and Clinical Excellence. 2009. January. 28. Available at: URL: http://www.nice.org.uk/TA166.
8 Bai Z, Stephens D. Subjective outcome measures after cochlear implantation: Overall measures. Audiological Medicine. 2005;3(4):212-9. PMID: None.
9 Bassim MK, Buss E, Clark MS, et al. MED-EL Combi40+ cochlear implantation in adults. Laryngoscope. 2005;115(9):1568-73. [pmid: 16148696].
10 Damen GWJA, Beynon AJ, Krabbe PFM, Mulder JJS, Mylanus EAM. Cochlear implantation and quality of life in postlingually deaf adults: Long-term follow-up. Otolaryngology - Head and Neck Surgery. 2007;136(4):597-604. [pmid: 17418258].
11 Gifford RH, Shallop JK, Peterson AM. Speech recognition materials and ceiling effects: considerations for cochlear implant programs. Audiol Neurootol. 2008;13(3):193-205. [pmid: 18212519].
12 Hay-McCutcheon MJ, Pisoni DB, Kirk KI. Audiovisual speech perception in elderly cochlear implant recipients. The Laryngoscope. 2005;115(10):1887-94. [pmid: 16222216].
13 Gantz BJ, Hansen MR, Turner CW, Oleson JJ, Reiss LA, Parkinson AJ. Hybrid 10 clinical trial: preliminary results. Audiol Neurootol. Suppl 1. 2009;14:8-13. [pmid: 19390170].
14 Hawthorne G, Hogan A, Giles E, et al. Evaluating the health-related quality of life effects of cochlear implants: a prospective study of an adult cochlear implant program. Int J Audiol. 2004;43(4):183-92. [pmid: 15250122].
15 Klop WMC, Boermans PPBM, Ferrier MB, Van Den Hout WB, Stiggelbout AM, Frijns JHM. Clinical relevance of quality of life outcome in cochlear implantation in postlingually deafened adults. Otology and Neurotology. 2008;29(5):615-21. [pmid: 18451751].
16 Krueger B, Joseph G, Rost U, StrauÃŸ-Schier A, Lenarz T, Buechner A. Performance groups in adult cochlear implant users: Speech perception results from 1984 until today. Otology and Neurotology. 2008;29(4):509-12. [pmid: 18520586].
17 Liu B, Chen XQ, Kong Y, et al. Quality of life after cochlear implantation in postlingually deaf adults. National Medical Journal of China. 2008;88(22):1550-2. [pmid: 18956638].
18 Mawman DJ, Bhatt YM, Green KMJ, O'Driscoll MP, Saeed SR, Ramsden RT. Trends and outcomes in the Manchester adult cochlear implant series. Clinical Otolaryngology and Allied Sciences. 2004;29(4):331-9. [pmid: 15270818].
19 Morris LG, Mallur PS, Roland J, Waltzman SB, Lalwani AK. Implication of central asymmetry in speech processing on selecting the ear for cochlear implantation. Otology and Neurotology. 2007;28(1):25-30. [pmid: 17195742].
20 Most T, Shrem H, Duvdevani I. Cochlear implantation in late-implanted adults with prelingual deafness. Am J Otolaryngol. November. 2010;31(6):418-23. [pmid: 20015795].
21 Orabi AA, Mawman D, Al-Zoubi F, Saeed SR, Ramsden RT. Cochlear implant outcomes and quality of life in the elderly: Manchester experience over 13 years. Clinical Otolaryngology. 2006;31(2):116-22. [pmid: 16620330].
22 Rama-Lopez J, Cervera-Paz FJ, Manrique M. Cochlear implantation of patients with far-advanced otosclerosis. Otology and Neurotology. 2006;27(2):153-8. [pmid: 16436983].
23 Roditi RE, Poissant SF, Bero EM, Lee DJ. A predictive model of cochlear implant performance in postlingually deafened adults. Otology and Neurotology. 2009;30(4):449-54. [pmid: 19415041].
24 Firszt JB, Holden LK, Skinner MW, et al. Recognition of speech presented at soft to loud levels by adult cochlear implant recipients of three cochlear implant systems. Ear Hear. 2004;25(4):375-87. [pmid: 15292777].
25 UK Cochlear Implant Study Group. Criteria of candidacy for unilateral cochlear implantation in postlingually deafened adults III: prospective evaluation of an actuarial approach to defining a criterion. Ear Hear. 2004;25(4):361-74. [pmid: 15292776].
26 Vermeire K, Brokx JPL, Wuyts FL, Cochet E, Hofkens A, Van De Heyning PH. Quality-of-life benefit from cochlear implantation in the elderly. Otology and Neurotology. 2005;26(2):188-95. [pmid: 15793403].
27 Vermeire K, Brokx JPL, Wuyts FL, et al. Good speech recognition and quality-of-life scores after cochlear implantation in patients with DFNA9. Otology and Neurotology. 2006;27(1):44-9. [pmid: 16371846].
28 Wanscher JH, Faber CE, Grontved AM. Effect on quality of life of cochlear implantation in deaf adults. Ugeskr Laeger. 2006;168(33):2656-9. [pmid: 16942684].
29 Bradley J, Bird P, Monteath P, Wells JE. Improved speech discrimination after cochlear implantation in the Southern Cochlear Implant Adult Programme. New Zealand Medical Journal. 2010;123(1321):34-44. [pmid: 20927155].
30 Lazard DS, Bordure P, Lina-Granade G, et al. Speech perception performance for 100 post-lingually deaf adults fitted with Neurelec cochlear implants: Comparison between Digisonic(R) Convex and Digisonic(R) SP devices after a 1-year follow-up. Acta Otolaryngol. November. 2010;130(11):1267-73. [pmid: 20446821].
31 Friedland DR, Runge-Samuelson C, Baig H, Jensen J. Case-control analysis of cochlear implant performance in elderly patients. Archives of Otolaryngology - Head and Neck Surgery. 2010;136(5):432-8. [pmid: 20479370].
32 Haensel J, Ilgner J, Chen YS, Thuermer C, Westhofen M. Speech perception in elderly patients following cochlear implantation. Acta Otolaryngol (Stockh). 2005;125(12):1272-6. [pmid: 16303673].
33 Bodmer D, Shipp DB, Ostroff JM, et al. A comparison of postcochlear implantation speech scores in an adult population. Laryngoscope. 2007;117(8):1408-11. [pmid: 17585277].
34 Chatelin V, Kim EJ, Driscoll C, et al. Cochlear implant outcomes in the elderly. Otology and Neurotology. 2004;25(3):298-301. [pmid: 15129109].
35 Francis HW, Yeagle JD, Brightwell T, Venick H. Central effects of residual hearing: Implications for choice of ear for cochlear implantation. Laryngoscope. 2004;114(10 I):1747-52. [pmid: 15454765].
36 Green KMJ, Bhatt YM, Mawman DJ, et al. Predictors of audiological outcome following cochlear implantation in adults. Cochlear Implants Int. 2007;8(1):1-11. [pmid: 17479968].
37 Nascimento LTd, Bevilacqua MC. Evaluation of speech perception in noise in cochlear implanted adults. Rev Bras Otorrinolaringol (Engl Ed). 2005;71(4):432-8. [pmid: 16446956].
38 Rotteveel LJC, Snik AFM, Cooper H, Mawman DJ, Van Olphen AF, Mylanus EAM. Speech perception after cochlear implantation in 53 patients with otosclerosis: Multicentre results. Audiology and Neurotology. 2010;15(2):128-36. [pmid: 19690406].
39 Spahr AJ, Dorman MF. Performance of Subjects Fit with the Advanced Bionics CII and Nucleus 3G Cochlear Implant Devices. Archives of Otolaryngology - Head and Neck Surgery. 2004;130(5):624-8. [pmid: 15148187].
40 Matterson AG, O'Leary S, Pinder D, Freidman L, Dowell R, Briggs R. Otosclerosis: Selection of ear for cochlear implantation. Otology and Neurotology. 2007;28(4):438-46. [pmid: 17468676].
41 Carlson ML, Breen JT, Gifford RH, et al. Cochlear implantation in the octogenarian and nonagenarian. Otology and Neurotology. October. 2010;31(8):1343-9. [pmid: 20729782].
42 Dunn CC, Tyler RS, Oakley S, Gantz BJ, Noble W. Comparison of speech recognition and localization performance in bilateral and unilateral cochlear implant users matched on duration of deafness and age at implantation. Ear Hear. 2008;29(3):352-9. [pmid: 18453885].
43 Dunn CC, Noble W, Tyler RS, Kordus M, Gantz BJ, Ji H. Bilateral and unilateral cochlear implant users compared on speech perception in noise. Ear Hear. 2010;31(2):296-8. [pmid: 19858720].
44 Koch DB, Soli SD, Downing M, Osberger MJ. Simultaneous bilateral cochlear implantation: Prospective study in adults. Cochlear Implants Int. 2009;11(2):84-99. [pmid: 19247979].
45 Litovsky R, Parkinson A, Arcaroli J, Sammeth C. Simultaneous bilateral cochlear implantation in adults: a multicenter clinical study. Ear Hear. 2006;27(6):714-31. [pmid: 17086081].
46 Noble W, Tyler R, Dunn C, Bhullar N. Hearing handicap ratings among different profiles of adult cochlear implant users. Ear Hear. 2008;29(1):112-20. [pmid: 18091100].
47 Buss E, Pillsbury HC, Buchman CA, et al. Multicenter U.S. bilateral MED-EL cochlear implantation study: Speech perception over the first year of use. Ear Hear. 2008;29(1):20-32. [pmid: 18091099].
48 Grantham DW, Ashmead DH, Ricketts TA, Labadie RF, Haynes DS. Horizontal-plane localization of noise and speech signals by postlingually deafened adults fitted with bilateral cochlear implants. Ear Hear. 2007;28(4):524-541. [pmid: 17609614].
49 Litovsky RY, Parkinson A, Arcaroli J, et al. Bilateral Cochlear Implants in Adults and Children. Archives of Otolaryngology - Head and Neck Surgery. 2004;130(5):648-55. [pmid: 15148192].
50 Litovsky RY, Parkinson A, Arcaroli J. Spatial hearing and speech intelligibility in bilateral cochlear implant users. Ear Hear. 2009;30(4):419-431. [pmid: 19455039].
51 Mosnier I, Sterkers O, Bebear JP, et al. Speech performance and sound localization in a complex noisy environment in bilaterally implanted adult patients. Audiol Neurootol. 2009;14(2):106-14. [pmid: 18832816].
52 Quentin Summerfield A, Barton GR, Toner J, et al. Self-reported benefits from successive bilateral cochlear implantation in post-lingually deafened adults: randomised controlled trial. Int J Audiol. Suppl 1. 2006;45:S99-107. [pmid: 16938781].
53 Ramsden R, Greenham P, O'Driscoll M, et al. Evaluation of bilaterally implanted adult subjects with the nucleus 24 cochlear implant system. Otology and Neurotology. 2005;26(5):988-98. [pmid: 16151348].
54 Schleich P, Nopp P, D'Haese P. Head shadow, squelch, and summation effects in bilateral users of the MED-EL COMBI 40/40+ cochlear implant. Ear Hear. 2004;25(3):197-204. [pmid: 15179111].
55 Laske RD, Veraguth D, Dillier N, Binkert A, Holzmann D, Huber AM. Subjective and objective results after bilateral cochlear implantation in adults. Otology and Neurotology. 2009;30(3):313-8. [pmid: 19318885].
56 Nopp P, Schleich P, D'Haese P. Sound localization in bilateral users of MED-EL COMBI 40/40+ cochlear implants. Ear Hear. 2004;25(3):205-14. [pmid: 15179112].
57 Verschuur CA, Lutman ME, Ramsden R, Greenham P, O'Driscoll M. Auditory localization abilities in bilateral cochlear implant recipients. Otology and Neurotology. 2005;26(5):965-71. [pmid: 16151344].
58 Zeitler DM, Kessler MA, Terushkin V, et al. Speech perception benefits of sequential bilateral cochlear implantation in children and adults: A retrospective analysis. Otology and Neurotology. 2008;29(3):314-25. [pmid: 18494140].
59 Laszig R, Aschendorff A, Stecker M, et al. Benefits of bilateral electrical stimulation with the nucleus cochlear implant in adults: 6-Month postoperative results. Otology and Neurotology. 2004;25(6):958-68. [pmid: 15547426].
60 Cullington HE, Zeng Fg. Bimodal hearing benefit for speech recognition with competing voice in cochlear implant subject with normal hearing in contralateral ear. Ear Hear. 2010;31(1):70-73. [pmid: 19858722].
61 Noble W, Tyler RS, Dunn CC, Bhullar N. Younger- and older-age adults with unilateral and bilateral cochlear implants: speech and spatial hearing self-ratings and performance. Otology and Neurotology. 2009;30(7):921-929. [pmid: 19692936].
62 Ray J, Wright T, Fielden C, Cooper H, Donaldson I, Proops DW. Non-users and limited users of cochlear implants. Cochlear Implants Int. 2006;7(1):49-58. [pmid: 18792374].
63 Eapen RJ, Buss E, Adunka MC, Pillsbury HC, Buchman CA. Hearing-in-noise benefits after bilateral simultaneous cochlear implantation continue to improve 4 years after implantation. Otology and Neurotology. 2009;30(2):153-159. [pmid: 19180675].
64 Harrell FE Jr, Lee KL, Califf RM, Pryor DB, Rosati RA. Regression modelling strategies for improved prognostic prediction. Stat Med. April. 1984;3(2):143-52. [pmid: 6463451].