# Summary Tables

Table D.1 Effectiveness of cochlear implants: summary of general study characteristics

Table D.2 Effectiveness of cochlear implants: summary results of studies with multi-syllable tests

Table D.3 Effectiveness cochlear implants: summary results of studies with open-set sentences tests

Table D.4 Effectiveness cochlear implants: summary results of studies with health-related quality-of-life measures

Table D.5 Discontinuation of device use

Table D.6 Preoperative patient characteristics associated with postimplant improvement in communication and health outcomes: summary of general study characteristics

Table D.7 Preoperative patient characteristics associated with postimplant improvement in communication and health outcomes: summary of study results

Table D.8 Effectiveness of bilateral cochlear implants, sequential and simultaneous: summary of general study characteristics

Table D.9 Effectiveness of bilateral cochlear implants, sequential and simultaneous: summary of study results

Table D.10 Effectiveness of hybrid implant: summary of study results

Table D.11 Adverse events from hybrid implant