# Search Strategy

# | Searches. Cochlear Implant 8-5-10 | Results
1 | exp hearing loss/ | 21068
2 | exp hearing loss, sensorineural/ | 8711
3 | Hearing Loss, Bilateral/ | 751
4 | exp deafness/ | 6961
5 | severe to profound deafness.mp. | 30
6 | (severe adj4 deaf$).mp. | 222
7 | (profound adj4 deaf$).mp. | 405
8 | Hearing Loss, Unilateral.mp. [mp=ti, ot, ab, nm, hw, ui, sh, kw] | 194
9 | exp Hearing Disorders/ | 25838
10 | deaf$.ti,ab. | 11670
11 | or/1-10 | 30915
12 | exp ear, middle/ or exp ear, inner/ | 19780
13 | 11 or 12 | 45309
14 | Cochlear Implants/ | 3141
15 | Cochlear Diseases/ | 383
16 | Cochlear Implantation/ | 2200
17 | (cochlear adj5 implant$).mp. | 5586
18 | (cochlear adj5 device$).mp. | 229
19 | or/14-18 | 5921
20 | 13 and 19 | 4485
21 | limit 20 to yr="2004-Current" | 2363
22 | animals/ not (animals/ and humans/) | 1353004
23 | 21 not 22 | 2214
24 | (meta-analysis or review).pt. | 1020124
25 | 23 not 24 | 1985
26 | limit 25 to "all child (0 to 18 years)" [Limit not valid in CCTR; records were retained] | 1038
27 | 25 not 26 | 947
28 | remove duplicates from 27 | 947

Additional searches in the Scopus database yielded 863 abstracts, which were screened separately from the initial yield of 947 abstracts that were identified through Medline and Cochrane databases

Updated search in March 2011 yielded 9 8 additional citations published between July 2010 through February 2011.

Figure 1 Study Flow

Figure 1 is a diagram depicting the study flow. It summarizes the number of studies searched for and screened, with reasons given for their inclusion and exclusion. A keyword search in Medline, Scopus, and Cochrane Central databases yielded 1810 abstracts. 1595 were excluded after screening for the following reasons: population not of interest, evaluation of surgical techniques, electrode designs evalutation, brain stem implant, reviews or commentaries without primary data. The remaining 215 articles were selected for full-text review. Of these, 174 were exluded for the following reasons: population either mixed pediatric and adult (or not of interest); no intervention or comparator of interest; no outcome of interest; small sample size; article evaluated only techniques; or duplicates, reviews, and commentaries. 41 unique studies were ultimately included in the review.