# Description of abbreviations and relevant terms

Table A 1 Description of abbreviations of speech perception outcomes

Name | Outcome category | Description | Score range
AzBio Sentences | Speech perception in quiet | The AzBio sentences include variable number of sentences (20-40) presented from the multiple-talker (both male and female). The score range from 1 to 100 percent based on the percent of words correctly identified. | 0-100% (Best score: 100)
Bamford-Kowal-Bench (BKB) / BKB-speech in noise (BKB-SIN) sentence test | Speech perception in noise | The BKB Standard Sentence Lists comprise 21 lists, each having 16 sentences and 50 keywords (3 or 4 per sentence). Although designed for testing children, the sentences have also proved useful and appropriate in testing adults. The evaluated studies used variable number of sentence lists. The score range from 1 to 100 percent based on the percent of words correctly identified. The BKB-speech in noise (SIN) presents BKB sentences in high- and low-level sentences to listeners. | 0-100% (Best score: 100)
Central Institute for the Deaf sentences (CID) | Speech perception in quiet or noise | The CID sentences test involves presenting 10 lists of sentences with 50 keywords per list. The score range from 1 to 100 percent based on the percent of keywords correctly identified. | 0-100% (Best score: 100)
Centro de Pesquisas Audiologicas (CPA) sentence recognition test | Speech perception in quiet or noise | The CPA sentences are presented in quiet and in competition with noise. Listeners are scored using sentence recognition index. | Sentence recognition index
City University of New York Sentences (CUNY) | Speech perception in quiet or noise | The CUNY Sentences are topic-related sentences consisting of 6 lists of 12 sentences each. The evaluated studies used variable number of sentence lists. Performance is scored for keywords correct per list. | 0-100% (Best score: 100)
Hearing In Noise Test (HINT) | Speech perception in quiet or noise | The HINT test assesses a listener’s recognition of everyday sentences in quiet and noise. The test involves 25 lists per listening condition; 10 sentences / list and is scored for percent of key words correctly identified. | 0-100% (Best score: 100)
Hochmair-Schulz-Moser (HSM) | Speech perception in quiet or noise | The HSM sentences are presented in quiet and in competition with noise. Listeners are scored based on correctly repeating 50 percent of the sentences. | Poor, medium, and good performers
Multiple-jammers test | Speech perception in quiet or noise | A multiple-jammers test uses the target spondee words and sentences as combinations of randomly selected male and female sentences (jammers) that were presented simultaneously from one of the two speakers placed at two different azimuth. | 0-100% (Best score: 100)
Open-set sentences test | Speech perception in quiet or noise | A speech perception test is considered to be “open-set” if the listener is required to recognize words or sentences without the presence of response alternatives (a free recall response). Listeners must identify what they heard by repeating or writing the words or sentences down. | 0-100% (Best score: 100)
Oldenburg sentence test (OLSA) | Speech perception in noise | The OLSA test consists of 40 lists of 30 sentences each. Each sentence consists of 5 words and is generated by permutations of 50 words. | 0-100% (Best score: 100)
Spondee recognition test | Speech perception in quiet | This is an open-set test in which the subject is asked to repeat each of 25 spondaic words. The spondee words spoken by a female or male talker and presented in a two-talker background. Scored for percent of words correctly identified. | 0-100% (Best score: 100)
Spondees or spondaic words | Speech perception in quiet | Spondee words have two-syllables with emphasis on both of them, for example, “base-ball” and “sidewalk.” Half credit is given when one of the two syllables are correct. | 0-100% (Best score: 100)

Table A 2 Description of abbreviations of health-related quality-of-life outcomes

Name | Outcome category | Description | Score range
Abbreviated Profile of Hearing Aid Benefit (APHAB) | Disease specific health-related quality-of-life | The APHAB consists of four subscales: ease of communication (EC), reverberant listening conditions (RV), background noise (BN), and aversiveness to sounds (AV). | Tied Ranks based on the average score for each subscale
Adapted Deaf Identity Developmental Scale (ADIDS) | Disease specific health-related quality-of-life | The ADIDS is 29-item self-assessment in 5 areas: communication, family climate, social skills, academic and work performance, and general satisfaction. | 1 (Totally disagree) to 6 (Totally agree)
Assessment of Quality of Life (AQoL) | Generic and disease health-related quality-of-life | The AQoL consists of (generic, with 2 questions hearing-specific) with 15-items and is a multi-attribute utility instrument. It comprises of five dimensions self-assessment measuring illness, independent living, social relationships, physical senses, and psychological well-being. | –0.04 (worst) to 0.00 (death) to 1.00 (best)
EuroQol 5 dimensions (EQ-5D) | Generic measure of health-related quality-of-life | The EQ-5D measures 5 dimensions: mobility, self-care, usual activities, pain and discomfort, and anxiety and depression | 0 (death)-1 (full health
Glasgow Benefit Inventory (GBI) | Generic measure of health-related quality-of-life | The Glasgow Benefit Inventory Questionnaire measures psychological, social and emotional aspects of quality-of-life. The GBI is maximally sensitive to a change in health status brought about by the cochlear implant | -100 (maximal worsening) to +100 (maximal improvement)
Glasgow Health Status Inventory (GHSI) | Generic measure of health-related quality-of-life | The Glasgow Health Status Inventory Questionnaire measures effect of a hearing problem on the quality-of-life. Measures overall life, general, physical health, and social support | 0 (worst) – 100 (best)
Hearing Handicap Inventory for Adults | Disease specific health-related quality-of-life | The HHIA is a test of hearing handicap in adult populations. It is 25 items, hearing-specific, quality-of-life scale with two sub-scales (emotional and situational impact of hearing loss) | 0 (best) – 100 (worst with maximum handicap)
Hearing handicap Inventory for the Elderly (HHIE) | Disease-specific health-related quality-of-life | The HHIE comprises 25 item in two subscales, assessing social and emotional handicap. Self-administered using a three point scale (yes, sometimes, no) | Range of scores not documented. Higher scores associated with greater handicap
Hearing Handicap Questionnaire (HHQ) | Disease-specific health-related quality-of-life | The HHQ comprises of 12 item administered questionnaire using a 5 point scale and higher scores indicate greater handicap. The questionnaire has two parts related to emotional distress and social restriction. | Range of scores not documented. Higher scores associated with greater handicap
Hearing Participation Scale (HPS) | Disease-specific health-related quality-of-life | The HPS is a shortened form of the GHSI comprising of 11-item self-assessment measuring self-esteem and level of social interaction related to hearing, and hearing handicap. The scores range between 0 and 1, where a lower score corresponds to profound effects due to hearing loss. | 0.00 (worst) -1.00 (best) (0.00 - low score indicates profound effects due to deafness)
Health Utilities Index 2 (HUI-2) or Health Utilities Index 3 (HUI-3) | Generic measure of health-related quality-of-life | The HUI-2 or HUI-3 establishes the respondent’s level of function with regard to 8 attributes: hearing, vision, the capacity to be understood when speaking, mobility, dexterity, cognition, feelings, and pain. The quality-of-life scores range from 0 to 1, where 0 corresponds to death and 1 corresponds to full health. | 0 (death)-1 (full health)
Index of Self-Esteem | Disease-specific health-related quality-of-life | The Index of Self-Esteem consists of 25 items, which rates how positive a person feels about him or herself. The scores range from 1 to 5, where a higher score corresponds to a higher sense of self-esteem. | 1 (worse) – 5 (higher sense of self-esteem)
Loneliness Scale | Disease-specific health-related quality-of-life | The University of California, Los Angeles (UCLA), Loneliness Scale involves 20-item self-assessment rating how frequently a person experiences the feeling of loneliness described in each question. The Loneliness Scale score ranges from 1 (never) to 4 (frequently or higher sense of loneliness). | 1 (never) -4 (frequently or higher sense of loneliness)
Nijmegen Cochlear Implant Questionnaire (NCIQ) | Disease-specific health-related quality-of-life | The NCIQ is specially developed to evaluate how cochlear implantation affects health status. The general physical domain consists of 3 subdomains (basic and advanced sound perception and speech production) and mainly focuses on communication (referred to as NCIQ communication). The psychological domain (NCIQ psychological) contains mainly self-esteem questions, while the social domain (NCIQ social) addresses activity limitations and social interactions. Each subdomain includes 10 items | 0 (worse) - 100 (best)
Short- Form 36 (SF-36) | Generic measure of health-related quality-of-life | The SF-36 is a multidimensional outcome instrument to measure QOL. It has been designed to prospectively monitor patient outcomes in medical and clinical research settings. It includes 36 items and assesses 8 different health concepts: Physical functioning, role functioning due to physical health or emotional problems, bodily pain, vitality, social functioning, mental health, and general health perceptions | 0 (worse) - 100 (best)
Overall Quality of Life (VAS) | Generic measure of health-related quality-of-life | The VAS is an unconstrained measure by asking participants about their general well-being, enjoyment of life, independence and ability to take care of themselves, ability to take care of others, feeling about themselves, ability to get around and communicate, ability to socialize and get things done at work or at home | 0 (worst) - 100 (best)

Table A 3 Description of sound location and other terms

Name | Description
Azimuth | Azimuth refers to the spatial dimensions of the source of sound that relates to the direction from the listener in the horizontal plane.
Binaural Squelch | Binaural squelch refers to the mechanism by which the auditory system potentially can combine the information from the ears to form a better central representation
Binaural Summation or redundancy | Binaural summation or redundancy can occur when speech and noise originate from the same location. It indicates the auditory system’s ability to combine duplicate signals (from the ears) in the brain.
dB SPL | Decibel (dB): dB = 10*log10(I/Iref), where I refers to sound intensity, p is sound pressure, ref is a referent intensity or pressure, and log10 is the logarithm to the base 10. SPL is a logarithmic measure of the sound pressure relative to a reference value. It is measured in dB above a standard reference level.
Head Shadow effect | The “head shadow effect” refers to the “shadow” or partial blockage of sound created when the head and shoulders are interposed between a sound source and the opposite sided implant (or hearing ear). The reduction of speech perception by the “head shadow effect” is amplified in the presence of background noise.
Hertz (Hz) | Hertz is the measure of vibratory frequency in which “n” cycles per second of periodic oscillation is “n” Hz.
Signal-to-Noise Ratio (SNR) | The objective is to find the SNR (also known as signal-to-babble ratio) needed for the subject to correctly repeat 50 percent of the items on the speech test presented against a background of noise or speech babble. For example, the background noise is presented at a fixed level of 60 or 70 dB HL and then the level of the sentences are raised or lowered until the level where the subject correctly repeats 50 percent of the items. A lower SNR indicates better speech perception in noise, and a higher SNR means poorer speech perception in noise.
Sound Localization | When sound is presented in the horizontal plane (at ear level), subjects with normal hearing are able to tell where sound is coming from with an accuracy of ±14 degrees. The brain uses differences in intensity and time between the two ears to locate a sound source. To localize sound in a vertical plane (up and down), or when time and intensity cues between the two ears are ambiguous, spectral (pitch) information is important.
Speech recognition threshold (SRT) | The speech recognition threshold (SRT): The SRT is the minimum hearing level of a speech signal at which a listener correctly repeats 50 percent of the spoken message