# 41 Electronic Health Record Adoption and Interoperability among U.S. Skilled Nursing Facilities and Home Health Agencies in 2017

Interoperability has the potential to improve transitions of care between acute-care and post-acute care facilities; such as skilled nursing facilities (SNFs) and home health agencies (HHAs) (1). Poor communication and coordination during these transitions may lead to adverse events including readmissions and medication errors. Federal policies aim to advance interoperability in post-acute care settings. The Improving Medicare Post-Acute Care Transformation Act (IMPACT Act) of 2014, for example, requires assessment data to be standardized and interoperable to allow for the exchange of data among post-acute care providers and other providers (2,3). This brief describes the state of health IT use among HHAs and SNFs in 2017. Specifically, it presents key measures on electronic health record (EHR) adoption and interoperability from nationally representative surveys of SNFs and HHAs. The data brief also describes variation in interoperability by method of electronic exchange and examines the extent to which these facilities have information electronically available at the point of care. Finally, this data brief reports on the use of mobile and telehealth technologies among HHAs.

HIGHLIGHTS

▶ More HHAs (78 percent) adopted EHRs than SNFs (66 percent) in 2017.
▶ The ability to integrate patient health information received from outside facilities lagged behind for both HHAs (36 percent) and SNFs (18 percent) compared to these facilities’ engagement in other domains of interoperability.
▶ HHAs (32 percent) and SNFs (37 percent) most commonly used their EHR to exchange health information.
▶ HHAs and SNFs that use three methods of exchange are more likely to have information electronically available.
▶ Nearly 40 percent of HHAs used telehealth technology to keep track of patients’ health between in-person visits.

## EHR adoption rates were higher among HHAs compared to SNFs

Figure 1 Percent of HHA and SNFs that used an EHR, 2017

Notes: * Difference is statistically significant at p<0.05.

SOURCE: 2017 IQVIA Nursing Home, n=1,000 and 2017 IQVIA Home Health Agency, n=1,004. See Definitions for EHR description.

★ In 2017, over three-quarters of HHAs and two-thirds of SNFs reported they had adopted EHRs.

## Among facilities with an EHR, a majority of HHAs and SNFs used their EHR for medication management purposes

Figure 2 Percent of SNFs and HHAs with an EHR that used medication management functions, 2017

Notes: * Difference is statistically significant at p<0.05. The denominator includes HHAs and SNFs that adopted an EHR.

SOURCE: 2017 IQVIA Nursing Home, n=1,000 and 2017 IQVIA Home Health Agency, n=1,004.

★ HHAs had higher rates of recording and reconciling patient medications using an EHR compared to SNFs.
★ Almost all HHAs used their EHRs to record patient medications and reconcile medications.
★ Almost 9 out of 10 SNFs with an EHR recorded patient medications using an EHR.

## HHAs are more likely than SNFs to engage in each domain of interoperability

Figure 3 Percent of SNFs and HHAs with an EHR that reported having the ability to electronically send, receive, find, and integrate patient health information, and have outside information available, 2017

Notes: * Difference is statistically significant at p<0.05.

SOURCE: 2017 IQVIA Nursing Home, n=1,000 and 2017 IQVIA Home Health Agency, n=1,004 Census.

★ About half of HHAs engaged in electronically sending or receiving patient health information from outside providers; compared to four out of 10 SNFs.
★ Integration of received information lagged behind other interoperability domains for both HHAs and SNFs.
★ More HHAs (41 percent) had the ability to find patient’s health information from outside facilities than SNFs (27 percent).
★ HHAs were twice as likely to integrate patient health information than SNFs.
★ Nearly half of HHAs (55 percent) and SNFs (48 percent) had information available from outside providers at the point of care.

## About one-third of HHAs and SNFs relied on EHRs alone to electronically exchange patient health information

Table 1 Percent of HHAs and SNFs that used different methods of electronic exchange (EHR alone, health information organization (HIO), and read only access, 2017

Methods of Exchange | HHA | SNF
EHR alone | 32% | 37%
EHR and HIO and Read-only access | 20% | 8%^*^
EHR and Read only access | 19% | 17%^*^
No EHR, HIO, or Read-only access | 23% | 32%^*^
EHR and HIO | 4% | 4%
HIO alone | 1% | 1%
Read-only access alone | 1% | 1%
HIO and Read-only Access | 0% | 0%

SOURCE: 2017 IQVIA Nursing Home, n=1,000 and 2017 IQVIA Home Health Agency, n=1,004.

Notes:

* Difference is statistically significant between HHAs and SNFs at p<0.05. Read Only is defined as a permission to access files or directories where the user is only allowed to read, not make changes.

★ About 43 percent of HHAs and 29 percent of SNFs used more than one method for electronic exchange.
★ Nearly one-third of SNFs did not use an EHR, HIO, or read-only access to an EHR for electronic exchange of patient health information.
★ A greater proportion of HHAs (20 percent) used all three methods of electronic exchange (EHR and HIO and read-only access) than SNFs (eight percent).
★ Nearly one-fifth of HHAs (19 percent) and SNFs (17 percent) exchanged data using an EHR and read-only access.
★ Neither HHAs nor SNFs used both HIO and read-only access for electronic exchange.

## SNFs that used EHRs, HIOs, and read-only access were twice as likely to have clinical information from outside organizations electronically available than SNFs that only used an EHR

Table 2 Interoperability domains (send, receive, find, integrate) by methods of exchange for HHAs and SNFs

Method used to exchange | Facility Type | Find/Query | Send | Receive | Integrate | Outside Information Available
EHR alone | HHA | 19% | 51% | 50% | 32% | 62%
EHR alone | SNF | 24% | 44% | 42% | 18% | 32%
EHR and Read-only Access | HHA | 55% | 67% | 70% | 58% | 67%
EHR and Read-only Access | SNF | 51% | 56% | 56% | 32% | 41%
EHR and HIO and Read-only Access | HHA | 94% | 76% | 83% | 60% | 76%
EHR and HIO and Read-only Access | SNF | 74% | 82% | 81% | 46% | 68%

SOURCE: 2017 IQVIA Nursing Home, n=1,000 and 2017 IQVIA Home Health Agency, n=1,004.

★ Among HHAs that use an EHR, HIO, and read-only access, almost all facilities (94 percent) had the ability to query for patients’ health information from outside facilities.
★ Using EHR, HIO, and read-only access enabled eight out 10 SNFs to routinely send and receive information with outside organizations.
★ HHAs using all three methods of electronic exchange had higher rates of reporting electronic availability of patient health information at the point of care compared to those that used only an EHR.

## Almost three out of four HHAs used mobile technology during patient visits

Figure 4 Use of mobile technology (e.g., laptops, tablets and smartphones) during patient visit

Notes: Denominator of Mobile Technology Data Entry is among those who reported “Yes” to whether they use mobile technology.

SOURCE: 2017 IQVIA Home Health Agency, n=1,004.

★ Among HHAs that use mobile technology during visits, most (85 percent) used devices to enter information directly into their EHR system.

## About 4 out of 10 HHAs used telehealth technology to keep track of patients' health between in-person visits

Figure 5 Rates of telehealth technology use among HHAs by ownership type and location (rural vs. urban)

Notes: Telehealth includes video conferencing or remote patient monitoring devices that collect data such as vital signs or blood sugar levels and transmit the data back to the agency. *Difference is statistically significant at p<0.05.

SOURCE: 2017 IQVIA Home Health Agency, n=1,004.

★ The use of telehealth technology does not vary by HHAs’ ownership status and location- almost 40 percent of HHAs used telehealth for tracking patients’ health across each of these categories.

## Summary

The nation’s aging population is projected to grow by 80 percent in the next 25 years (4). As a result, interoperability will be important to ensure care coordination between acute care, post-acute care and other providers of care. A majority of SNFs and HHAs have adopted EHRs. However, EHR adoption rates were higher among HHAs than SNFs. Among HHAs with an EHR, a majority used their EHRs for both reconciling and recording medications. HHAs were also more likely to engage in the use of these functions compared to SNFs.

HHAs and SNFs differed in their rates of engaging in the four interoperability domains: sending, receiving, finding, and integrating health information received from outside sources. HHAs are more likely, than SNFs, to engage in each domain of interoperability. Over half of HHA electronically sent or received health information; compared to 41 percent of SNFs. However, both HHAs and SNFs had lower rates of electronically finding and integrating patient health data. Only 18 percent of SNFs report that they integrate patient health information electronically received from outside sources. Like HHAs and SNFs, hospitals have a similar pattern related to interoperability; while a large proportion are electronically sending and receiving health information fewer possess the capability to electronically find or integrate data from outside sources.

Having patient health information electronically available from outside sources varied by the methods HHAs and SNFs used to exchange information. An EHR was the most common method used to exchange information for both facility types. Yet, at least 43 percent of HHAs and 29 percent of SNFs used more than one method for electronic exchange of health information. Facilities that used multiple methods of electronic exchange, were more likely to engage in the four interoperability domains. These facilities were also more likely to have information electronically available at the point of care. For example, SNFs that use an EHR, HIO, and read-only access are twice as likely to have information available at the point of care; compared to SNFs that use an EHR alone. Although using multiple methods increases the availability of information, it also may increase the complexity and cost of of data exchange.

HHAs need to use technology during in home patient visits and to monitor patients between visits. Three-fourths of HHAs (72 percent) used mobile technology. Among HHAs that used this technology, 85 percent used it during patient visits to directly enter data into their EHR. About four in 10 HHAs (37 percent) used telehealth. There was no variation in the use of telehealth technology by HHAs ownership status (private vs. not) or location (urban vs. rural).

Unlike hospitals and office-based physicians, SNFs and HHAs are not eligible to participate in the Medicare and Medicaid Promoting Interoperability Programs, formerly known as the Medicare and Medicaid EHR Incentive Programs (5, 6). However, implementation of federal policies, like the IMPACT Act, and the availability of interoperability standards for standardized patient assessment data through resources such as the CMS Data Element Library ^1^ provide important building blocks to advancing health information exchange. Policies that advance interoperability in the post-acute care settings, are critical to ensuring that HHAs and SNFs are able to meet future demand for services and the complex health needs of their patient population.

## Definitions

Electronic Health Record (EHR): An Electronic Health Record (EHR) is an electronic version of a patient’s medical history that is maintained by the provider over time, and may include all of the key clinical data relevant to that person's care under a particular provider, including demographics, progress notes, problems, medications, vital signs, past medical history, immunizations, laboratory data and radiology reports.
Health Information Organization (HIO): A group of organizations within a specific geographic (state or regional) area that share health care-related information, often via health information exchanges, according to accepted health care information technology standards.
Interoperability: The ability of a system to exchange electronic health information with and use electronic health information from other systems without special effort on the part of the user. This brief further specifies interoperability as the ability for health systems to electronically send, receive, find, and integrate or use health information with other electronic systems outside their organization.
Skilled Nursing Facility (SNF): Survey respondents that self-identified as a skilled nursing facility. Skilled nursing facilities traditionally provide short-term, sub-acute care for persons recuperating from a hospitalization or an acute condition. See Data Source and Methods section for more detail on sample of nursing homes.
Home Health Agency (HHA): Organizations that provide home-based healthcare services to patients with a medical illness, chronic medical condition or a disability.
Mobile technology: tablets, smartphones, etc.

## Data Source and Methods

The data presented in this brief are from the private company, IQVIA (formerly QuintilesIMS/ SK&A). IQVIA is a provider of U.S. healthcare reference information including EHR adoption. In collaboration with ONC, IQVIA fielded a 10 question telephone survey between September and November of 2017. Refer to the appendix for the subset of questions asked in the survey and presented in this brief.

Over one thousand facilities rendering LTPAC services were surveyed. Of the facilities surveyed, 1,000 self-identified as a SNF and 1,004 HHA.

Significant differences noted throughout the data brief were tested using p < 0.05 as the threshold.

## References

1 Patel V., Pylypchuk Y., Henry J., & Searcy T. (July 2016) Variation in Interoperability among U.S. Non-federal Acute Care Hospitals in 2015. ONC Data Brief, no.37. Office of the National Coordinator for Health Information Technology: Washington DC.
2 IMPROVING MEDICARE POST-ACUTE CARE TRANSFORMATION ACT OF 2014 - IMPACT Act of 2014 - Public Law 113–185 - 113th Congress (2013–2014) https://www.congress.gov/bill/113th-congress/house-bill/4994/text.
3 IMPACT Act: Connecting Post-Acute Care across the Care Continuum. Centers for Medicare & Medicaid. Available: https://www.cms.gov/Outreach-and-Education/Outreach/NPC/National-Provider-Calls-and-Events-Items/2016-02-04-IMPACT-Act.html.
4 States Census. (2018) Older People Projected to Outnumber Children for First Time in U.S. History. https://www.census.gov/newsroom/press-releases/2018/cb18-41-population-projections.html.
5 Office of the National Coordinator for Health Information Technology. 'Percent of Hospitals, By Type, that Possess Certified Health IT,' Health IT Quick-Stat #52. dashboard.healthit.gov/quickstats/pages/certified-electronic-health-record-technology-in-hospitals.php. May 2016.
6 Office of the National Coordinator for Health Information Technology. 'Office-based Physician Electronic Health Record Adoption,' Health IT Quick-Stat #50. dashboard.healthit.gov/quickstats/pages/physician-ehr-adoption-trends.php. December 2016.

## Acknowledgements

The authors are with the Office of the National Coordinator for Health Information Technology (ONC). The data brief was completed under the direction of Steve Posnack, Director of the Office of Technology and Talisha Searcy, Data Analysis Branch Chief for the Office of Technology. Other staff that contributed to this document include Elizabeth Palena-Hall from the Office of Policy at ONC.

## Appendix

Appendix 1 Survey questions assessing EHR adoption and interoperability among skilled nursing facilities and home health agencies

| Question Text | Response Options
SNF | Not including for accounting or billing purposes, does your facility currently use an EHR to manage your patients’ health records? | Yes \| No \| Don’t Know
HHA | Not including for accounting or billing purposes, does your home health agency currently use an electronic health record to manage your patients’ health records? | Yes \| No \| Don’t Know
SNF | Do staff at your skilled nursing facility electronically send key clinical information such as labs, medications or problem lists to outside organizations on a routine basis? Electronic does not include fax, e-fax or MDS (minimum data set) quality reporting. | Yes \| No \| Don’t Know
HHA | Does your agency electronically send key clinical information such as labs, medications, or problem lists to outside organizations on a routine basis? Electronic does not include fax, e-fax, or OASIS quality reporting. | Yes \| No \| Don’t Know
SNF | Do staff at your skilled nursing facility electronically receive key clinical information such as labs medications or problem lists from outside organizations on a routine basis? (Electronic does not include fax, e-fax or MDS (minimum data set) quality reporting. | Yes \| No \| Don’t Know
HHA | Does your agency electronically receive key clinical information such as labs, medications, or problem lists from outside organizations on a routine basis? Electronic does not include fax, e-fax, or OASIS quality reporting | Yes \| No \| Don’t Know
SNF | Do staff at your skilled nursing facility electronically easily integrate patient health information that you electronically receive into your EHR without manual entry or scanning? | Yes \| No \| Don’t Know
HHA | Is the electronically received information easily incorporated or integrated into your EHR without manual entry or scanning? | Yes \| No \| Don’t Know
SNF | Do staff at your skilled nursing facility electronically search or query for your patients’ health information from sources outside your facility? This might include through a web portal, remote access to another facility or health information exchange organization, for example. | Yes \| No \| Don’t Know
HHA | Does your staff electronically search or query for your patients’ health information from facilities outside of your home health agency? This might include through a web portal, remote access to another facility, health information exchange organization, or through your EHR vendor’s network | Yes \| No \| Don’t Know
SNF | Does your skilled nursing facility use a state or regional health information exchange organization (HIO) to electronically send, receive, integrate or search for patient health information from outside sources? | Yes \| No \| Don’t Know
HHA | Does your home health agency use a regional, state or local health information exchange organization (HIO) to electronically send, receive, or search for patient health information from a variety of providers or other organizations outside your organization? A Health Information Exchange Organization (HIO is a state, regional or local organization that oversees and governs the electronic sharing of health-related information among organizations. It does not refer to a private, closed network. | Yes \| No \| Don’t Know
SNF | When treating patients seen by other providers outside your skilled nursing facility, how often does your staff have clinical information from outside encounters electronically available at the point of care? Electronically available does not include scanned or PDF documents. Is it often, sometimes, rarely or never? | Often \| Sometimes \| Rarely \| Never \| Do Not Know
HHA | When treating patients previously seen by other providers outside your home health agency, how often do staff have clinical information from those outside encounters electronically available at the point of care? | Often \| Sometimes \| Rarely \| Never \| Do Not Know
HHA | Do staff at your home health agency use an EHR system to record patients’ medications? | Yes \| No \| Don’t Know
SNF | Do staff at your skilled nursing facility use an EHR system to record patients’ medications? | Yes \| No \| Don’t Know
HHA | Do staff at your home health agency use an EHR system to reconcile medications? | Yes \| No \| Don’t Know
SNF | Does your skilled nursing facility use an EHR system to reconcile lists of patient medications to identify the most accurate list? | Yes \| No \| Don’t Know
HHA | Do [underlined: other] facilities provide [underlined: your] home health agency with electronic, “read only” access to [underlined: their] EHR systems? This means that your staff have the ability to view patient health information in a third party’s EHR but not modify the record. | Yes \| No \| Don’t Know
SNF | Do external organization(s) provide your skilled nursing facility with electronic, “read only” access to clinical information within their EHR systems? This means that appropriate staff have the ability to view patient health information in a third party’s EHR but not modify the record. | Yes \| No \| Don’t Know
HHA | Does your staff use telehealth technology to keep track of patients’ health (such as vital signs, mobility or pain) between in-person visits? Telehealth includes video conferencing or remote patient monitoring devices that collect data such as vital signs or blood sugar levels and transmit the data back to the agency. | Yes \| No \| Don’t Know
HHA | Does your staff use mobile technology, such as laptops, tablets and smartphones, during patient visits? | Yes \| No \| Don’t Know
HHA | Do staff directly enter information into your agency’s EHR system using mobile technology (such as laptop, tablet or smartphone)? | Yes \| No \| Don’t Know

1 CMS Data Element Library (https://del.cms.gov/)