# 34 Disparities in Individuals’ Access and Use of Health Information Technology in 2014

Findings from nationally representative surveys show that individuals’ use of information technology (IT) for health needs increased significantly between 2013 and 2014 (1). The percentage of individuals offered online access to their medical record also grew by over one-third to nearly 4 in 10 individuals in 2014 (2). Prior analysis revealed that disparities in online access of medical records and use of IT for health-related needs existed by certain sociodemographic characteristics and geographic settings in 2013 (3). This data brief examines 2014 data to identify disparities in online access to medical records and use of IT for health needs.

## Individuals whose provider had an EHR were offered online access to their medical record at three times the rate of those whose provider does not.

Figure 1 Percent of individuals who have been offered access to an online medical record and use certain types of IT for health related needs by whether or not the individual’s provider has an EHR, 2014

NOTE: *Significant differences among individuals whose provider has versus does not have an EHR ( p<0.05), comparisons within same year.

Bar chart showing percent of individuals offered access to online medical records. *denotes significantly difference from reference category (p< 05) In 2013 38%* of Individuals whose provider has an EHR were offered access to an online medical record by a healthcare provider or insurer, in 2014 this increased to 48%*. In 2013 13% of individuals whose providers did not have an EHR were offered access to an online medical record by a healthcare provider or insurer, in 2014 this increased to 15%, In 2013 30%* of individuals whose provider has an EHR had "ever emailed their provider," in 2014 this increased to 40%.* In 2013 9% of individuals whose provider does not have an EHR had "ever emailed their provider," in 2014 this increased to 10%. In 2013 29%* of individuals whose provider has an EHR had ever looked at their test results online, in 2014 this increased to 29%*. In 2013 6% of individuals whose provider did not have an EHR had ever looked at their test results online, in 2014 this increased to 9%. In 2013 17%* of individuals whose provider has an EHR had ever used a smart phone health app, in 2014 this increased to 22%*. In 2013 5% whose provider did not have an EHR had ever used a smart phone health app, in 2014 this increased to 9%.

SOURCE: 2013–2014 Consumer Survey of Attitudes Toward the Privacy and Security Aspects of Electronic Health Records and Health Information Exchange.

★ In 2014, individuals whose provider had an EHR had significantly higher rates of using IT for health needs compared to individuals whose provider did not have an EHR.
★ The percent of individuals offered access to online medical records, emailing providers, and looking up test results online increased between 2013 and 2014; however, the rate of increase was greater among those whose provider had an EHR.

## Individuals with lower incomes and less education had significantly lower rates of being offered online access to their health information.

Figure 2 Percentage of individuals offered online access to a medical record by a health insurer or health care provider by annual household income and education, 2014

NOTE: *Significantly different from reference category (p<0.05). No significant differences were found by age, setting (e.g., rural vs. urban), chronic health condition, or disability. See Appendix Table 1 for variation in being offered online access to medical record.

A bar chart showing the percent of individuals offered online access to a medical record by a health insurer or provider in 2014. Overall 38% of individuals nationwide have been offered online access. *denotes significantly difference from reference category (p< 05) Annual Income: 53%* of individuals with an annual income of $100,000 or greater were offered access. 45%* of individuals with an annual income of $50,000 to $99,999 were offered access. 36% of individuals with an annual income of $25,000 to $49,999 were offered access. 27% of individuals with an annual income of less than $25,000 (Reference) were access. Education 52% of individuals with more than 4-year college degrees (Reference) were offered access. 49% of 4-year college graduates were offered access. 37%* with Some college or a 2-year degree were offered access. 26%* of High School Graduates or with a GED were offered access. 19%* of those Individual who did not graduate High School were offered access.

SOURCE: 2014 Consumer Survey of Attitudes Toward the Privacy and Security Aspects of Electronic Health Records and Health Information Exchange

★ While about half of individuals with incomes of $100,000 or more were offered online access to their health information, only about one-quarter of individuals with less than a $25,000 annual income were offered online access.
★ Individuals with more than a four year college degree were offered online access at about twice the rate as individuals who had a high school degree or less.

## Individuals who had difficulty speaking English were offered online access to their medical records at significantly lower rates.

Figure 3 Percentage of individuals who were offered online access to their medical record by a health insurer or health care provider by language and race/ethnicity, 2014.

NOTE: *Significantly different from reference category (p<.05). See Appendix Table 1 for variation in being offered online access to medical record.

Bar chart showing the percent of individuals offered online access to their medical record by a health insurer or provider in 2014. Overall 38% of individuals nationwide were offered access. *denotes significantly difference from reference category (p< 05) Group 1: 40% of individuals who took the survey in English (reference) were offered access. 11%* of individuals who took the survey in Spanish were offered access. Group 2: 39% of individuals who Speak English Very well or Well (Reference) were offered access 15%* of those who Speak English: No well were offered access 5%* of thos who Speak English Not at all were offered access Group 3 43% of Non-Hispanic White individuals were offered access 35% of Non-Hispanic, Black individuals were offered access 34% of Non-Hispanic, Other and Multi-Race Individuals were offered access 31% of Non-Hispanic, Asian Individuals were offered access 22%* Hispanic Individuals were offered access.

SOURCE: 2014 Consumer Survey of Attitudes Toward the Privacy and Security Aspects of Electronic Health Records and Health Information Exchange

★ While 39% of individuals who spoke English very well or well were offered online access to their medical record, only 15% of individuals who didn’t speak English well and only 5% of those who didn’t speak English at all were offered online access to their medical record.
★ Forty percent of individuals who took the survey in English were offered online access to their medical record compared to 11% of individuals who took the survey in Spanish.
★ Almost twice as many white, non-Hispanic individuals were offered online access to their medical record as compared to Hispanic individuals.

## Among individuals offered online access to their medical record, those with higher incomes and more education were more likely to view their record.

Figure 4 Among individuals who were offered online access to their medical record by a health care provider or health insurer, the percentage who viewed their online medical record at least once within the last year by annual household income and education, 2014.

Notes: *Significantly different compared to reference category (p<0.001). No significant differences were found by demographic characteristics (e.g., age, gender), race, language, setting (e.g., rural vs. urban), chronic health condition, or disability. See Appendix Table 1 for variation in rates of viewing online medical record.

Bar chart showing the percentage of individuals who viewed their medical record at least once in the last year, among those who were offered online access to their medical record by a health care provider or insurer. *denotes significantly difference from reference category (p< 05) Annual Income 66%* of individuals with an income of $100,000 or greater had accessed their medical records at least once in the last year. 60% of individuals with income between $50,000 and $99,999 had accessed their medical records at least once in the last year. 53% of individuals with income between $25,000 and $49,999 had accessed their medical records at least once in the last year. 36% of individuals with income less than $25,000 (reference) had accessed their medical records at least once in the last year. Education 68% of individuals with more than 4-Year college degree (reference) had accessed their medical records at least once in the last year. 61% of individuals with 4-year degrees had accessed their medical records at least once in the last year. 54% of individuals with some college or 2-year degrees had accessed their medical records at least once in the last year. 35%* of individuals who graduated High School or had a GED had accessed their medical records at least once in the last year. 26%* of individuals who had not graduated high school had accessed their medical records at least once in the last year.

SOURCE: 2014 Consumer Survey of Attitudes Toward the Privacy and Security Aspects of Electronic Health Records and Health Information Exchange

★ Individuals with annual incomes of at least $50,000 had significantly higher rates of viewing their online medical record compared to individuals with incomes less than $25,000.
★ While almost two-thirds of individuals with annual incomes higher than $100,000 viewed their online medical record at least once within the past year, only about one-third of individuals with incomes less than $25,000 viewed their record within the past year.
★ Individuals with a high school degree or less had significantly lower rates of viewing their online medical record compared to individuals with more than a four-year college degree.
★ Individuals with a four-year college degree or more education were over twice as likely to view their online medical record compared to those without a high school degree.

## Individuals with more education and higher income use certain types of IT for health-related needs at significantly higher rates

Figure 5 Percentage of individuals who have ever used certain types of IT for health-related needs by various characteristics (significant differences shaded dark).

NOTE: Significant differences among respondent categories reflect unadjusted comparisons to reference category, indicated by parentheses ( ). See Appendix Table 2 for values. Measurement of disability is based upon a composite measure (see Definitions).

See Appendix Table 2 for data. This bar chart shows the percent of individuals who have ever used certain types for IT health needs. 31% of individuals overall emailed their health care provider; 22% looked at test results online, 18% test messaged their health care provider; and 17% used a smartphone/ mobile health application. Agewise, significantly more individuals in age groups under 60, had used a smartphone/ mobile health application. Individuals in the 50 to 59 year group were significantly more likely to have used certain IT for health related needs in all 4 IT types tracked. In all 4 IT types, the use of IT for these health needs declined as educational and income levels declined did . Significantly fewer Hispanics and those who took the survey in Spanish emailed their health care provider or looked at their test results online. Rural residents were significantly less likely to email their health provider, look at their tests online or use a smartphone/ mobile health application. Blacks were significantly less likely to use a smartphone/ mobile health application. Significantly more individuals who were not disabled had e-mailed their health care provider and used a smartphone/ mobile health application.

SOURCE: 2014 Consumer Survey of Attitudes Toward the Privacy and Security Aspects of Electronic Health Records and Health Information Exchange

★ Individuals 50–59 years of age had significantly higher rates of text-messaging and emailing their provider, looking up online test results, and using a mobile health application compared to individuals 70 years or older.
★ Individuals with no disabilities had significantly higher rates of emailing their provider and using a mobile health application than individuals with a disability.
★ Individuals residing in rural areas have significantly lower rates of emailing their provider, looking up test results online and using a smart phone health application compared to individuals residing in suburban settings.

## Summary

Although rates of individuals offered online access and use of certain types of information technology grew significantly between 2013 and 2014, disparities remain. This data brief’s findings suggest that individuals’ access to their online medical record and their use of IT to address their health care needs varies significantly across socio-demographic characteristics and by geographic setting in 2014.

Individuals with less income or education had lower rates of access to and use of their online medical record. These individuals also had lower rates of using certain types of IT to address their health care needs, such as emailing or text messaging their health care provider and using a smart phone health application.

Findings from this data brief also suggest that language barriers may impede access to online medical records and use of health IT. Individuals who did not speak English well or took the survey in Spanish were significantly less likely to be offered access to their online medical record. Individuals who took the survey in Spanish also had significantly lower rates of emailing their health care provider or looking up test results online.

There were no differences in rates of access to or the viewing of an online medical record by age. However, individuals 50 to 59 years of age had significantly higher rates of emailing or text-messaging health care providers, looking up test results online, and using smartphone health applications compared to individuals 70 years or older.

Individuals’ electronic access their personal health information and use of IT for health differed by whether their provider had an EHR. In both 2013 and 2014, individuals whose health care providers used EHRs had significantly higher rates of being offered online access to their medical record and using IT for health-related needs compared to those who did not. Hospitals’ and physicians’ adoption of computerized functionality to support individuals’ online access to medical records also grew significantly over this same time period, and this may be reflected in the consumer data (4,5). Increased use of these online capabilities by providers may also drive increased use by consumers.

ONC intends to continue monitoring patient access to their electronic health information. ONC is collaborating with the National Cancer Institute and the National Partnership for Women and Families on future rounds of Health Information National Trends Survey, a nationally representative survey of individuals to monitor health IT access and use (6). This will allow ONC to continue examining variation in health IT access and use to identify disparities and factors that enable greater access and use of health IT.

## Definitions

Online medical record: The survey defined this as: “Some patients can access information from their medical records online—that is, through the Internet—on secure websites set up for this purpose. By going to the secure website, patients can view parts of their own medical record, download the information, or send it somewhere else.”
Disability: Individuals who responded “yes” to one or more of the following items:
  - Are you deaf or do you have serious difficulty hearing?
  - Are you blind or do you have serious difficulty seeing, even when wearing glasses?
  - Because of a physical, mental, or emotional condition, do you have serious difficulty concentrating, remembering, or making decisions?

## Data Source and Methods

Data are from The Office of the National Coordinator for Health Information Technology’s (ONC) Consumer Survey of Attitudes Toward the Privacy and Security Aspects of Electronic Health Records and Health Information Exchange. The survey was conducted by NORC at the University of Chicago with MITRE.

The respondent universe for the survey was the civilian, non-institutionalized population ages 18 years old and older within the 50 states and the District of Columbia. This survey utilized a dual random digit dialing (RDD) frame of landline phone numbers and wireless/mobile phone numbers developed by Survey Sampling International (SSI). In order to reduce sampling variability and to represent the nation, NORC stratified the landline RDD frame by Census Region. The 2013 survey oversampled Hispanic, Asian and Black populations, and the 2012 and 2014 oversampled for Hispanic and Black populations. A total of 2,123 were completed in 2014; 2,107 surveys were completed in 2013; and 2,050 surveys were completed in 2012. Data presented in this data brief are weighted national estimates. Bivariate, unadjusted analyses were conducted across groups.

New survey data will not be available in 2015. ONC is collaborating with the National Cancer Institute on future rounds of their nationally representative Health Information Trends Survey to monitor health IT access and use. For more information regarding HINTS please go to http://hints.cancer.gov/about.aspx.

Appendix Table 1 Rates of Access and Use of Online Medical Records by Select Characteristics, 2014 (^†^ items in bolded italic green font are significantly different from reference category, p<0.05)

Category | Offered electronic access to your health information by health insurer/provider | Viewed medical record at least once within last year (among those who were offered access)
National Estimate | 38% | 55%
Demographics
Sex
*Male | 32% | 53%
Female | 43% ^†^ | 56%
Age
18 to 29 years | 34% | 58%
30 to 39 years | 43% | 57%
40 to 49 years | 40% | 57%
50 to 59 years | 39% | 62%
60 to 69 years | 40% | 48%
*70 years or older | 34% | 40%
Race/Ethnicity/Hispanic Origin
Hispanic | 22% ^†^ | 54%
Non-Hispanic, Asian | 31% | 84%
Non-Hispanic, Black | 35% | 61%
*Non-Hispanic, White | 43% | 53%
Non-Hispanic, Others and Multi-Race | 34% | 34%
Education
Not A High School Graduate | 19% ^†^ | 26% ^†^
High School Graduate Or GED | 26% ^†^ | 35% ^†^
Some College Or 2-Year Degree | 37% ^†^ | 54%
4-Year College Graduate | 49% | 61%
*More Than 4-Year College Degree | 52% | 68%
Income
*Less than $25,000 | 27% | 36%
Between $25,000 and $49,999 | 36% | 53%
Between $50,000 and $99,999 | 45% ^†^ | 60% ^†^
$100,000 or greater | 53% ^†^ | 66% ^†^
Language
*Speak English: Very well or Well | 39% | 56%
Speak English: Not well | 15% ^†^ | 14%
Speak English: Not at all | 5% ^†^ | 0%
*Took survey in English | 40% | 55%
Took survey in Spanish | 11% ^†^ | 35%
Setting (rural, urban, etc.)
Urban | 41% | 61%
*Suburban | 39% | 54%
Rural | 30% | 48%
Health and Functional Status
Disability Composite
*Yes to any disability | 38% | 52%
No to all disabilities | 38% | 56%
Chronic health condition
*Yes | 39% | 49%
No | 37% | 59%

Notes: Weighted Percentages.

* Denotes reference category.

† items in bolded italic green font are significantly different from reference category, p<0.05

SOURCE: 2014 Consumer Survey of Attitudes Toward the Privacy and Security Aspects of Electronic Health Records and Health Information Exchange

Appendix Table 2 Individuals’ Use of Certain Types of IT for Health-Related Needs by Selected Characteristics, 2014. (^†^ items in bolded italic green font are significantly different from reference category, p<0.05)

Category | Looked at test results online | Emailed Provider | Text messaged provider | Used smart phone health app
National Estimate | 22% | 31% | 18% | 17%
Demographics
Sex
*Male | 19% | 31% | 17% | 16%
Female | 24% | 31% | 18% | 18%
Age
18 to 29 years | 20% | 27% | 16% | 19% ^†^
30 to 39 years | 24% | 35% ^†^ | 16% | 20% ^†^
40 to 49 years | 22% | 32% | 21% ^†^ | 24% ^†^
50 to 59 years | 27% ^†^ | 35% ^†^ | 25% ^†^ | 21% ^†^
60 to 69 years | 21% | 32% ^†^ | 15% | 12% ^†^
*70 years or older | 14% | 22% | 10% | 3%
Race/Ethnicity/Hispanic Origin
Hispanic | 13% ^†^ | 22% ^†^ | 18% | 18%
Non-Hispanic, Asian | 22% | 27% | 22% | 20%
Non-Hispanic, Black | 20% | 24% | 14% | 8% ^†^
*Non-Hispanic, White | 24% | 34% | 18% | 19%
Non-Hispanic, Others and Multi-Race | 11% | 31% | 20% | 18%
Education
Not A High School Graduate | 5% ^†^ | 8% ^†^ | 7% ^†^ | 10% ^†^
High School Graduate Or GED | 9% ^†^ | 18% ^†^ | 15% ^†^ | 8% ^†^
Some College Or 2-Year Degree | 20% ^†^ | 28% ^†^ | 17% ^†^ | 13% ^†^
4-Year College Graduate | 30% | 39% ^†^ | 18% ^†^ | 26%
*More Than 4-Year College Degree | 40% | 54% | 30% | 29%
Income
*Less than $25,000 | 7% | 12% | 8% | 11%
Between $25,000 and $49,999 | 19% ^†^ | 27% ^†^ | 20% ^†^ | 13% ^†^
Between $50,000 and $99,999 | 29% ^†^ | 42% ^†^ | 22% ^†^ | 22% ^†^
$100,000 or greater | 42% ^†^ | 54% ^†^ | 26% ^†^ | 35% ^†^
Language
*Speak English: Very well or Well | 23% | 32% | 18% | 18%
Speak English: Not well | 4% ^†^ | 9% ^†^ | 10% | 12%
Speak English: Not at all | 0% | 0% | 0% | 12%
*Took survey in English | 23% | 32% | 18% | 18%
Took survey in Spanish | 6% ^†^ | 8% ^†^ | 14% | 13%
Setting (rural, urban, etc.)
Urban | 26% | 35% | 16% | 21%
*Suburban | 23% | 33% | 20% | 18%
Rural | 14%^†^ | 19%^†^ | 13% | 11%
Health and Functional Status
Disability Composite
*Yes to any disability | 17% | 23% | 14% | 11%
No to all disabilities | 23% | 33%^†^ | 19% | 19%^†^
Chronic health condition
*Yes | 21% | 31% | 17% | 16%
No | 22% | 31% | 18% | 18%

Notes: Weighted Percentages.

* Denotes reference category.

† items in bolded italic green font are significantly different from reference category, p<0.05

SOURCE: 2014 Consumer Survey of Attitudes Toward the Privacy and Security Aspects of Electronic Health Records and Health Information Exchange

## References

1 Office of the National Coordinator for Health Information Technology. 'Trends in Individuals Use of Health IT: 2012 – 2014,' Health IT Quick-Stat #46. dashboard.healthit.gov/quickstats/pages/FIG-Individuals-Health-IT-Use.php. June 2015.
2 Patel V., Barker W. & Siminerio E. (October 2015). Trends in Consumer Access and Use of Electronic Health. ONC Data Brief, no.30. Office of the National Coordinator for Health Information Technology: Washington DC.
3 Patel V., Barker W. & Siminerio E. (June, 2015). Disparities in Individuals’ Access and Use of Health IT in 2013. ONC Data Brief, no.26. Office of the National Coordinator for Health Information Technology: Washington DC.
4 Charles, D., Gabriel, M., Henry, J. (October 2015) Electronic Capabilities for Patients among U.S. Non-Federal Acute Care Hospitals: 2008–2014. ONC Data Brief, no.29. Office of the National Coordinator for Health Information Technology: Washington DC.
5 Heisey-Grove, D., Patel, V., Searcy, T. (September 2015) Physician electronic exchange of patient health information, 2014. ONC Data Brief, no. 31. Office of the National Coordinator for Health Information Technology: Washington DC.
6 HINTS: Health Information National Trends Survey. http://hints.cancer.gov/about.aspx

## Acknowledgements

MITRE and NORC at the University of Chicago contributed to the development of the survey instrument, survey administration, and data analysis.