# 3 ONC's Community College Program Trains Over 12,000 Health IT Professionals

The Health Information Technology for Economic and Clinical Health (HITECH) Act of 2009 directed the Office of the National Coordinator for Health Information Technology (ONC) to train healthcare and information technology students to ensure the rapid and effective utilization and development of health information technology.^1^ This brief describes trends in program attainment and student demographics for the Community College Consortia to Educate Health IT Professionals Program (“Community College Consortia”), a part of ONC’s Health IT Workforce Development Program.

## The Community College Consortia Program has trained more than 12,000 health IT professionals since its inception.

Figure 1 Number of students who successfully completed the Community College Consortia Program: March 31, 2012

Figure 1: A cumulative line graph that shows 12,082 students successfully completed the Community College Consortia Program as of March 31, 2012. The x-axis covers the date range from November 2010 to March 2012, with one-month intervals. The completion rate is nearly flat from November 2010 to February 2011, with a jump to nearly 2,000 completions in March 2011. There is a steady growth in completions through the remaining period. SOURCE: ONC analysis of Community College Consortia Program data

SOURCE: ONC analysis of Community College Consortia Program data

➢ The Community College Consortia Program has collectively trained an average of 900 students per month since April 2011 (Figure 1).

## The Community College Consortia Program has trained students in all 50 states.

Figure 2 Number of students who successfully completed the Community College Consortia Program by state: March 31, 2012

NOTES: Each point on the map represents a participating community college.

For an interactive view, please visit http://dashboard.healthit.gov/college/ .

Figure 2: A map of the United States of America that shows how many students have successfully completed the Community College Consortia Program as of March 31, 2012 by state. Washington, Oregon, California, North Dakota, Texas, Michigan, Ohio, Florida, North Carolina, Virginia, New Jersey, and New York each have between 401 to 1, 000 students completing. Utah, Colorado, South Dakota, and Wisconsin each have between 301 to 400 students completing. Idaho, Montana, Arizona, Nebraska, Minnesota, Missouri, Louisiana, Illinois, Tennessee, Pennsylvania, and Georgia each have 151 to 300 students completing. Nevada, Kansas, Oklahoma, Iowa, Kentucky, Mississippi, South Carolina, West Virginia, Maryland, Connecticut, Vermont, Alaska, and Maine each have between 51 to 150 students completing. Wyoming, New Mexico, Arkansas, Alabama, Indiana, Delaware, Rhode Island, New Hampshire, District of Columbia, Massachusetts, Hawaii, the Virgin Islands, and Puerto Rico each have between 1 and 50 students completing. SOURCE: ONC analysis of Community College Consortia Program data

SOURCE: ONC analysis of Community College Consortia Program data

➢ Twelve states have more than 400 students successfully completing the program (Figure 2).

## Each of the Community College Consortia regions has trained over 1,500 students.

Figure 3 Number of students who successfully completed and are actively enrolled in the Community College Consortia Program by region: March 31, 2012

Figure 3: A stacked vertical bar graph showing the number of students that have successfully completed and are actively enrolled in the Community College Consortia Program by region as of March 31 2012, with the x-axis indicating the region and the y-axis indicating the number of students (scale is in thousands). The Northwest region has 3,828 students that have successfully completed and 69 students that are actively enrolled. The Southwest region has 1,568 students that have successfully completed, and 1,124 that are actively enrolled. The Midwest region has 2,315 students that have successfully completed, and 1,692 students that are actively enrolled. The South region has 2,162 students that have successfully completed, and 2,758 students that are actively enrolled. The Northeast region has 2,209 students that have successfully completed, and 928 students that are actively enrolled. SOURCE: ONC analysis of Community College Consortia Program data

SOURCE: ONC analysis of Community College Consortia Program data

➢ There are over 6,500 students actively enrolled in the Community College Consortia Program (Figure 3).
➢ The region with highest number of student completions is the Northwest region, led by Bellevue Community College, which trained 3,828 students.

## The majority of Community College Consortia students have prior experience in fields outside of Health IT.

Figure 4 Prior experience of students who successfully completed the Community College Consortia Program: March 31, 2012

Figure 4: A stacked horizontal bar graph that shows the prior experience of students who successfully completed the Community College Consortia Program as of March 31, 2012, with the x-axis indicating the region and the y-axis indicating the percent of students by experience category. The breakdown at a national-level shows 24% of students have prior experience in health information technology, 38% of students had prior experience in healthcare (not information technology), 21% of students had prior experience in information technology (not healthcare), and 17% of students had prior experience in other fields or is not reported. The breakdown in the Northwest shows 41% of students have prior experience in health information technology, 37% of students had prior experience in healthcare (not information technology), 6% of students had prior experience in information technology (not healthcare), and 17% of students had prior experience in other fields or is not reported. The breakdown in the Southwest 17% of students have prior experience in health information technology, 42% of students had prior experience in healthcare (not information technology), 31% of students had prior experience in information technology (not healthcare), and 10% of students had prior experience in other fields or is not reported. The breakdown in the Midwest shows 18% of students have prior experience in health information technology, 31% of students had prior experience in healthcare (not information technology), 30% of students had prior experience in information technology (not healthcare), and 21% of students had prior experience in other fields or is not reported. The breakdown in the South shows 16% of students have prior experience in health information technology, 50% of students had prior experience in healthcare (not information technology), 27% of students had prior experience in information technology (not healthcare), and 7% of students had prior experience in other fields or is not reported. The breakdown in the Northeast shows 15% of students have prior experience in health information technology, 32% of students had prior experience in healthcare (not information technology), 25% of students had prior experience in information technology (not healthcare), and 28% of students had prior experience in other fields or is not reported. SOURCE: ONC analysis of Community College Consortia Program data

SOURCE: ONC analysis of Community College Consortia Program data

➢ More students had prior experience in Healthcare (38%) and Information Technology (21%), relative to those with experience in Health IT (24%) (Figure 4).

## Community College Consortia Program students have varied and diverse characteristics.

Table 1 Demographic characteristics for students who successfully completed the Community College Consortia Program: March 31, 2012

Consortium | Rural | Minority Status | Student Age
Consortium | Rural | Minority Status | Mean | Min | Max
Northwest | 30.6% | 14.9% | 42.2 | 18 | 79
Southwest | 10.1% | 42.1% | 46.1 | 19 | 78
Midwest | 6.4% | 30.2% | 46.2 | 20 | 74
South | 12.5% | 38.4% | 46.1 | 20 | 76
Northeast | 4.9% | 27.2% | 47.0 | 19 | 78
National | 15.3% | 27.8% | 45.1 | 18 | 79

SOURCE: ONC analysis of Community College Consortia Program data

➢ The average age of students completing the program was 45 years old (Table 1).
➢ 15% of students successfully completing the program reside in rural areas.
➢ More than one in four students (28%) was non-Caucasian.

## Summary

The HITECH Act has spurred significant investment in the adoption and meaningful use of EHR systems.^2^ Greater EHR adoption is projected to increase the demand for skilled professionals to implement, support, and use health IT. The estimated shortage in the health IT workforce has ranged from 37,700 to 41,000.^3,^ ^4^ Since HITECH’s passage in 2009, the number of online postings for health IT jobs has tripled.^5^

To address increased demand for health IT workers, ONC invested $116 million in the Health IT Workforce Development Program, which consists of four initiatives: Community College Consortia to Educate Health IT Professionals, Curriculum Development Centers Program, Competency Exam Program, and Program for Assistance for University-Based Training.^6^

Under the Community College Consortia Program, ONC committed $68 million to five regional groups to develop or improve non-degree health IT training programs that can be completed in six months or less. The five regions collectively supported 82 community colleges nationwide (Appendix Table 1), offering in-person and distance learning programs with a goal of training 10,500 students by 2012. ONC designed this intensive training program for professionals with healthcare or IT experience. Students are trained in one or more of the following roles: practice workflow and information management redesign specialists; clinician/practitioner consultants; implementation support specialists; implementation managers; technical/software support; and trainers.^6^

Since its launch in September 2010, the Community College Consortia Program has rapidly trained more than 12,000 professionals nationwide. The majority of students are mid-career healthcare or IT professionals with prior experience in fields outside health IT. Student demographics included significant minority and rural representation. By leveraging distance learning platforms, the program has trained students in all 50 States, the District of Columbia, and Puerto Rico.

## Data Source

Each consortium is required to report student data on monthly basis to ONC. Data reported includes: enrollment status; training start date; training end date; zip code of student’s address; date of birth, minority status; prior experience. ONC merges the zip codes with the Area Resource File to designate whether the student resides in a rural location.

## Definitions

Successfully completed: Enrollment status for students that completed all program requirements.
Actively enrolled: Enrollment status for students actively participating in the program. Excludes students who have withdrawn or on leave.
Rural location: Designates whether the student lives in a rural location based on the zip code of the student’s address. Rural designations were based on the U.S. Census Bureau definition that includes micropolitan and non-CBSA (Core-Based Statistical Area).
Minority status: Self-reported information on whether students are Caucasian or non-Caucasian.
Prior experience: Self-reported information on whether students had experience prior to enrolling in the program in: Health IT; Healthcare, not IT-related; IT, not healthcare-related; or Other/not reported.

## References

1 Health Information Technology for Economic and Clinical Health (HITECH) Act, Title XIII of Division A and Title IV of Division B of the American Recovery and Reinvestment Act of 2009 (ARRA), Pub. L. No. 111–5 (Feb. 17, 2009),
2 Blumenthal D. Launching HITECH. N Engl J Med. 2010;362(5):382–5.20042745
3 Bureau of Labor Statistics, U.S. Department of Labor, Occupational Outlook Handbook, 2012–13 Edition, Medical Records and Health Information Technicians.
4 Hersh WR, Wright A. What Workforce is Needed to Implement the Health Information Technology Agenda? An Analysis from the HIMSS Analytics™ Database. AMIA Annual Symposium Proceedings. 2008; 303–307.
5 Furukawa MF, Vibbert D, Swain M. HITECH and Health IT Jobs: Evidence from Online Job Postings. ONC Data Brief, no. 2. Washington, DC: Office of the National Coordinator for Health Information Technology, May 2012.
6 NORC at the University of Chicago. Overview of ONC’s Workforce Development Program. 2011. Access at: http://www.healthit.gov/sites/default/files/pdf/onc-work-force-development-program-annual-report-2011.pdf

## Acknowledgements

Special thanks to Chitra Mohla, Cinyon Reed and Mat Kendall of the ONC Community College Consortia Program team.

Appendix Table 1 Participants in the Community College Consortia Program

Region | School Name | City | State
Region A:; Northwest | Bellevue College (Lead) | Bellevue | WA
Region A:; Northwest | Dakota State University | Madison | SD
Region A:; Northwest | Lake Region State College | Devil’s Lake | ND
Region A:; Northwest | Montana Tech | Butte | MT
Region A:; Northwest | North Idaho College | Coeur d’Alene | ID
Region A:; Northwest | Portland Community College | Portland | WA
Region A:; Northwest | Pueblo Community College | Pueblo | CO
Region A:; Northwest | Salt Lake Community College | Salt Lake City | UT
Region B:; Southwest | Butte College | Oroville | CA
Region B:; Southwest | College of Southern Nevada | Las Vegas | NV
Region B:; Southwest | Cosumnes River College | Sacramento | CA
Region B:; Southwest | Cypress College | Cypress | CA
Region B:; Southwest | East Los Angeles College | Monterey Park | CA
Region B:; Southwest | Los Rios Community College District (Lead) | Sacramento | CA
Region B:; Southwest | Fresno City College | Fresno | CA
Region B:; Southwest | Maricopa College | Phoenix | AZ
Region B:; Southwest | Mission College | Santa Clara | CA
Region B:; Southwest | Orange Coast College | Costa Mesa | CA
Region B:; Southwest | Pima College | Tucson | AZ
Region B:; Southwest | San Diego Mesa College | San Diego | CA
Region B:; Southwest | Santa Barbara City College | Santa Barbara | CA
Region B:; Southwest | Santa Monica Community College | Santa Monica | CA
Region B:; Southwest | University of Hawaii College - Kapiolani | Honolulu | HI
Region C:; Midwest | Cincinnati State Technical and Community College | Cincinnati | OH
Region C:; Midwest | Columbus State Community College | Columbus | OH
Region C:; Midwest | Cuyahoga Community College (Lead) | Cleveland | OH
Region C:; Midwest | Delta College | University Center | MI
Region C:; Midwest | Des Moines Area Community College | Ankeny | IA
Region C:; Midwest | Johnson County Community College | Overland Park | KS
Region C:; Midwest | Kirkwood Community College | Cedar Rapids | IA
Region C:; Midwest | Lansing Community College | Lansing | MI
Region C:; Midwest | Macomb Community College | Warren | MI
Region C:; Midwest | Madison Area Technical College | Madison | WI
Region C:; Midwest | Metropolitan Community College | Omaha | NE
Region C:; Midwest | Milwaukee Area Technical College | Milwaukee | WI
Region C:; Midwest | Moraine Valley Community College | Palos Hills | IL
Region C:; Midwest | Normandale Community College | Bloomington | MN
Region C:; Midwest | Sinclair Community College | Dayton | OH
Region C:; Midwest | St. Louis Community College | St. Louis | MO
Region C:; Midwest | Wayne County Community College District | Detroit | MI
Region D:; South | Atlanta Technical College | Atlanta | GA
Region D:; South | Broward College | Coconut Creek | FL
Region D:; South | Catawba Valley Community College | Hickory | NC
Region D:; South | Central Piedmont Community College | Charlotte | NC
Region D:; South | Chattanooga State Community College | Chattanooga | TN
Region D:; South | Dallas County Community College District | Dallas | TX
Region D:; South | Delgado Community College | New Orleans | LA
Region D:; South | Dyersburg State Community College | Dyersburg | TN
Region D:; South | Florence-Darlington Technical College | Florence | SC
Region D:; South | Hinds Community College | Raymond | MS
Region D:; South | Houston Community College | Houston | TX
Region D:; South | Indian River State College | Ft. Pierce | FL
Region D:; South | Itawamba Community College | Tupelo | MS
Region D:; South | Jefferson Community & Technical College | Louisville | KY
Region D:; South | Midland College | Midland | TX
Region D:; South | National Park Community College | Hot Springs | AR
Region D:; South | Pitt Community College (Lead) | Winterville | NC
Region D:; South | Santa Fe College | Gainesville | FL
Region D:; South | Tulsa Community College | Tulsa | OK
Region D:; South | Walters State Community College | Morristown | TN
Region E:; Northeast | Bristol Community College | Fall River | MA
Region E:; Northeast | Bronx Community College | Bronx | NY
Region E:; Northeast | Brookdale Community College | Lincroft | NJ
Region E:; Northeast | Burlington Community College | Pemberton | NJ
Region E:; Northeast | Camden County College | Blackwood | NJ
Region E:; Northeast | Capital Community College | Hartford | CT
Region E:; Northeast | Community College of Allegheny County | Pittsburgh | PA
Region E:; Northeast | Community College of Baltimore County | Baltimore City | MD
Region E:; Northeast | Community College of the District of Columbia | Washington | DC
Region E:; Northeast | Community College of Vermont | Waterbury | VT
Region E:; Northeast | Essex County College | Newark | NJ
Region E:; Northeast | Gloucester County College | Sewall | NJ
Region E:; Northeast | Kennebec Valley Community College | Fairfield | ME
Region E:; Northeast | Northern Virginia Community College | Annandale | VA
Region E:; Northeast | Ocean County College | Toms River | NJ
Region E:; Northeast | Passaic County Community College | Paterson | NJ
Region E:; Northeast | Raritan Valley Community College | Branchburg | NJ
Region E:; Northeast | Southern Maine Community College | South Portland | ME
Region E:; Northeast | Suffolk County Community College | Brentwood | NY
Region E:; Northeast | Tidewater Community College (Lead) | Virginia Beach | VA
Region E:; Northeast | West Virginia Northern Community College | Wheeling | WV
Region E:; Northeast | Westchester Community College | Valhalla | NY

NOTES: Consortium lead designated in parentheses.